# 8 REGULATIONS AND ADVISORIES

Table 8-1 summarizes international, national, and state regulations and guidelines on human exposure to PBBs.

ATSDR has derived an MRL of 0.01 mg/kg/day for acute-duration oral exposure to PBBs. The MRL is based on a NOAEL for thyroid effects in rats (Allen-Rowland et al. 1981). Intermediate- and chronic-duration oral MRLs were not derived because serious developmental effects (fetal abortion and stillbirths) were observed in monkeys that had been exposed to PBBs for durations that spanned the intermediate and chronic categories at the lowest dose tested in the database. This dose, 0.012 mg/kg/day, caused increased menstrual cycle duration and implantation bleeding after 6–7 months of exposure and fetal deaths after 1 year of exposure in monkeys, with surviving infants having decreased birth weight and decreased postnatal weight gain and weight loss also occurring in maternal animals (Allen et al. 1978, 1979; Lambrecht et al. 1978). The reproductive effects are less serious, but concern for serious developmental toxicity following exposures of >1 year precludes deriving an MRL for intermediate-duration exposure. Derivation of an MRL for chronic oral exposure is precluded by the serious developmental effects that occurred following exposures exceeding 1 year in duration.

IARC (1987) has classified decabromobiphenyl, hexabromobiphenyl, and octabromobiphenyl in Group 2B, possibly carcinogenic to humans. NTP (2002) has classified decabromobiphenyl, octabromobiphenyl, and polybrominated biphenyl as reasonably anticipated to be human carcinogens.

Table 8-1 Regulations and Guidelines Applicable to PBBs^a^

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 1987
IARC | Decabromobiphenyl | Group 2B^b^ | IARC 1987
IARC | Hexabromobiphenyl | Group 2B^b^ | IARC 1987
IARC | Octabromobiphenyl | Group 2B^b^ | IARC 1987
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | No data
NIOSH | REL (10-hour TWA) | No data
OSHA | PEL (8-hour TWA) | No data
b. Water
| Suggested EPA method | 8270 | 40CFR264,
| PQL | 10 μg/L | Appendix IX
d. Food
FDA | Indirect food additives; substances for use only as components of adhesives | | FDA 2001; 21CFR175.105 (c)(5)
FDA | Hexabromo-1,1’-biphenyl | | FDA 2001; 21CFR175.105 (c)(5)
e. Other
EPA | Chemical substances subject to proposed or final TSCA rules or orders | Regulated under [underlined: TSCA section(s)] | EPA 1998
EPA | Decabromobiphenyl | 5(a)(2) | EPA 1998
EPA | Hexabromo-1,1’-biphenyl | 5(a)(2) | EPA 1998
EPA | Octabromobiphenyl | 5(a)(2) | EPA 1998
EPA | Chemicals subject to the Prior Informed Consent Procedure: International right-to-know | | EPA 2002g
EPA | Decabromobiphenyl | | EPA 2002g
EPA | Hexabromobiphenyl | | EPA 2002g
EPA | Octabromobiphenyl | | EPA 2002g
EPA | Toxic chemical release reporting; community right-to-know; effective date for reporting | | EPA 2002h; 40CFR372.65(c)
EPA | Polybrominated biphenyls | 01/01/87 | EPA 2002h; 40CFR372.65(c)
EPA | TSCA; significant new uses subject to reporting of polybrominated biphenyl | The significant new use is any use | EPA 2002n; 40CFR721.1790
EPA | Decabromodiphenyl | | EPA 2002n; 40CFR721.1790
EPA | Hexabromo-1,1’-biphenyl | | EPA 2002n; 40CFR721.1790
EPA | Octabromobiphenyl | | EPA 2002n; 40CFR721.1790
NTP | Carcinogenicity classification | | NTP 2002
NTP | Decabromobiphenyl | Reasonably anticipated to be human carcinogens | NTP 2002
NTP | Octabromobiphenyl | | NTP 2002
NTP | Polybrominated biphenyl | | NTP 2002

a Polybrominated biphenyls category includes: decabromobiphenyl (CAS# 13654-09-6); hexabromobiphenyl (CAS# 59080-40-9); hexabromo-1,1’-biphenyl (CAS# 36355-01-8); ; octabromobiphenyl (CAS# 27858-07-7); octabromobiphenyl (CAS# 61288-13-9) (CAS# 32534-81-9); polybrominated biphenyl (CAS# 59536-65-1); and polybrominated biphenyl mixture (CAS# 67774-32-7).

b Group 2B: possibly carcinogenic to humans.

ACGIH = American Conference of Governmental Industrial Hygienists; CFR = Code of Federal Regulations; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation limits; REL = recommended exposure limit; TLV = threshold limit value; TSCA = Toxic Substances Control Act; TWA = time-weighted average