# 6 POTENTIAL FOR HUMAN EXPOSURE

## 6.1 OVERVIEW

PBBs have been identified in at least 9 of the 1,647 hazardous waste sites that have been proposed for inclusion on the EPA National Priorities List (NPL) (HazDat 2004). However, the number of sites evaluated for PBBs is not known. The frequency of these sites can be seen in Figure 6-1. Of these sites, all are located within the United States and none are located in the Commonwealth of Puerto Rico (not shown).

The production of PBBs in the United States ceased in 1979 (IARC 1986). In the past, PBBs were released to the environment during the manufacture of these compounds and disposal of commercial and consumer products containing these compounds (Hesse and Powers 1978; Neufeld et al. 1977). One of the significant sources of environmental contamination occurred as a result of the accidental mixup of FireMaster BP-6 with cattle feed in a number of farms in the lower peninsula in Michigan (see Section 3.2 for additional details concerning this incident). By June 1975, 412 farms had been quarantined. Disposal of contaminated feed, animal carcasses (poultry, dairy cattle, swine), and animal products (dairy, meat, eggs) contributed to environmental contamination (Dunckel 1975; Kay 1977). No information was located on the current levels of contamination at these locations.

PBBs can exist as 209 different congeners, but only about 42 have been synthesized (Sundstrom et al. 1976b). Environmental contamination of PBBs is likely to have occurred mainly from the two commercial products, FireMaster BP-6 and FireMaster FF-1. The principal component in both of these commercial products was 2,2’,4,4’,5,5’-hexabromobiphenyl or BB-153 (Robertson et al. 1983b).

PBBs are strongly adsorbed to soil and sediment (Filonow et al. 1976; Hesse and Powers 1978) and usually persist in the environment (Jacobs et al. 1978). Adsorption of PBBs generally increases as bromination of the PBBs and organic carbon content of soil and sediment increase (Filonow et al. 1976; Griffin and Chou 1981a, 1981b). As a result, the leaching of commercial mixtures of PBBs from soil is slow. Leaching studies with four Michigan soils mixed with 100 mg/kg 2,2’,4,4’,5,5’-hexabromobiphenyl showed that <0.6% of the compound leached through soils after a 19-day period. Leachate quantities in this study were equivalent to 20 times the average annual rainfall in Michigan (Filonow et al. 1976). The PBBs in commercial mixtures resist both chemical and biological degradation (Jacobs et al. 1978; Kawasaki 1980; Shelton and Tiedje 1981), although biotic debromination to lower brominated products may occur in anaerobic zones of contaminated sediment and soil (Morris et al. 1992).

Figure 6-1 Frequency of NPL Sites with PBB Contamination

Derived from HazDat 2004

PBBs with six or fewer bromine substitutions bioconcentrate in aquatic organisms such as fish, but the octabromo- and decabromobiphenyls do not bioconcentrate significantly in fish (Gobas et al. 1989; Norris et al. 1973; Opperhuizen et al. 1985; Veith et al. 1979; Zitko 1979; Zitko and Hutzinger 1976). Orchard grass, alfalfa, corn, and tops of carrots grown in soil contaminated with PBBs showed no uptake of PBBs, and only minor uptake occurred on carrot roots (Jacobs et al. 1976, 1978). Although PBBs were detected in fish-eating birds and predatory animals that had consumed PBB-contaminated food (Heinz et al. 1983, 1985), the biomagnification potential of PBBs in predators resulting from such consumption remains unknown.

PBBs were detected in air, water, sediment, and soil in the vicinity of the manufacturing plants and in groundwater from a landfill site (DeCarlo 1979; Hesse and Powers 1978; Shah 1978). PBBs were also detected in soil near the contaminated farms in Lower Michigan (Fries and Jacobs 1980). The distribution of PBBs was limited to the environment in the vicinity of production sites and the contaminated farm sites. Studies have identified PBBs in marine mammals from coastal seas and the Atlantic Ocean (de Boer et al. 1998c). Data regarding the current levels of PBBs in ambient air, drinking water, or food were not located.

No estimate on PBB intake by the general population from air, water, and food was located in the literature. Current intake of PBBs for the general population is expected to be zero or very small. Populations near the contaminated farms in Lower Michigan may still have low exposures from air, water, and food. The level of PBBs in human tissue and body fluids in the exposed population of Michigan has been extensively studied (Brilliant et al. 1978; Cordle et al. 1978; Eyster et al. 1983; Humphrey and Hayner 1975; Lambert et al. 1990; Landrigan et al. 1979; Wolff et al. 1979a, 1982). The finding that PBBs are stored in fatty tissues of the human body and are very slowly excreted (Eyster et al. 1983) indicates a slow decline in the body burden for exposed individuals.

## 6.2 RELEASES TO THE ENVIRONMENT

The production of PBBs in the United States ceased in 1979 (IARC 1986). In the past, PBBs were released to the environment during the manufacture of these compounds and disposal of commercial and consumer products containing these compounds (Hesse and Powers 1978; Neufeld et al. 1977). One of the significant sources of environmental contamination occurred as a result of the accidental mixup of FireMaster BP-6 with cattle feed in a number of farms in the lower peninsula in Michigan (see Section 3.2 for additional details concerning this incident). By June 1975, 412 farms had been quarantined. Disposal of contaminated feed, animal carcasses (poultry, cattle, swine), and animal products (meat, milk, eggs) contributed to environmental contamination (Dunckel 1975; Kay 1977).

### 6.2.1 Air

In the past, PBBs were released into the air during the manufacture of these compounds in three areas: through the vents of the hydrogen bromide recovery system, from the centrifugation area for recovering PBBs from slurries produced by bromination, and from the drying, pulverizing, and bagging area of the finished product (Di Carlo et al. 1978). An estimated 0.07 pounds/million pounds of the PBBs produced were lost from the hydrogen bromide-recovery vent (Di Carlo et al. 1978). No data are available for the air pollution factor (amount released/million pounds produced) at the centrifugation site. The concentrations of FireMaster BP-6 in the Michigan Chemical Corporation bagging area were 0.016–0.032 mg/L of air during the bagging operation and 0.003 mg/L of air after the completion of bagging (Di Carlo et al. 1978). In 1977, the maximum air losses of PBBs at production sites were estimated to total 1,125 pounds of PBBs for every 1 million pounds of PBBs produced (Di Carlo et al. 1978).

Another process that could release lower levels of brominated biphenyls in the air is the incineration of PBBs. Pyrolysis of hexabromobiphenyl in the absence and presence of air has produced small amounts of lower brominated biphenyls (Thoma and Hutzinger 1987). No data are available on the importance of this source for the release of PBBs in the air during the incineration of PBBs. However, since the vast majority of products containing PBBs are expected to be out of circulation after more than 25 years since the voluntary ban, incineration will not be a significant source of PBBs to air.

PBBs have been identified in 1 air sample, collected from 1,647 NPL hazardous waste sites, where they were detected in some environmental media (HazDat 2004).

### 6.2.2 Water

In the past, PBBs were released to water during the manufacturing process. An estimated 0.0046 pounds were lost to sewers for every 1,000,000 pounds of PBBs produced at manufacturing sites (Neufeld et al. 1977). To manufacture PBBs, water was added to the reaction mixture when the desired extent of bromination was achieved. Ultimately, this water was discharged as effluent into surface water. Samples of effluents from the Michigan Chemical Corporation contained PBB concentrations 98–503 ppm (Di Carlo et al. 1978). Runoff water from the manufacturing plants containing PBBs also contaminated surface water (Di Carlo et al. 1978). Landfill sites used to dispose of wastes from PBB production can also be a source of PBBs in water. Concentrations of PBBs in groundwater from one such landfill in St. Louis, Michigan were low (0.1–0.2 ppb), but those in water from a drainage ditch and catch basin were much higher (0.35–1.2 ppm) (Di Carlo et al. 1978).

PBBs have been identified in 2 and 5 surface water and groundwater samples, respectively, collected from 1,647 NPL hazardous waste sites (HazDat 2004).

### 6.2.3 Soil

The important former sources of PBBs in soil are manufacturing operations, disposal of PBB-containing finished products, and agricultural operations contaminated in the original episode in 1973–1974. The concentrations of PBBs in soils from bagging and loading areas of the Michigan Chemical Corporation were 3,500 and 2,500 mg/kg, respectively (Di Carlo et al. 1978). Similarly, soil from sites adjacent to the Hexcel Corp and the White Chemical Company, the manufacturers of octabromo- and decabromobiphenyl, contained decabromobiphenyl and other lower brominated biphenyls down to hexabromobiphenyl (Di Carlo et al. 1978). The disposal into landfills of solid wastes generated during the production of PBBs was another important source of PBBs in soil (Neufeld et al. 1977). Photodecomposition of FireMaster BP-6 in soil could also be a source of lower brominated biphenyls (Ruzo and Zabik 1975; Trotter 1977) in soil.

Approximately 11.8 million pounds (5,350,000 kg) of hexabromobiphenyl was used in commercial and consumer products in the United States, mostly in the production of plastic products. Since the cessation of production of hexabromobiphenyl, all of these products, such as TV cabinet and business-machine housings, with a usable life of 5–10 years must have been disposed of by landfilling or incineration (Neufeld et al. 1977). Disposal of these plastic materials in waste-disposal sites is an important source of PBBs in soil. The migration of plastic-incorporated PBBs to soil would be very low since PBBs would be tightly bound into the plastic (Neufeld et al. 1977).

The indirect source of PBBs in soil was the contaminated farms in Michigan. Approximately 650 pounds (290 kg) of PBBs was mixed in cattle feeds that were delivered to Michigan farms during 1973–1974 (Fries 1985b). About 50% of this amount was excreted in the feces of the exposed animals and remained on the farms in places of fecal deposition and manure disposal (Fries 1985b). Soil in fields that received contaminated manure contained as high as 300 μg/kg PBBs, whereas soil in resurfaced cattle-exercise lots contained as high as 1,000–2,000 μg/kg of PBBs (Fries 1985b).

PBBs have been identified in 5 soil and 3 sediment samples collected from 1,647 NPL hazardous waste sites (HazDat 2004).

## 6.3 ENVIRONMENTAL FATE

### 6.3.1 Transport and Partitioning

PBBs exist predominantly in the particulate phase in the atmosphere. Particulate phase PBBs are removed from the atmosphere by wet and dry deposition and should not travel long distances in the environment. In water, PBBs are expected to absorb strongly to suspended solids and sediment, and may bioconcentrate in aquatic organisms. The volatilization of PBBs from water to air is not expected to be important due to attenuation by adsorption in the water column. In soil, PBBs are adsorbed strongly and will be immobile. Volatilization of PBBs from soil to air is not important due to the low volatility of PBBs and strong adsorption of PBBs to soil.

Organic compounds with vapor pressures >10^−4^ mm Hg should exist almost entirely in the vapor phase in the atmosphere, while organic compounds with vapor pressures <10^−8^ mmHg should exist almost entirely in the particulate phase (Eisenreich et al. 1981). The estimated vapor pressure of FireMaster BP-6 is 5.2x10^−8^ mm Hg at 25 °C (Jacobs et al. 1976). The vapor pressure of octabromobiphenyl is 7.0x10^−11^ mm Hg at 28 °C (Waritz et al. 1977). Although no data are available, the vapor pressures of decabromobiphenyl at ambient temperatures should be lower than octabromobiphenyl. Thus, PBBs produced in the 1970s should exist predominantly in the particulate phase in the atmosphere. Since the particulate phase PBBs would precipitate out by dry deposition and wet deposition due to washout (Atlas and Giam 1987), PBBs would not be expected to be transported long distances in the atmosphere.

There are limited data regarding the transport and partitioning of PBBs in water. Based on an estimated Henry’s law constant of 3.9x10^−6^ atm-m^3^/mol (where Henry’s law constant = vapor pressure/water solubility) and an estimation method (Thomas 1990), the estimated volatilization half-life of hexabromobiphenyl is 23 days. Therefore, the transport of PBBs from water to the atmosphere by volatilization is not expected to be important. This is consistent with a fish bioconcentration study in which losses of octabromobiphenyl and decabromobiphenyl from water to air were found to be insignificant (Norris et al. 1973). Soil-mobility studies have shown that PBBs are strongly adsorbed by soil materials (Filonow et al. 1976; Griffin and Chou 1981a, 1981b). Therefore, sorption of water-bound PBBs to particulate matter and sediment is a major transport process for PBBs in water. The detection of at least a 1,000-fold higher concentration of PBBs in Pine River sediment (where effluent from Michigan Chemical Corporation was discharged) compared with the level of PBBs in the river water confirms the importance of this transport process (Hesse and Powers 1978).

PBBs may also be transported from water to aquatic organisms in which bioconcentration may take place. Data from different laboratories on the bioconcentration of PBBs in fish show wide variation. The experimentally determined bioconcentration factor (BCF; the BCF is the concentration of the chemical in fish tissues over concentration of chemical in water) for hexabromobiphenyl (mixtures of unspecified congeners) in the whole body of fathead minnows (Pimephales promelas) was 18,100 in a 32-day exposure (Veith et al. 1979). In fillet of fathead minnow, the estimated BCF was >10,000 (Hesse and Powers 1978). The lipid weight-based BCF values of 4,4’-dibromobiphenyl, 2,4,6-tribromobiphenyl, 2,2’,5,5’-tetrabromobiphenyl, and 2,2’,4,4’,6,6’-hexabromobiphenyl in guppies (Poecilia reticulata) were 269,000; 115,000; 1,440,000; and 708,000; respectively (Gobas et al. 1989). BCF values for mono- to tetra- bromobiphenyl congeners tend to increase with higher degrees of bromination while BCF values for tetra- and higher congeners tend to decrease with higher degrees of bromination. A similar trend in BCF values for various PBBs was also observed in juvenile Atlantic salmon (Salmo salar). For example, the whole body BCF values determined for 2,6-dibromobiphenyl, 2,4-dibromobiphenyl, 3,4-dibromo-biphenyl, 2,5,4’-tribromobiphenyl, 2,2’,4,5’-tetrabromobiphenyl, 2,3’,4’,5-tetrabromobiphenyl, hexabromobiphenyl (unspecified congener), and octabromobiphenyl were 1,267, 1,343, 63, 425, 314, 111, 2–48, and 0.02, respectively (Zitko 1979; Zitko and Hutzinger 1976). The BCF values determined for 2,2’,3,3’,4,4’-hexabromobiphenyl and decabromobiphenyl in whole body guppies (P. reticulata) were 10 and 0, respectively (Opperhuizen et al. 1985). The BCF value for octabromobiphenyl in filleted rainbow trout (Salmo gairdneri) was 0 (Norris et al. 1973). The lack of accumulation for the higher brominated compounds is most likely because they have very limited water solubility and are therefore not available to penetrate membranes (Zitko 1979).

PBBs are adsorbed strongly to soil, and the adsorption increases with an increase in the organic carbon content of soil (Filonow et al. 1976; Griffin and Chou 1981a, 1981b). Neither clay content nor pH of soil correlated with adsorption of hexabromobiphenyl to soil (Filonow et al. 1976). PBBs present in soil-water solution will partition to the soil solids by adsorption. The presence of certain types of dissolved organic carbon in natural water (e.g., leachate from a landfill) may decrease the adsorption of PBBs in sediments (Simmons and Kotz 1982). Because of the strong adsorption, PBBs will have low mobility in soil, and the leaching of PBBs from soil to groundwater will generally be insignificant (Filonow et al. 1976; Griffin and Chou 1981a, 1981b). However, the mobility of PBBs may greatly increase if methanol or other organic solvents (capable of solubilizing PBBs) are present at significant concentrations in soil as would happen at some contaminated sites (Griffin and Chou 1981b). This phenomenon is commonly called “co-solvency.” The transport of PBBs from soil to the atmosphere by volatilization is not important due to the low volatility and strong adsoprtion of PBBs (Jacobs et al. 1976). The transport of PBBs from soil to surface water or another land area via eroded soil contained in runoff water is possible (Jacobs et al. 1976). Orchard grass and tops of carrots grown in soil contaminated with PBBs showed no uptake, and carrot roots showed only minor uptake of PBBs (Jacobs et al. 1976, 1978). Therefore, the transport of PBBs from soil to plants via translocation is insignificant.

### 6.3.2 Transformation and Degradation

Photolysis appears to be the dominant transformation process for PBBs. However, the importance of photochemical transformation reactions in the environment cannot be determined due to lack of information. Based on a very limited number of studies, biodegradation does not appear to be significant for PBBs.

#### 6.3.2.1 Air

In air, the two processes that may result in significant degradation or transformation of PBBs are photooxidation by hydroxyl (OH) radicals and direct photolysis. The estimated half-life of pentachlorobiphenyl in air due to reaction with hydroxyl radicals is 41.6–83.2 days (Atkinson 1987a). Based on a structure-activity relationship for the estimation of half-lives for the gas-phase reactions of hydroxyl radicals with organic compounds (Atkinson 1987b), the estimated half-lives of hexabromobiphenyl and decabromobiphenyl due to reaction with OH radicals are 182 and 2,448 days, respectively. These half-lives are consistent with the half-life of pentachlorobiphenyl due to reaction with OH radicals. However, the half-lives of brominated biphenyls expected to be present in the particulate phase in the air may be even longer than the estimated half-lives due to gas phase reaction. Therefore, the transformation of the hexa- and other higher brominated PBBs in the atmosphere due to reaction with OH radicals are probably not important.

Hexa- and other higher brominated biphenyls are expected to be present in the particle-adsorbed state in the atmosphere. These PBBs photolyze in solution and in soil (Hill et al. 1982; Ruzo and Zabik 1975; Trotter 1977). Since PBBs present in surface soil are known to photolyze, particle-sorbed PBBs present in the atmosphere may also undergo photolysis. The importance of the photochemical reaction under sunlight illumination conditions for the degradation/transformation of PBBs in air cannot be evaluated due the lack of information.

#### 6.3.2.2 Water

The photolytic degradation of PBBs in solution has been the subject of several studies. Available data in the literature indicate that brominated biphenyls photodegrade by reduction in solvents capable of proton transfer with the formation of lower brominated biphenyls. For example, the irradiation of FireMaster BP-6 and 2,2’,4,4’,5,5’-hexabromobiphenyl in methanol at wavelengths >286 nm produced mainly penta- and tetrabromobiphenyl (Ruzo and Zabik 1975). FireMaster BP-6 photolyzed 7 times faster than its chlorinated counterpart, 2,2’,4,4’,5,5’-hexachlorobiphenyl (Ruzo and Zabik 1975). Although an earlier study tentatively identified dimethoxy tetrabromobiphenyl as a photolysis product of FireMaster BP-6 (Ruzo and Zabik 1975), later work did not detect this compound (Ruzo et al. 1976). Earlier studies indicated that the debromination usually occurs with the stepwise preferential loss of bromine from the ortho and para positions of the biphenyl ring (i.e., 2, 2’, 6, and 6’ positions) (De Kok et al. 1977; Ruzo and Zabik 1975; Ruzo et al. 1976; Trotter 1977). Thus, the photolysis of 2,2’,4,4’,5,5’-hexachloro-biphenyl, the major component of FireMaster BP-6, would be expected to produce 2,3’,4,4’,5-penta-bromobiphenyl and subsequently 3,3’,4,4’-tetrabromobiphenyl. Although photolysis mainly produces debromination products, unlike in the case of an individual PBB congener, it has been indicated that reductive debromination of ortho substituents is not the predominant photolytic degradation pathway for FireMaster BP-6 (Robertson et al. 1983b).

The study of photolysis of PBBs in the aqueous phase is more relevant to natural environmental situations than photolysis in proton-donating organic solvents. It was suggested that the photolysis of PBBs in aqueous solution would proceed by oxidative process of photohydroxylation, leading to the formation of phenolic compounds (Norris et al. 1973). However, photolysis of 2,4-dibromo- and 2,3’,4’,5-tetrabromo-biphenyl in acetonitrile-water solution showed that debromination was the major reaction (Ruzo et al. 1976). No evidence of the formation of hydroxylated species (phenolic products) was found (Ruzo et al. 1976).

PBBs are not expected to undergo abiotic hydrolysis under environmental conditions due to the lack of hydrolysable functional groups (Boethling and Mackay 2000).

Several investigators assessed the biodegradation potential of PBBs under aerobic conditions, with activated sludge or pure cultures of microorganisms as microbial inoculum, and concluded that although the lower substituted biphenyls might biodegrade in aerobic water and sediment (Kong and Sayler 1983; Sugiura 1992; Yagi and Sudo 1980), the higher substituted biphenyls are resistant to aerobic biodegradation (Kawasaki 1980; Sasaki 1978; Shelton and Tiedje 1981). This is consistent with biodegradation studies in soil (see Section 6.3.2.3). It has been proposed that complete mineralization of 4-bromobiphenyl to carbon dioxide occurs via a 4-bromobenzoate intermediate by mixed bacterial cultures obtained from PBB-contaminated river sediment (Kong and Sayler 1983). However, complete mineralization was not observed for 2- and 3-bromobenzoate (Kong and Sayler 1984).

Although higher brominated biphenyls do not biodegrade in water or sediment under aerobic conditions, it has been shown that anaerobic microorganisms in river sediments obtained from populated areas can biodegrade higher substituted PBBs, including FireMaster mixtures (Morris et al. 1992). The biodegradation involved debromination at the meta and para positions, and no ortho bromine removal was observed (Morris et al. 1992). However, the possibility of ortho bromine removal from higher brominated biphenyls with certain inoculations (e.g., microorganisms from polluted river sediment repeatedly transferred on a pyruvate medium amended with Aroclor 1242) has been suggested (Morris et al. 1992).

#### 6.3.2.3 Sediment and Soil

Information on the fate of PBBs in soil is limited. A pure culture of microorganism isolated from soil biodegraded 2-bromobiphenyl via the 2-bromobenzoic acid pathway (Takase et al. 1986). There is little evidence that the higher brominated biphenyls biodegrade in soil under aerobic conditions during an incubation period of ≤1 year (Griffin and Chou 1981a, 1981b; Jacobs et al. 1976). Some degradation of an undefined congener of pentabromobiphenyl was observed when incubated in soil, but this degradation could not be definitely attributed to biodegradation (Jacobs et al. 1976). As discussed in Section 6.3.2.2, higher brominated PBBs may biodegrade in an anaerobic region of river sediment and possibly soil polluted with PCBs and PBBs to form lower brominated products. Biodegradation of the photolysis products of hexa- and heptabromobiphenyl in soil (which produces lower brominated products) was only minor (≈3% in 1 year) since the photodegradation products were bound to soil and light does not penetrate far into soil (Jacobs et al. 1978)

Degradation of PBBs present in a contaminated soil from a manufacturing site in Michigan was significant (Hill et al. 1982). For example, 2,2’,4,4’,5,5’-hexabromobiphenyl, the principal component of FireMaster (54–68% in FireMaster) was reduced to 26% of the total PBBs when exposed to a field soil for several years. In two other soils, in which the original concentrations of PBBs were much lower, the rate of degradation was much lower. Principal degradation products were 2,3’,4,4’,5-pentabromobiphenyl, 2,2’,4,4’,5-pentabromobiphenyl, and two unidentified tetrabromobiphenyls. The degradation was attributed to photochemical reactions. On the other hand, no significant photodegradation of FireMaster was observed after 1 year in contaminated manure spread in field soil from Michigan (Jacobs et al. 1978). The authors provided no explanation for the difference in photoreactivity of PBBs in soils with and without manure. It is important to point out that, due to attenuation and scattering of light, sunlight will not penetrate most soil beyond the surface layer. Therefore, it can be concluded from these studies that although photolysis may be the only viable degradative process for PBBs in soil, photolysis will be limited to the surface layer of soil, and the rate of photolysis will be very slow. PBBs incorporated into thermoplastics which were eventually buried at waste sites are not likely to absorb much light and undergo photolytic degradation.

Analysis (Morris et al. 1993) of sediments from a PBB-contaminated river in Michigan (Pine River) indicates that little degradation of PBBs has occurred since the 1970s. Although microorganisms capable of debrominating PBBs were not present in regions of highest contamination, they were found in sediments downstream from the area of highest contamination. The investigators (Morris et al. 1993) suggest that high levels of contaminants including PBBs may be inhibiting the microbial degradation of PBBs in this river.

#### 6.3.2.4 Other Media

No other information was found in the literature about the transformation and degradation processes for PBBs in other media.

## 6.4 LEVELS MONITORED OR ESTIMATED IN THE ENVIRONMENT

Evaluation of the potential for human exposure to PBBs depends in part on the reliability of supporting analytical data from environmental samples and biological specimens. Comparisons among various studies are complicated by the fact that authors may report PBB concentrations as technical mixtures, as homologs, or as congeners. Chemical analysis procedures are discussed in greater detail in Chapter 7. Recent monitoring data for PBBs are very limited. Historical monitoring data indicate that environmental PBB concentrations are confined to areas near former manufacturing facilities and regions of Michigan effected by the farm catastrophe of the early 1970’s (see Section 6.1).

### 6.4.1 Air

Historically, PBBs were released to the atmosphere during three stages of the manufacturing process, and an estimate of the maximum amount of PBBs expected to be lost to the air during the manufacture of PBBs in the United States is available (see Section 6.2.1) (Neufeld et al. 1977). Monitoring data on the ambient air levels of PBBs are very limited. The concentration of hexabromobiphenyl in air samples collected downwind and crosswind from the White Chemical Company plant in Bayonne, New Jersey was 0.06 ng/m^3^ (DeCarlo 1979).

### 6.4.2 Water

Recent information on the concentrations of PBBs is not available. The concentrations of PBBs in effluents discharged from the Michigan Chemical Corporation plant in St. Louis, Michigan, to the Pine River during 1974–1977 ranged from <0.01 to 150 μg/L (Hesse and Powers 1978). The concentrations of PBBs in effluents from White Chemical Company, Bayonne, New Jersey, and Hexcel Chemical Corporation, Sayerville, New Jersey, ranged from <0.2 to 210 μg/L (DeCarlo 1979). The concentrations of PBBs in the Pine River ≤12 miles downstream from the Michigan Chemical Corporation plant in 1974 were 0.01–3.2 μg/L (Hesse and Powers 1978; Neufeld et al. 1977). 2,2’,5,5’-Tetrabromobiphenyl and 3,3’,5,5’-tetrabromobiphenyl were qualitatively detected in water from Lake Ontario, and hexabromobiphenyl (unspecified congeners) was qualitatively detected in water from Lakes Ontario and Huron (Great Lakes Water Quality Board 1983). The concentrations of PBBs in test wells within a PBB landfill site in Michigan ranged from 0.4 to 26.0 μg/L, although the concentrations of PBBs in test wells outside the landfill ranged from <0.1 to 4.4 μg/L (Shah 1978). No other information was located about the concentrations of PBBs in water.

### 6.4.3 Sediment and Soil

Soil samples from the bagging and loading areas of the Michigan Chemical Corporation plant in St. Louis, Michigan, contained PBBs at concentrations of 3,500 and 2,500 mg/kg, respectively (Di Carlo et al. 1978). PBBs (mostly decabromobiphenyl, but some lower brominated biphenyls down to hexabromobiphenyl) in soil near the Hexcel Chemical Corporation plant in New Jersey and the White Chemical Company plant in New Jersey ranged from 40 to 4.6 mg/kg and from 1.14 to 4.25 mg/kg, respectively (DeCarlo 1979). PBB levels in surface soil samples from seven dairy farms in Michigan that spread contaminated manure on the fields ranged from 35 to 1,260 μg/kg, while the concentrations in surface soil of control farms (that did not use contaminated manure) were <25 μg/kg (Fries and Jacobs 1980).

Concentrations of PBBs in sediments upstream from the Michigan Chemical Corporation plant were below the detection limit (100 μg/kg) with the exception of one sample (Hesse and Powers 1978). The concentration of PBBs in sediment from one upstream sample was 350 μg/kg. Hesse and Powers (1978) explained that this higher value was due to contamination by upstream currents during periods of water-level regulation at the St. Louis dam. The concentrations of PBBs in near shore sediment near the Michigan Chemical Corporation plant sewer outfall were ≤77.0 mg/kg. PBB concentrations in Pine River sediments downstream from the plant showed a gradual decrease from a maximum value of 9.2 mg/kg to a value of 0.1 mg/kg at a location 29 miles downstream from the plant outfall (Hesse and Powers 1978). Similarly, PBB concentrations in sediment samples from swamps and marshes adjacent to the White Chemical Company and Hexcel Chemical Corporation plants in New Jersey ranged from <10 μg/kg to 4.6 mg/kg (DeCarlo 1979). A sludge sample from the discharge treatment plant of the White Chemical Company contained 431 mg/kg of PBBs (DeCarlo 1979).

### 6.4.4 Other Environmental Media

Food. Although the agriculture episode in Michigan involving contaminated feed occurred in May 1973, PBBs were not identified as the causative factor until April 1974 (Fries 1985b). PBB-containing meats, milk, butter, eggs, and cheese entered the human food chain for almost a year before the PBBs were identified. Concentrations of PBBs (on a fat basis) in milk samples collected from contaminated farms soon after PBB was identified ranged from 2.8 to 595 mg/kg (Cordle et al. 1978; Kay 1977). Concentrations of PBBs in other products processed from the contaminated milk were as follows: butter, 1–2 mg/kg; cheese, 1.4–15.0 mg/kg; and canned milk, 1.2–1.6 mg/kg (Cordle et al. 1978). In 1974, the levels of PBBs in eggs from contaminated farm premises were as high as 59.7 mg/kg (Kay 1977). The levels of PBBs in poultry and cattle tissues from the contaminated farm collected in 1974 were 4,600 mg/kg and up to 2,700 mg/kg, respectively (Kay 1977). With the seizure and destruction of the contaminated farm animals and products, the levels of PBBs in consumer products showed a steady decline. For example, in 1975, among 18 milk samples, 13 cheese samples, and 14 butter samples taken in Michigan, only 3 butter samples exceeded the FDA guidelines of 0.3 mg/kg fat (Di Carlo et al. 1978). In 1975, PBBs were detected in 245/2,040 meat samples collected in Michigan, with only 24 samples containing levels >0.3 mg/kg fat (Di Carlo et al. 1978). Although 95% of 1,430 meat samples collected in Michigan in 1976 contained detectable PBBs, only 1 sample contained >0.6 mg/kg, and a market basket survey in Michigan showed detectable PBBs in only 1/102 meat samples (Di Carlo et al. 1978).

Fish. No PBBs were detected in several varieties of fish (carp, white sucker, Northern pike, bullhead, and bass) from the Alma Reservoir, which is upstream from the Michigan Chemical Corporation plant and above a dam that prevents fish from moving upstream (Hesse and Powers 1978). On the other hand, tissue samples from fish collected from the Pine River, ≤29 miles downstream from the plant, contained up to 1.33 mg PBBs/kg (wet weight in skinless fillets). There was no apparent change in PBB concentrations in fish between 1974 and 1976 (Hesse and Powers 1978). PBBs could be detected in fish from Pine River and other embayments and tributaries of Lake Huron in 1983. PBB concentrations in carp and other sedentary fish from embayments and tributaries of Lake Huron (including Pine River) and Lake Superior were determined (Great Lakes Water Quality Board 1989; Jaffe et al. 1985). PBBs were detected in the concentration range of 15–15,000 μg/kg (fat basis) in fish from embayments and tributaries of Lake Huron, but not from Lake Superior. Luross et al. (2002) determined the concentrations of several PBB congeners in lake trout from Lakes Huron, Superior, Erie, and Ontario. 2,2’,4,4’,5,5’-Hexabromobiphenyl (BB-153) and 2,2’,4,5,5’-pentabromobiphenyl (BB-101) were found at the highest levels at concentrations ranging from 189 to 2,083 pg/g wet weight and from 42 to 633 pg/g wet weight, respectively. Several other congeners were also detected in these lake trout samples (see Table 6-1).

In German rivers, elevated levels of nona- and octaBBs were present in fish. HexaBB was predominant in fish from the North Sea and Baltic Sea. 3,3’,4,4’,5,5’-Hexabromobiphenyl (BB-169) was found at a maximum concentration of 36 mg/kg (μg/g) fat in samples from the Baltic Sea. However, BB-169 was not found in waters from the North Sea or rivers. In Baltic marine fish, the concentrations of 2,2’,4,4’,5,5’-hexabromobiphenyl (BB-153) ranged from 0.2 to 4.2 mg/kg (μg/g) lipid (de Boer et al. 2000a).

Animals. PBB concentrations in whole (with skin) and skinless ducks collected within 2 miles of the Michigan Chemical Corporation plant in 1974–1977 ranged from not detected to 2.70 mg/kg (μg/g) and not detected to 1.8 mg/kg (μg/g), respectively (Hesse and Powers 1978). Three bottlenose dolphins (Tursiops truncatus) collected during 1987–1988 from the U.S. mid-Atlantic contained PBBs at concentrations of 14–20 μg/kg (ng/g) lipid basis (Kuehl et al. 1991). The source of the PBBs in the dolphins was not given. The median concentrations of PBBs in 10 specimens of carcass and brain of bald eagles (Haliaeetus leucocephalus) collected from 29 states in 1977 were 0.07 and 0.05 mg/kg (μg/g), respectively (Kaiser et al. 1980). Twenty-two other specimens did not contain detectable levels (<0.03 mg/kg [μg/g]) of PBBs. The concentrations of PBBs in eggs of fish-eating birds (common tern, little gull, herring gull, and red-breasted mergansers) collected during 1975–1980 from nesting islands in northwestern Lake Michigan and Green Bay contained PBBs in the concentration range of 0.02–0.25 mg/kg (μg/g) wet weight (Heinz et al. 1983, 1985).

Table 6-1 Mean Concentrations of Nine PBB Congeners in Lake Trout from the Great Lakes (pg/g Wet Weight)

Congener | Lake Superior | Lake Huron | Lake Erie | Lake Ontario
BB-26/29 | <1.3 | 5.2±2.3 | <1.3 | <1.3
BB-31 | <1.8 | 5.2±1.8 | <1.8 | <1.8
BB-49 | 6.8±1.7 | 125±43 | 20±7.6 | 14±4.9
BB-52 | 8.4±3.6 | 191±77 | 24±9.5 | 11±4.5
BB-80 | <3.8 | <3.8 | <3.8 | <3.8
BB-101 | 42±18 | 633±359 | 71±20 | 109±50
BB-103 | <1.5 | 4.4±1.9 | <1.5 | <1.5
BB-153 | 189±105 | 2,083±1,282 | 220±47 | 1,008±513
BB-155 | 1.0±0.78 | 5.8±3.4 | <0.98 | 1.1±0.43

Source: Luross et al. 2002

White-tailed sea eagles collected from the Baltic Sea contained 280 ng PBBs/g lipid weight (Jansson et al. 1987). The concentration of PBBs in common guillemots (Uria aalge) collected in 1979–1981 from the Baltic Sea was 160 ng/g lipid (Jansson and Asplund 1987). Brunnich’s guillemot (Uria lomvia), collected from Svalbard in the Arctic, contained 50 ng PBBs/g lipid (Jansson et al. 1987).

In 1981, female ringed seals from Svalbard in the Swedish Arctic contained 4 ng PBBs/g lipid (Jansson et al. 1987). The level of PBBs in Baltic Sea harbor seal (Phoca vitulina) was 20 ng/g lipid; North Sea harbor seal contained 3 ng PBBs/g lipid (Jansson et al. 1987). The concentration of hexaBB ranged from 13–61 μg/kg (ng/g) wet weight from harbor seals collected from the North Sea (decaBB <1 μg/kg [ng/g] wet weight). In whitebeaked dolphins from the North Sea, the concentration of hexa-, penta-, and deca-BBs were 13, 8.3, and <0.9 μg/kg (ng/g) wet weight, respectively. Tetra-, penta-, and deca-BBs concentration ranges were 1.1–1.9, 0.4–0.9, and <0.5 μg/kg (ng/g) wet weight, respectively, in sperm whales from the Atlantic Ocean (de Boer et al. 1998c).

Human Tissues and Body Fluids. The quantitative determination of the concentrations of PBBs in blood, serum, adipose tissue, milk, and other body tissues or fluids is important in determining the human body burden of these chemicals. Fat is the largest repository of PBBs in the body, and concentrations in fat can provide an index of body burdens and exposure. It is simpler and less invasive to collect samples of serum or breast milk than body fat. However, the collection of milk and serum for the estimation of possible body burden has limitations. Breast milk can be obtained from limited segments of the population. Also the concentration of PBBs in breast milk can show considerable fluctuations because the breast is emptied only periodically (Brilliant et al. 1978; Willett et al. 1988). Serum, however, has lower PBB concentrations than body fat (see Section 3.5.1).

Hexabromobiphenyl was detected (detection limit 6.6 μg/kg [ng/g]) at a frequency of 8–57% in human adipose tissue samples from six Canadian Great Lakes municipalities in 1984 (Williams et al. 1988). The concentration of 2,2’,4,4’,5,5’-hexabromobiphenyl in adipose tissue samples pooled from tissues of the general population of the conterminous Unites States ranged from 1 to 2 μg/kg (ng/g) (Lewis and Sovocool 1982). PBB levels in the adipose tissues of 15 quarantined dairy farm residents in mid-Michigan (where the mix-up involving FireMaster BP-6 occurred) ranged from 0.104 to 174 mg/kg (μg/g) (Humphrey and Hayner 1975).

In the fall of 1993, the serum levels of BB-167 (2,2’,4,4’,5,5’-hexabromobiphenyl) in 32 subjects, approximately 10 of whom consumed sport fish from the Great Lakes, were measured (Anderson et al. 1998). When the data were stratified by lake, on average, the Lake Huron fish consumers had the highest levels of PBBs (0.6 ppb [ng/g]) and Lake Erie fish consumers had the lowest (0.2 ppb [ng/g]). When the data were then stratified by state of residence, on average, Great Lakes sport fish consumers who live in Michigan had the highest PBB level (0.7 ppb [ng/g]) and residents of Wisconsin had the lowest level (0.05 ppb [ng/g]).

In Michigan after the agriculture contamination episode in 1973–1974, the median PBB concentrations in blood of exposed adults and children in farms were 0.014 and 0.035 mg/kg (14 and 35 ppb [ng/g]), respectively, compared to corresponding median concentrations of 0.003 and 0.006 mg/kg (3 and 6 ppb [ng/g]) in a control group (Humphrey and Hayner 1975). PBB levels in the blood of quarantined farm workers in Michigan were also higher than in nonquarantined farm residents and the general population of Michigan (Cordle et al. 1978; Kimbrough 1987; Lambert et al. 1990; Landrigan et al. 1979). The concentration ratio of PBBs in adipose tissue over blood plasma for 13 paired specimens was 175 to 1 (Humphrey and Hayner 1975).

A cross-section of the population of Michigan was studied in 1978, 5 years following the agriculture episode involving FireMaster BP-6, to determine the levels of PBBs in human tissues. Levels of PBBs were highest in the part of state in which the episode occurred (median: adipose tissue, 500 μg/kg (ng/g); serum, 1.7 μg/L) and were lowest in the upper peninsula (median: adipose tissue, 15 μg/kg (ng/g); serum, 0.2 μg/L), farthest from the source of contamination. Levels in the rest of the state were in between (median: adipose tissue, 240 μg/kg [ng/g]; serum, 0.9 μg/L) (Wolff et al. 1982). The estimated concentration ratio of PBBs in adipose tissue over serum was near 300 among 31 Michigan dairy farm residents (Wolff et al. 1979a). The ratio of adipose tissue to serum PBB concentration was 363 to 1 for the general population and 100 to 1 in lactating women (Brilliant et al. 1978). The kinetics of fat metabolism in lactating women seems to alter PBB partitioning. The ratios of adipose tissue to serum PBB concentration for nonpregnant females and male chemical workers, farm workers and other males, and pregnant females in 3,683 Michigan residents with varying degrees of exposure were 190–260 to 1, 325–329 to 1, and 107–119 to 1, respectively (Eyster et al. 1983). The PBB ratios for cord to serum and placenta to serum in pregnant females were 0.10–0.14 to 1 and 0.10–0.17 to 1, respectively (Eyster et al. 1983). The PBB ratios for feces to serum and bile to serum in farm and chemical workers were 0.53–0.71 to 1 and 0.45–0.63 to 1, respectively (Eyster et al. 1983). The detection of PBBs in bile and feces indicates transfer into the intestinal tract. However, the concentration of PBBs in feces represented a minor proportion of the total body burden, indicating a slow rate of excretion (Eyster et al. 1983). Serum PBBs were determined in a nested case-control study of 1,925 women enrolled in the Michigan Department of Public Health registry for persons exposed to PBBs (Henderson et al. 1995). Study participants had lived on or received food from a farm quarantined by the Michigan Department of Agriculture, were recruited from July 1976 to December 1977, and were followed up annually from 1978 through 1993. Median serum PBB concentrations were 2 ppb (n=290; range=0.5–419 ppb [μg/L]).

The concentrations of PBBs in the breast milk of females from the lower peninsula of Michigan (exposed area) were generally higher than in breast milk of females from the upper peninsula (farthest from the sources) (Brilliant et al. 1978). PBB levels in breast milk of five females from the exposed farms were 0.21–92.7 mg/kg (Cordle et al. 1978; Humphrey and Hayner 1976). In a cohort of Michigan residents, the ratio of PBBs in breast milk to maternal serum was 107–122 to 1 and in adipose tissue to breast milk was 1.1–1.5 to 1 (Eyster et al. 1983; Landrigan et al. 1979). The concentrations of PBBs found in human tissues and body fluids are given in Table 6-2. Recent levels of PBBs in human breast milk (i.e., 1990 to present) were not located (WHO 1994b).

Cow’s Milk. In an attempt to determine the metabolites of PBBs, whole milk of lactating cows from contaminated areas of Michigan was analyzed for monohydroxy metabolites, but none were found (Gardner et al. 1976). In a later study, the feces of dogs fed FireMaster BP-6 in corn oil was found to contain a metabolite identified as 6-hydroxy-2,2’,4,4’,5,5’-hexabromobiphenyl (Gardner et al. 1979).

The effects of processing cow’s milk containing PBBs also has been studied (Murata et al. 1977; Zabik et al. 1978). Spray-drying reduced PBB levels in whole and skim milk, whereas pasteurization, freeze-drying, aging of cheese, and condensation were not effective in reducing the level of PBBs in milk products. Pressure-cooking meat containing PBBs reduced the level of PBBs in the cooked meat (Zabik et al. 1978).

## 6.5 GENERAL POPULATION AND OCCUPATIONAL EXPOSURE

PBBs are no longer produced or used in the United States. Thus, the general population exposure to PBBs will only be from historical releases. For people residing in the lower peninsula of Michigan, especially in the immediate vicinity of the PBB contaminated areas of this region, exposure to PBBs may still be occurring today. However, environmental levels have decreased since the 1970s and current exposure, if any, will be at low levels. For other regions of the United States, the levels of exposure will either be very low or none.

Table 6-2 Tissue Levels of PBBs in Michigan Residents

Tissue | Subject(s) | Mean/median concentration^a^ | Year | Reference
Serum | Exposed farm workers | 14 μg/L | 1976 | Stross et al. 1979
Serum | Chemical workers | 48 μg/L | No data | Stross et al. 1981
Serum | Chemical workers | 1.1–1,000 μg/L | 1976 | Anderson et al. 1978d
Serum | Exposed farm workers | BDL to 1,000 μg/L | 1976 | Anderson et al. 1978d
Serum | Residents from quarantined farms | 26.9 μg/L | 1976–1977 | Landrigan et al. 1979
Serum | Residents from non-quarantined farms | 3.5 μg/L | 1976–1977 | Landrigan et al. 1979
Serum | Farm product consumers | 17.1 μg/L | 1976–1977 | Landrigan et al. 1979
Serum | Chemical workers and families | 43.0 μg/L | 1976–1977 | Landrigan et al. 1979
Serum | Control group | 3.5 μg/L | 1976–1977 | Landrigan et al. 1979
Serum | General population (lower peninsula) | 1.9 μg/L | 1978 | Wolff et al. 1982
Serum | General population (upper peninsula) | 0.2 μg/L | 1978 | Wolff et al. 1982
Serum | General population (remainder of state) | 0.9 μg/L | 1978 | Wolff et al. 1982
Serum | Chemical workers | 25.4 μg/L | No data | Eyster et al. 1983
Serum | Farm and other workers | 5.4 μg/L | No data | Eyster et al. 1983
Serum | Mothers from lower peninsula | 26.2 μg/L | 1976–1977 | Landrigan et al. 1979
Serum | Exposed mothers from farms | 3.4 μg/L | No data | Eyster et al. 1983
Serum | Non-pregnant women from exposed farms | 3.1 μg/L | No data | Eyster et al. 1983
Serum | Exposed women enrolled in the Michigan Department of Public Health registry | 2 μg/L | 1993 | Henderson et al. 1995
Cord serum | Exposed mothers from lower peninsula | 3.2 μg/L | 1976–1977 | Landrigan et al. 1979
Cord serum | Mothers from lower peninsula | <1.0 μg/L | No data | Eyster et al. 1983
Blood plasma | Workers from quarantined farms | 14 μg/L | 1974 | Humphrey and Hayner 1975
Blood plasma | Children from quarantined farms | 35 μg/L | 1974 | Humphrey and Hayner 1975
Blood plasma | Adults from non-quarantined farms | 3 μg/L | 1974 | Humphrey and Hayner 1975
Blood plasma | Children from non-quarantined farms | 6 μg/L | 1974 | Humphrey and Hayner 1975
Placenta | Exposed mothers | <1 μg/L | No data | Eyster et al. 1983
Breast milk | Exposed mothers | 370 μg/kg (fat basis) | No data | Eyster et al. 1983
Breast milk | Exposed mothers from lower peninsula | 3,614 μg/kg (fat basis) | 1976–1977 | Landrigan et al. 1979
Breast milk | Mothers from lower peninsula | 68 μg/kg (fat basis) | 1976 | Brilliant et al. 1978
Breast milk | Mothers from upper peninsula | <44 μg/kg (fat basis) | 1976 | Brilliant et al. 1978
Adipose tissue | Population of lower peninsula | 500 μg/kg | 1978 | Wolff et al. 1982
Adipose tissue | Population of upper peninsula | 15 μg/kg | 1978 | Wolff et al. 1982
Adipose tissue | Population of rest of the state | 240 μg/kg | 1978 | Wolff et al. 1982
Adipose tissue | Chemical workers | 9,330 μg/kg | No data | Brown et al. 1981
Adipose tissue | Farm residents from lower peninsula | 3,940 μg/kg | No data | Brown et al. 1981
Adipose tissue | Farm residents from lower peninsula | 3,260 μg/kg | 1976 | Stross et al. 1979
Adipose tissue | Chemical workers | 12,820 μg/kg | No data | Stross et al. 1981
Adipose tissue | Workers from quarantined dairy farms | 12,500 μg/kg | 1974 | Humphrey and Hayner 1975
Adipose tissue | Pregnant females from lower peninsula | 400 μg/kg | No data | Eyster et al. 1983
Adipose tissue | Chemical workers | 5,290 μg/kg | No data | Eyster et al. 1983
Adipose tissue | Farm and other workers from lower peninsula | 1,650 μg/kg | No data | Eyster et al. 1983

a When both mean and median values are available, the former values have been used in the table. In some cases, when neither value is available, the range is given in the table.

BDL = below detection limit

In the past, the general population may have been exposed to PBBs by inhaling contaminated air, ingesting contaminated water and food, and using consumer products containing PBBs. Other than in air in the vicinity of PBB production plants (see Section 6.1), no current or historical data exist that would indicate that PBBs might be present in ambient air. There are no current or historical data on the direct exposure of humans to PBBs from water. The general population may have been exposed to low levels of PBBs from the consumption of contaminated foods, but no estimate is available that quantitated this exposure. Historical monitoring and body burden data indicate that low level exposures to PBBs were limited to the population within the state of Michigan (see Section 6.4 and Table 6-2). The level of exposure to PBBs was slightly higher for the people residing in the lower peninsula of Michigan and highest among people residing in the immediate vicinity of the contaminated dairy farms, where people consumed contaminated meat, eggs, and dairy products (see Section 6.4 and Table 6-2). Consumer exposure in the past (plastics containing PBBs may not be in circulation anymore since PBB production ceased in the 1970s) from using PBB-containing plastics (e.g., typewriters, calculators, projector housings, and movie equipment cases) is expected to be very low since the PBBs were incorporated into the plastic and their mobilization could only have occurred under conditions such as combustion (Di Carlo et al. 1978).

Workers involved in the historical production of PBBs, PBB-containing plastics, and PBB-containing plastic products could have been exposed to PBBs via inhalation of dust and vapor and/or dermal contact. Both workplace environmental monitoring and body burden monitoring data of workers (see Table 6-2) (Hesse and Powers 1978; Humphrey and Hayner 1975; Wolff et al. 1979b) indicated that workers in PBB industries were exposed to higher concentrations of PBBs than the general population. Although no evidence has been reported, workers in facilities that combusted or incinerated PBB-containing plastics might have been exposed to higher levels of PBBs.

## 6.6 EXPOSURES OF CHILDREN

This section focuses on exposures from conception to maturity at 18 years in humans. Differences from adults in susceptibility to hazardous substances are discussed in Section 3.7 Children’s Susceptibility.

Children are not small adults. A child’s exposure may differ from an adult’s exposure in many ways. Children drink more fluids, eat more food, breathe more air per kilogram of body weight, and have a larger skin surface in proportion to their body volume. A child’s diet often differs from that of adults. The developing human’s source of nutrition changes with age: from placental nourishment to breast milk or formula to the diet of older children who eat more of certain types of foods than adults. A child’s behavior and lifestyle also influence exposure. Children crawl on the floor, put things in their mouths, sometimes eat inappropriate things (such as dirt or paint chips), and spend more time outdoors. Children also are closer to the ground, and they do not use the judgment of adults to avoid hazards (NRC 1993).

Infants who consume breast milk may have had a higher exposure to PBBs than children who drink formula milk, especially children exposed during the Michigan episode (see Section 6.4.4). No additional information was found in the literature about the exposure of children to PBBs (WHO 1994b).

## 6.7 POPULATIONS WITH POTENTIALLY HIGH EXPOSURES

The production of PBBs ceased in 1979, and the usable life of the plastics containing PBBs has expired. Therefore, these plastics are probably no longer in circulation. At the present time and in the near future, populations potentially exposed to low levels of PBBs are those living near hazardous waste sites in which the PBB-containing plastics have been disposed and the residents in and around the contaminated farms in Michigan. The lifetime of PBBs in soil is on the order of years (Jacobs et al. 1978), and the levels of PBBs in fish caught in contaminated waters have declined slowly (Hesse and Powers 1978). Therefore, concentrations of residual PBBs in soil and streams in the vicinity of PBB-containing hazardous waste sites, PBB production facilities, and contaminated farm areas are expected to remain above background levels for many years. The sources of potential exposure to PBBs for residents in these areas are consumption of contaminated meat and dairy products obtained from herds grazing over contaminated soil and consumption of fish from nearby contaminated streams. PBB contamination has triggered the issuance of one human health advisory in the state of Michigan. As of September 30, 1993, recreational and subsistence fishermen who consume appreciably higher amounts of fish caught in the Pine River downstream from St. Louis in Gratiot and Midland Counties (RTI 1993) may be exposed to above-average levels of PBBs associated with dietary intake. The body burden for PBBs in residents of contaminated areas has been higher than in the general population (Brilliant et al. 1978; Cordle et al. 1978; Eyster et al. 1983; Humphrey and Hayner 1975; Kimbrough 1987; Lambert et al. 1990; Landrigan et al. 1979; Wolff et al. 1982). Therefore, babies breastfed by exposed mothers in the contaminated areas may also be at higher risk (Jacobson et al. 1989).

## 6.8 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of PBBsis available. Where adequate information is not available, ATSDR, in conjunction with NTP, is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of PBBs.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 6.8.1 Identification of Data Needs

Physical and Chemical Properties. Many of the relevant physical and chemical properties of the PBBs are not available (see Table 4-3). More data on the physical and chemical properties of hexabromobiphenyl are available relative to octabromo- and decabromobiphenyl. Even in the case of hexabromobiphenyl, not all relevant data are available, and the quality of data is questionable because the properties of FireMaster BP-6 have been reported as the properties of hexabromobiphenyls. More importantly, very limited data are available on the physical and chemical properties for the individual congeners of hexabromo-, octabromo-, and decabromobiphenyl. The absence of such important data as K_oc_, vapor pressure, and Henry’s law constant, is a major impediment in the prediction of the environmental fate and transport of PBBs.

Production, Import/Export, Use, Release, and Disposal. The production of all PBBs in the United States stopped in 1979 (IARC 1986). Data on the past production, import/export, and use of PBBs are available (Neufeld et al. 1977). In the past, PBB-containing plastic was used in consumer products, but the useful life of these products may have ended (Di Carlo et al. 1978; Neufeld et al. 1977), and these products are probably no longer in circulation. In the workplace, the environmental media contaminated by PBBs were air, water, and soil (DeCarlo 1979). Outside of the workplace, soil is expected to be the medium with significant contamination due to disposal of solid waste from production plants and disposal of PBB-containing plastics in landfills (Neufeld et al. 1977). Although it is known that PBB-containing plastics may have been disposed in landfills (Di Carlo et al. 1978), the amount that may have been incinerated is not known. No data were located from studies that determined the efficiency of incineration as a method of disposal of PBBs present in the neat form in industrial wastes or in plastics. Environmental regulations regarding the manufacture and disposal of PBBs have been established (EPA 1988a). According to the Emergency Planning and Community Right-to-Know Act of 1986, 42 U.S.C. Section 11023, industries are required to submit chemical release and off-site transfer information to the EPA. The Toxics Release Inventory (TRI), which contains this information for 1999, became available in 2002. This database will be updated yearly and should provide a list of industrial production facilities and emissions.

Environmental Fate. Information regarding the environmental fate of PBBs in air was not located in the literature. The data about the fate of PBBs in air are important for the prediction of transport characteristics of these compounds in air. Photolysis of the PBBs will produce debrominated products in proton-donating organic solvents (Ruzo and Zabik 1975; Ruzo et al. 1976), but there is less certainty about the importance of photolysis of PBBs in water (Norris et al. 1973; Ruzo et al. 1976). PBBs will partition from the aquatic phase to sediment and suspended solids in water (Hesse and Powers 1978). PBBs will bioconcentrate in aquatic organisms, but the BCF may decrease as the bromine substitution exceeds six (Gobas et al. 1989; Opperhuizen et al. 1985; Zitko 1979; Zitko and Hutzinger 1976). However, the difference in the reported BCF values for hexabromobiphenyl among different investigators is vast (Gobas et al. 1989; Hesse and Powers 1978; Opperhuizen et al. 1985; Veith et al. 1979). PBBs will remain strongly sorbed to soil (Filonow et al. 1976; Griffin and Chou 1981a, 1981b) and will persist in soil because of the lack of suitable degradation pathways (Jacobs et al. 1978). The translocation of PBBs from soil to upper parts in plants was not observed, and the transfer of PBBs from soil to carrot roots was found to be minor (Jacobs et al. 1976, 1978). de Boer et al. (1998c) found PBBs in deep ocean marine mammals, which suggests that PBBs may be transported globally. More monitoring data for PBBs in the environment are needed to verify the possible global transport of PBBs. Since the toxicity and the environmental fate of PBBs depends on specific PBBs congeners, development of more data regarding congener-specific fate and transport of PBBs in the environment are needed.

Bioavailability from Environmental Media. Available information regarding the rate of absorption of PBBs following inhalation, oral, or dermal contact is discussed in the Toxicokinetics Section (Section 3.4). Although no data on the bioavailability of PBBs from inhalation of contaminated air, or ingestion of or dermal contact with water, or inhalation of or dermal contact with soil are available, the bioavailabilities from these routes of exposure are expected to be far less than 100% because these compounds strongly sorb to particulate matter and soil. The estimated bioavailability of higher brominated biphenyls is expected to be even lower than the less brominated biphenyls due to stronger sorption characteristics of the former compounds. The estimated bioavailability of PBBs by farm animals from ingestion of contaminated soil was 56–65% (Fries 1985a). Also, studies on many persistent halogenated aromatic compounds clearly show that they become progessively less bioavailable with time (Alexander 2000). Often, three-fourths or more of the concentration of such compounds is not bioavailable. Information on the possibility of the very low bioavailability of PBBs is needed.

Food Chain Bioaccumulation. PBBs do not readily translocate from soil to plants via root uptake (Jacobs et al. 1976, 1978). Therefore, PBBs may not bioconcentrate in plants. However, plant uptake data are limited, and it will be helpful to develop additional plant uptake data. Brominated biphenyls with bromine substitution 6 or less will bioconcentrate in aquatic organisms (Gobas et al. 1989; Norris et al. 1973; Opperhuizen et al. 1985; Zitko 1979; Zitko and Hutzinger 1976). PBBs are preferentially stored in the adipose tissue of animals (Kimbrough 1987). Although PBBs have been detected in fish-eating birds and predatory animals from the consumption of contaminated food (Heinz et al. 1983, 1985; Hesse and Powers 1978), no systematic study was located that analyzed the biomagnification potential in predators resulting from consumption of contaminated food.

Exposure Levels in Environmental Media. Only limited data on the levels of PBBs in ambient air are available (DeCarlo 1979). Data are available on the levels of PBBs in effluent water from manufacturing plants, in river water, stream sediment, and soil in the vicinity of the plants, in sludge of a waste treatment plant, and in groundwater of a landfill site (Hesse and Powers 1978; Shah 1978). No data on the level of PBBs in drinking water from the contaminated sites were located. No estimate on the human intake of PBBs from any of the various environmental media was located in the literature.

Reliable monitoring data for the levels of PBBs in contaminated media at hazardous waste sites are needed so that the information obtained on levels of PBBs in the environment can be used in combination with the known body burden of PBBs to assess the potential risk of adverse health effects in populations living in the vicinity of hazardous waste sites.

Exposure Levels in Humans. Body burden data indicate that low-level exposures to PBBs have occurred for people in the state of Michigan. No recent information about average daily intake of PBBs was located. The levels of PBBs in human tissue and body fluids, such as blood, serum, adipose tissue, breast milk, feces, cord blood, biliary fluid, and placenta, of people in the state of Michigan have been extensively studied (Brilliant et al. 1978; Cordle et al. 1978; Eyster et al. 1983; Humphrey and Hayner 1975; Lambert et al. 1990; Landrigan et al. 1979; Wolff et al. 1982). However, no recent data are available. Data on the levels of PBBs in tissues and body fluids of residents in the vicinity of sites of industrial discharge of PBB wastes were not located. Updated information would be useful to understand current exposure levels of people in the state of Michigan to PBBs. This information is necessary for assessing the need to conduct health studies on these populations.

Exposures of Children. Children may be exposed to PBBs by a variety of exposure pathways. Levels will be highest for children living in the vicinity of the area affected by the Michigan contamination episode. The most important pathway appears to be consumption of contaminated mother’s milk (see Section 6.4.4). More data are needed on the levels of PBB exposure in nursing women from consumption of fish and from those of the general population. Exposure and body burden studies related to consumption of fish in the U.S. population are needed to determine exposure levels, particularly in children of recreational and subsistence fishers. Information related to the exposure of children living near hazardous waste sites is also needed. In particular, information is needed that is related to the potential for children to be exposed to PBBs bound to soil and dust particles through pica or unintentional hand-to-mouth activity within homes located in these areas. Quantitative information regarding the bioavailability and amount of PBBs that children are exposed to through contact with contaminated soils are unavailable. Therefore, any information concerning this subject would be useful in evaluating children’s exposure. Additional information on weight-adjusted intakes would be helpful for determining the health risks for young children. Infants and young children consume a greater amount of food per kilogram of body weight and, therefore, may have a proportionately greater exposure to PBBs than adults.

Child health data needs relating to susceptibility are discussed in Section 3.12.2 Identification of Data Needs: Children’s Susceptibility.

Exposure Registries. The Michigan Department of Community Health (MDCH), together with the Centers for Disease Control and Prevention (CDC) and three other federal agencies, began a major study to assess the health effects of PBBs after the Michigan contamination episode. A health questionnaire and blood samples were collected from people affected by the feed-contamination incident. MDCH had the responsibility to analyze several thousand samples for PBB from 1975 to 1978. MDCH continues contact with this cohort, updates health questionnaires, and collects blood samples to be analyzed (MDCH 2002).

### 6.8.2 Ongoing Studies

A search in Federal Research in Progress (FEDRIP 2002) did not identify ongoing research studies for PBBs.