# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Polybrominated Biphenyls (PBBs) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Polybrominated Biphenyls (PBBs)
CAS number(s): | 36355-01-8 (unspecified hexabromo mixture)
Date: | September 2, 2004
Profile status: | Final Post Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to figure: | 4
Species: | Rat

[underlined: Minimal Risk Level]: 0.01 [X] mg/kg/day [ ] ppm [ ] mg/m3

[underlined: Reference]: Allen-Rowlands CF, Castracane VD, Hamilton MG, . 1981. Effect of polybrominated biphenyls (PBB) on the pituitary - thyroid axis of the rat. Proc Soc Exp Biol Med 166:506–514.6261263

[underlined: Experimental design]: Groups of 8–11 male rats were treated with 0, 1, 3, or 6 mg/kg/day doses of an unspecified mixture of PBBs in lecithin liposomes by gavage for 10 days. Plasma T_4_ was assayed on treatment days 10 and 20. Other end points were evaluated on treatment day 20; these included plasma TSH levels, 5-hour thyroid uptake of ^131^I, incorporation of ^131^I into monoiodotyrosine, diiodotyrosine, T_3_ or T_4_, amount of intrathyroidal iodide, thyroid and liver weights, and body weights. Differences between mean values for the measured parameters in the control and PBB-treated groups were analyzed with the Student’s t-test, with a P value of 0.05 considered as statistically significant.

[underlined: Effects noted in study and corresponding doses]: Plasma (T_4_) was significantly (p<0.05) decreased at ≥3 mg/kg/day after 10 and 20 days; this reduction was both dose- and time-dependent. Plasma TSH levels were significantly elevated (p<0.01) at 6 mg/kg/day. The 6 mg/kg dose also produced a significant increase (p<0.01) in the 5-hour thyroid uptake of ^131^I and a significant depression (p<0.01) in the incorporation of ^131^I into monoiodotyrosine, without any apparent effect on the incorporation of ^131^I into diiodotyrosine, T_3_ or T_4_. There was a significant increase (p<0.01) of intrathyroidal iodide (nine rats/dose evaluated). At ≥3 mg/kg, the absolute thyroid weights were significantly increased (p<0.01) (not evaluated at 1 mg/kg). Relative liver weight was significantly increased at ≥1 mg/kg/day, but no treatment related effects on body weight were observed. The 1 mg/kg/day dose is considered a NOAEL.

Despite the fact that the inappropriate statistical test (t-test, rather than an ANOVA with multiple comparison tests) was used to analyze these data, ATSDR is confident with the designation of the NOAEL and LOAEL values. The data in the manuscript are presented graphically, with animal numbers presented as a range (8–11 animals/group); thus, an ANOVA could not be performed from the published report. However, using the graphical data, the change in plasma T4 levels in the 3 mg/kg/day groups is clearly on the order of 20–30%, which represents a biologically significant change. As such, the identification of 3 mg/kg/day as a LOAEL, and 1 mg/kg/day as a NOAEL, is not contraindicated by the lack of appropriate statistical analysis.

[underlined: Dose and end point used for MRL derivation]: 1 mg/kg/day; NOAEL for thyroid effects.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation]:

[X] 10 for extrapolation from animals to humans

[X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] NA (gavage study)

[underlined: Was a conversion used from intermittent to continuous exposure?] NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: NA

[underlined: Other additional studies or pertinent information that lend support to this MRL]: It is well documented in intermediate-duration studies that the thyroid is a target of PBBs showing a spectrum of effects, including decreases in serum T_3_ and T_4_ hormone, thyroid enlargement, effects in the follicular cells (e.g., reduced size, hyperplasia with columnar appearance, and papillary projections) and accumulation of colloid droplets (Akoso et al. 1982a, 1982b; Byrne et al. 1987; Gupta and Moore 1979; Kasza et al. 1978a; Norris et al. 1975a, 1975b, 1975c; NTP 1983; Sepkovic and Byrne 1984; Sleight et al. 1978).

[underlined: Agency Contact (Chemical Manager):] Dr. Hana Pohl