# 9 REFERENCES

*Cited in text

*Aarts JMMJG, Denison MS, Cox MA, . 1995. Species-specific antagonism of Ah receptor action by 2,2’,5,5’-tetrachloro- and 2,2’,3,3’4,4’-hexachlorobiphenyl. Eur J Pharmacol 293(4):463–474.8748700
*Abraham K, Hille A, Ende M, . 1994. Intake and fecal excretion of PCDDs, PCDFs, HCB, and PCBs (138, 153, 180) in a breast-fed and a formula-fed infant. Chemosphere 29(9–11):2279–2286.7850375
*Abrahamson LJ, Allen JR. 1973. The biological response of infant nonhuman primates to a polychlorinated biphenyl. Environ Health Perspect 4:81–86.4198473
*Abramowicz DA. 1990. Aerobic and anaerobic biodegradation of PCBs: A review. Crit Rev Biotechnol 10(3):241–251.
*Abramowicz DA. 1994. Aerobic PCB biodegradation and anaerobic PCB dechlorination in the environment. Res Microbiol 145(1):42–6.8090983
*Abramowicz DA. 1995. Aerobic and anaerobic PCB biodegradation in the environment. Environ Health Perspect Suppl 103(5):97–99.
*Abramowicz DA, Brennan MJ, Van Dort HM, . 1993. Factors influencing the rate of polychlorinated biphenyl dechlorination in Hudson River sediments. Environ Sci Technol 27:1125–1131.
ACGIH. 1994. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1994-1995. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
ACGIH. 1995. Threshold limit values for chemicals substances and physical agents and biological exposure indices for 1995-1996. American Conferences of Governmental Industrial Hygienists, Cincinnati, OH.
*ACGIH. 1998. 1998 TLVs and BEIs. Threshold limit values for chemical substances and physical agents. Biological exposure indices. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
*Achman DR, Brownawell BJ, Zhang L. 1996. Exchange of polychlorinated biphenyls between sediment and water in the Hudson River estuary. Estuaries 19(4):950–965.
*Acquavella JF, Hanis NM, Nicolich MJ, . 1986. Assessment of clinical, metabolic, dietary, and occupational correlations with serum polychlorinated biphenyl levels among employees at an electrical capacitor manufacturing plant. J Occup Med 28(11):1177–1180.3097280
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112. Endocrine section
*Adriaens P, Grbic-Galioc D. 1994. Cometabolic transformation of mono- and dichlorobiphenyls and chlorohydroxybiphenyls by methanotrophic groundwater isolates. Environ Sci Technol 28:1325–1330.22176326
*Afghan BK, Chau ASY. 1989. Analysis of trace organics in the aquatic environment. Boca Raton, FL: CRC Press, Inc., 33–68.
*Agrawal AK, Tilson HA, Bondy SC. 1981. 3,4,3’,4’-Tetrachlorobiphenyl given to mice prenatally produces long-term decreases in striatal dopamine and receptor binding sites in the caudate nucleus. Toxicol Lett 7:417–424.6787740
*Agrell C, Okla L, Larsson P, . 1999. Evidence of latitudinal fractionation of polychlorinated biphenyl congeners along the Baltic Sea region. Environ Sci Technol 33(8):1149–1156.
Ahlborg MG, Becking GC, Birnbaum LS, . 1994. Toxic equivalency factors for dioxin-like PCBs. Chemosphere 28(6):1049–1067.
Ahlborg UG, Lipworth L, Titus-Ernstoff L, . 1995. Organochlorine compounds in relation to breast cancer, endometrial cancer, and endometriosis: An assessment of the biological and epidemiological evidence. Crit Rev Toxicol 25(6):463–531.8611187
Albrecht WE. 1987. Central nervous system toxicity of some common environmental residues in the mouse. J Toxicol Environ Health 21:405–421.3599086
*Albro PW, Fishbein L. 1972. Intestinal absorption of polychlorinated biphenyls in rats. Bull Environ Contam Toxicol 8:26–31.4630020
Albro PW, Parker CE. 1979. Comparison of the compositions of Aroclor 1242 and Aroclor 1016. J Chromatogr 169:161–166.119790
*Albro PW, Corbett JT, Schroeder JL. 1981. Quantitative characterization of polychlorinated biphenyl mixtures (Aroclors 1248, 1254, and 1260) by gas chromatography using capillary columns. J Chromatogr 205:103–111.
*Alcock RE, Bacon J, Bardget RD, . 1996. Persistence and fate of polychlorinated biphenyls (PCBs) in sewage sludge-amended agricultural soils. Environ Pollut 93(1):83–92.15091372
*Alcock RE, McGrath SP, Jones KC. 1995. The influence of multiple sewage sludge amendments on the PCB content of an agricultural soil over time. Environ Toxicol Chem 14(4):553–560.
*Alcock RE, Sweetman AJ, Juan C-Y, . 1999. The intake and clearance of PCBs in humans - a generic model of lifetime exposure. Organohalogen Compounds 44:61–65.
*Alder AC, Haggblom MM, Oppenheimer SR, . 1993. Reductive dechlorination of polychlorinated biphenyls in anaerobic sediments. Environ Sci Technol 27:530–538.
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Alford-Stevens AL, Bellar TA, Eichelberger JW, . 1986. Accuracy and precision of determinations of chlorinated pesticides and polychlorinated biphenyls with automated interpretation of mass spectrometric data. Anal Chem 58:2022–2029.
Alford-Stevens AL, Budde WL, Bellar TA. 1985. Interlaboratory study on determination of polychlorinated biphenyls in environmentally contaminated sediments. Anal Chem 57:2452–2457.
*Allen JR. 1975. Response of the nonhuman primate to polychlorinated biphenyl exposure. Fed Proc 34:1675–1679.805720
*Allen JR, Abrahamson LJ. 1973. Morphological and biochemical changes in the liver of rats fed polychlorinated biphenyls. Arch Environ Contam Toxicol 1:265–280.4130176
*Allen JR, Barsotti DA. 1976. The effects of transplacental and mammary movement of PCBs on infant Rhesus monkeys. Toxicology 6:331–340.825993
*Allen JR, Norback DH. 1973. Polychlorinated biphenyl- and triphenyl-induced gastric mucosal hyperplasia in primates. Science 179:498–499.4196170
*Allen JR, Norback DH. 1976. Pathobiological responses of primates to polychlorinated biphenyl exposure. In: Proceedings of the National Conference on Polychlorinated Biphenyls, EPA 560/6-75-004, 43–49.
*Allen JR, Abrahamson LJ, Norback DH. 1973. Biological effects of polychlorinated biphenyls and triphenyls on the subhuman primate. Environ Res 6:344–354.4270482
*Allen JR, Barsotti DA, Carstens LA. 1980. Residual effects of polychlorinated biphenyls on adult nonhuman primates and their offspring. J Toxicol Environ Health 6:55–66.6770099
Allen JR, Barsotti DA, Lambrecht LK, . 1979. Reproductive effects of halogenated aromatic hydrocarbons on nonhuman primates. Ann NY Acad Sci 320:419–424.222194
*Allen JR, Carstens LA, Barsotti DA. 1974a. Residual effects of short-term, low-level exposure of nonhuman primates to polychlorinated biphenyls. Toxicol Appl Pharmacol 30:440–451.4141140
*Allen JR, Norback DH, Hsu IC. 1974b. Tissue modifications in monkeys as related to absorption, distribution, and excretion of polychlorinated biphenyls. Arch Environ Contam Toxicol 2:86–95.4208176
*Allen-Gil SM, Gubala CP, Wilson R, . 1997. Organochlorine pesticides and polychlorinated biphenyls (PCBs) in sediments and biota from four US Arctic lakes. Arch Environ Contam Toxicol 33(4):378–387.9419256
*Alley EG, Lu G. 1995. Analysis of polychlorinated biphenyls in fatty biological matrixes by on-line supercritical fluid extraction and supercritical fluid cleanup. J AOAC Int 78(4):1051–1054.7580317
Altenkirch H, Stoltenburg G, Haller D, Hopmann D, Walter G. 1996. Clinical data on three cases of occupationally induced PCB-intoxication. Neurotoxicology 17(3–4):639–643.9086484
*Althaus FR, Lawrence SD, Sattler GL, . 1982. Chemical quantification of unscheduled DNA synthesis in cultured hepatocytes as an assay for the rapid screening of potential chemical carcinogens. Cancer Res 42:3010–3015.7093950
Altman NH, New AE, McConnell EE, . 1979. A spontaneous outbreak of polychlorinated biphenyl (PCB) toxicity in Rhesus monkeys (macaca mulatta): Clinical observations. Lab Anim Sci 29(5):661–665.117226
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Altmann L, Lilienthal H, Hany J, . 1998. Inhibition of long-term potentiation in developing rat visual cortex but not hippocampus by in utero exposure to polychlorinated biphenyls. Dev Brain Res 110:257–260.9748615
*Altmann L, Weinand-Haerer A, Lilienthal H, . 1995. Maternal exposure to polychlorinated biphenyls inhibits long-term potentiation in the visual cortex of adult rats. Neurosci Lett 202(1–2):53–56.8787829
*Altshul L, Korrick S, Tolbert P, . 1999. Cord blood levels of PCBs, p,p’-DDE and HCB in infants born in communities adjacent to a PCB-contaminated hazardous waste site. Organohalogen Compounds 44:67–70.
*Alvares AP, Fischbein A, Anderson KE, . 1977. Alterations in drug metabolism in workers exposed to polychlorinated biphenyls. Clin Pharmacol Ther 22:140–146.407043
*American Liver Foundation. 2000. Gilbert’s Syndrome. October 22, 2000. Http://www.gastro.com/liverpg/gilberts.htm.
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987a. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Andersen ME, MacNaughton MG, Clewell HJ, . 1987b. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am Ind Hyg Assoc J 48(4):335–343.3591649
*Andersen ME, Mills JJ, Gargas ML, . 1993. Modeling receptor-mediated processes with dioxin: implications for pharmacokinetics and risk assessment. Risk Anal 13:25–36.8383868
*Anderson DJ, Bloem TB, Blankenbaker RK, . 1999. Concentrations of polychlorinated biphenyls in the water column of the Laurentian Great Lakes: Spring 1993. J Great Lakes Res 25(1):160–170.
Anderson HA. 1985. Utilization of adipose tissue biopsy in characterizing human halogenated hydrocarbon exposure. Environ Health Perspect 60:127–131.2992921
*Anderson HA. 1989. General population exposure to environmental concentrations of halogenated biphenyls. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 325–344.
*Anderson HA, Falk C, Hanrahan L, . 1998. Profiles of Great Lakes critical pollutants: A sentinel analysis of human blood and urine. Environ Health Perspect 106(5):279–289.9560354
*Anderson JW, Rossi SS, Tukey RH, . 1995. A biomarker, P450 RGS, for assessing the induction potential of environmental samples. Environ Toxicol Chem 14:1159–1169.
*Anderson LM, Beebe LE, Fox SD, . 1991. Promotion of mouse lung tumors by bioaccumulated polychlorinated aromatic hydrocarbons. Exp Lung Res 17:455–471.1904809
*Anderson LM, Fox SD, Riggs CW, . 1993. Selective retention of polychlorinated biphenyl congeners in lung and liver after single-dose exposure of infant mice to Aroclor 1254. J Environ Pathol Toxicol Oncol 12(1):3–16.8459365
*Anderson LM, Logsdon D, Ruskie S, . 1994. Promotion by polychlorinated biphenyls of lung and liver tumors in mice. Carcinogenesis 15(10):2245–2248.7955061
*Anderson LM, van Havere K, Budinger JM. 1983. Effects of polychlorinated biphenyls on lung and liver tumors initiated in suckling mice by N-nitrosodimethylamine. J Natl Cancer Inst 71:157–163.6408294
*Anderson LM, Ward JM, Fox SD, . 1986. Effects of a single dose of polychlorinated biphenyls to infant mice on N-nitrosodimethylamine-initiated lung and liver tumors. Int J Cancer 38:109–116.3087890
*Anderson PN, Hites RA. 1996. OH radical reactions: The major removal pathway for polychlorinated biphenyls from the atmosphere. Environ Sci Technol 30(5):1756–1763.
*Andersson L, Nikolaidis E, Brunstrom E, . 1991. Effects of polychlorinated biphenyls with Ah receptor affinity on lymphoid development in the thymus and the bursa of Fabricius of chick embryos in ovo and in mouse thymus anlagen in vitro. Toxicol Appl Pharmacol 107:183–188.1846246
*Andersson O, Linder CE, Olsson M, . 1988. Spatial differences and temporal trends of organochlorine compounds in biota from the northwestern hemisphere. Arch Environ Contam Toxicol 17:755–765.3228296
Andersson O, Nordlund-Moller L, Barnes HJ, . 1994. Heterologous expression of human uteroglobin/polychlorinated biphenyl-binding protein. J Biol Chem 269:19081–19087.7518449
*Andersson PL, Blom A, Johannisson A, . 1999. Assessment of PCBs and hydroxylated PCBs as potential xenoestrogens: In vitro studies based on MCF-7 cell proliferation and induction of vitellogenin in primary culture of rainbow trout hepatocytes. Arch Environ Contam Toxicol 37:145–150.10398763
*Ando M, Saito H, Wakisaka I. 1985. Transfer of polychlorinated biphenyls (PCBs) to newborn infants through the placenta and mothers’ milk. Arch Environ Contam Toxicol 14:51–57.3919656
*Andrews JE. 1989. Polychlorinated biphenyl (Aroclor 1254) induced changes in femur morphometry calcium metabolism and nephrotoxicity. Toxicology 57:83–96.2501909
Angus WGR, Contreras ML. 1994. The effects of Aroclor 1254 on undifferentiated and NGF-stimulated differentiating PC12 cells. Neurotoxicology 15:809–818.7715852
*Angus WGR, Mousa MA, Vargas VM, . 1997. Inhibition of L-aromatic amino acid decarboxylase by polychlorinated biphenyls. Neurotoxicology 18:857–868.9339832
*Anid PJ, Ravest-Webster BP, Vogel TM. 1993. Effect of hydrogen peroxide on the biodegradation of PCBs in anaerobically dechlorinated river sediments. Biodegradation 4(4):241–248.7764921
*Anitescu G, Tavlarides LL. 1998. Solubility of individual polychlorinated biphenyl (PCB) congeners in supercritical fluids: CO_2_,CO_2_/MeOH and CO_2_/n-C_4_H_10_. Journal of Supercritical Fluids 14(3):197–211.
*Ankley GT, Niemi GJ, Lodge KB, . 1993. Uptake of planar polychlorinated biphenyls and 2,3,7,8-substituted polychlorinated dibenzofurans and dibenzo-p-dioxins by birds nesting in the lower Fox River and Green Bay, Wisconsin, USA. Arch Environ Contam Toxicol 24:332–344.
*AOAC. 1990. Association of Official Analytical Chemists. Agricultural chemicals; contaminants; drugs. Pesticides and industrial chemical residues. 1:274–280.
Aono S, Tanabe S, Fujise Y, . 1997. Persistent organochlorines in minke whale (balaenoptera acutorostrata) and their prey species from the Antarctic and the North Pacific. Environ Pollut 98(1):81–89.15093347
*Apfelbach R, Engelhart A, Behnisch P, . 1998. The olfactory system as a portal of entry for airborne polychlorinated biphenyls (PCBs) to the brain? Arch Toxicol 72(5):314–317.9630019
*Arbon RE, Mincher BJ, Knighton WB. 1994. Gamma-X-Ray destruction of individual PCB congeners in neutral 2-propanol. Environ Sci Technol 28(12):2191–2196.22191761
*Arbon RE, Mincher BJ, Knighton W. 1996. Gamma-ray destruction of PCBs in isooctane and transformer oil. Environ Sci Technol 30(6):1866–1871.
*Arcaro KF, Vakharia DD, Yang Y, . 1998. Lack of synergy by mixtures of weakly estrogenic hydroxylated polychlorinated biphenyls and pesticides. Environ Health Perspect Suppl 106(4):1041–1046.
*Arcaro KF, Yi L, Seegal RF, . 1999. 2,2’,6,6’-Tetrachlorobiphenyl is estrogenic in vitro and in vivo. J Cell Biochem 72:94–102.10025670
*Arimoto R. 1989. Atmospheric deposition of chemical contaminants to the Great Lakes. J Great Lakes Res 15:339–356.
*Ariyoshi N, Koga N, Oguri K, . 1992. Metabolism of 2,4,5,2’,4’,5’-hexachlorobiphenyl with liver microsomes of phenobarbital-treated dog; the possible formation of PCB 2,3-arene oxide intermediate. Xenobiotica 22(11):1275–1290.1492420
*Ariyoshi N, Oguri K, Koga N, . 1995. Metabolism of highly persistent PCB congener, 2,4,5,2’, 4’, 5’-hexachlorobiphenyl, by human CYP2B6. Biochem Biophys Res Comm 212(2): 455–460.7626059
Armstrong DE, Swackhamer DL. 1983. PCB accumulation in southern Lake Michigan sediments: Evaluation from core analysis. In: Mackay D, ., eds. Physical behavior of PCBs in the Great Lakes. Ann Arbor, MI: Ann Arbor Science Press, 229–244.
*Arnold DL, Bryce F, Karpinski K, . 1993b. Toxicological consequences of Aroclor 1254 ingestion by female Rhesus (macaca mulatta) monkeys. Part 1B. Prebreeding phase: Clinical and analytical laboratory findings. Food Chem Toxicol 31(11):811–824.8258410
*Arnold DL, Bryce F, McGuire PF, . 1995. Toxicological consequences of Aroclor 1254 ingestion by female Rhesus (macaca mulatta) monkeys. Part 2. Reproduction and infant findings. Food Chem Toxicol 33:457–474.7797173
*Arnold DL, Bryce F, Mes J, . 1999. Toxicological consequences of feeding PCB congeners to infant Rhesus (macaca mulatta) and Cynomolgus (macaca fascicularis) monkeys. Food Chem Toxicol 37:153–167.10227739
*Arnold DL, Bryce F, Stapley R, . 1993a. Toxicological consequences of Aroclor 1254 ingestion by female Rhesus (macaca mulatta) monkeys. Part 1A. Prebreeding phase: Clinical health findings. Food Chem Toxicol 31(11):799–810.8258409
*Arnold DL, Mes J, Bryce F, . 1990. A pilot study on the effects of Aroclor 1254 ingestion by Rhesus and Cynomolgus monkeys as a model for human ingestion of PCBs. Food Chem Toxicol 28:847–857.2125970
*Arnold DL, Nera EA, Stapley R, . 1996. Prevalence of endometriosis in Rhesus (macaca mulatta) monkeys ingesting PCB (Aroclor 1254): Review and evaluation. Fundam Appl Toxicol 31(1):42–55.8998952
*Arnold DL, Nera EA, Stapley R, . 1997. Toxicological consequences of Aroclor 1254 ingestion by female rhesus (macaca mulatta) monkeys and their nursing infants. Part 3: Post-reproduction and pathological findings. Food Chem Toxicol 35(12):1191–1207.9449225
*Arnold DL, Stapley R, Bryce F, . 1998. A multigeneration study to ascertain the toxicological effects of Great Lakes salmon fed to rats: Study overview and design. Regul Toxicol Pharmacol 27:S1–S7.9618329
Arnold SF, Klotz DM, Collins BM, . 1996. Synergistic activation of estrogen receptor with combinations of environmental chemicals. Science 272:1489–1492.8633243
*Aronson KJ, Miller AB, Woolcott CG, . 2000. Breast adipose tissue concentrations of polychlorinated biphenyls and other organochlorines and breast cancer risk. Cancer Epidemiol Biomarkers Prev 9:55–63.10667464
Assaf-Anid N, Nies L, Vogel TM. 1992. Reductive dechlorination of a polychlorinated biphenyl congener and hexachlorobenzene by vitamin B_12_. Appl Environ Microbiol 58:1057–1060.1575479
*ASTER. 1996. ASTER (Assessment Tools for the Evaluation of Risk) ecotoxicity profile. Duluth, MN: U.S. Environmental Protection Agency, Environmental Research Laboratory.
*ASTER. 1998. ASTER (Assessment Tools for the Evaluation of Risk) ecotoxicity profile. Duluth, MN: U.S. Environmental Protection Agency, Environmental Research Laboratory.
*Astroff B, Safe S. 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin as an antiestrogen: Effect on rat uterine peroxidase activity. Biochem Pharmacol 39:485–488.2154986
*Atkinson R. 1987. Estimation of OH radical reaction rate constants and atmospheric lifetimes for polychlorobiphenyls, dibenzo-p-dioxins, and dibenzofurans. Environ Sci Technol 21:305–307.22185111
*Atkinson R. 1996. Atmospheric chemistry of PCBs, PCDDs and PCDFs. Issues Environ Sci Technol 6:53–72.
*Atlas E, Giam CS. 1988. Ambient concentration and precipitation scavenging of atmospheric organic pollutants. Water Air Soil Pollut 38:19–36.
*ATSDR. 1987. Final report: Exposure study of persons possibly exposed to polychlorinated biphenyl in Paoli, Pennsylvania. Atlanta, GA: U.S. Department of Health and Human Services, Office of External Affairs, Exposure and Disease Registry Branch, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37617–37634.
ATSDR. 1992. Draft toxicological profile for chlorinated dibenzofurans (CDFs). Atlanta, GA: U.S Department of Health and Human Services, Office of External Affairs, Exposure and Disease Registry Branch, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1994. Toxicological profile for chlorodibenzofurans. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1995. Exposure to PCBs from hazardous waste among Mohawk women and infants at Akwesasne. Atlanta, GA.: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1998. Toxicological profile for chlorinated dibenzo-p-dioxins. Atlanta, GA: U.S Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR/CDC. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction, Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*Atuma SS, Aune M. 1999. Method for the determination of PCB Congeners and Chlorinated Pesticides in human blood serum. Bull Environ Contam Toxicol 62: 8–15.9870983
*Aulerich RJ, Ringer RK. 1977. Current status of PCB toxicity to mink, and effect on their reproduction. Arch Environ Contam Toxicol 6:279–292.409355
*Aulerich RJ, Bursian SJ, Breslin WJ, . 1985. Toxicological manifestations of 2,4,5, 2’,4’,5’-, 2,3,6,2’,3’,6’-, and 3,4,5,3’,4’,5’-hexachlorobiphenyl and Aroclor 1254 in mink. J Toxicol Environ Health 15:63–79.3920403
*Aulerich RJ, Bursian SJ, Evans MG, . 1987. Toxicity of 3,4,5,3’,4’,5’-hexachlorobiphenyl to mink. Arch Environ Contam Toxicol 16:53–60.3101620
*Aulerich RJ, Ringer RK, Safronoff J. 1986. Assessment of primary vs. secondary toxicity of Aroclor® 1254 to mink. Arch Environ Contam Toxicol 15:393–399.3090951
Aulerich RJ, Ringer RK, Safronoff J. 1990. Assessment of primary vs secondary toxicity of Aroclor® 1254 to mink. Michigan State University, Department of Animal Science, East Lansing, MI.
Aust SD, Bourquin A, Loper JC, . 1994. Biodegradation of hazardous wastes. Environ Health Perspect Suppl 102(1):245–252.
*Ayotte P, Dewailly E, Bruneau S, . 1995. Arctic air pollution and human health: what effects should be expected? Sci Total Environ 160/161:529–537.7892583
*Ayotte P, Dewailly E, Ryan JJ, . 1997. PCBs and dioxin-like compounds in plasma of adult Inuit living in Nunavik (Arctic Quebec). Chemosphere 34(5–7):1459–1468.9134679
*Bacci E, Gaggi C. 1985. Polychlorinated biphenyls in plant foliage: Translocation or volatilization from contaminated soils? Bull Environ Contam Toxicol 35:673–681.3935191
*Bachour G, Failing K, Georgii S, . 1998. Species and organ dependence of PCB contamination in fish, foxes, roe deer, and humans. Arch Environ Contam Toxicol 35:666–673.9776785
*Backlin BM, Bergman A. 1995. Histopathology of postpartum placental sites in mink (mustela vison) exposed to polychlorinated biphenyls or fractions thereof. APMIS 103(12):843–54.8562024
*Backlin BM, Gessbo A, Forsberg M, . 1998a. Expression of the insulin-like growth factor II gene in polychlorinated biphenyl exposed female mink (mustela vison) and their fetuses. Mol Pathol 51(1):43–7.9624420
*Backlin BM, Madej A, Forsberg M. 1997. Histology of ovaries and uteri and levels of plasma progesterone, oestradiol-17beta and oestrone sulphate during the implantation period in mated and gonadotrophin-releasing hormone-treated mink (mustela vison) exposed to polychlorinated biphenyls. J Appl Toxicol 17(5):297–306.9339742
*Backlin BM, Persson E, Jones CJ, . 1998b. Polychlorinated biphenyl (PCB) exposure produces placental vascular and trophoblastic lesions in the mink (mustela vison): a light and electron microscopic study. APMIS 106(8):785–99.9744765
*Bacon CE, Jarman WM, Estes JA, . 1999. Comparison of organochlorine contaminants among sea otter (enhydra lutris) populations in California and Alaska. Environ Toxicol Chem 18(3):452–458.
*Baek NH. 1993. Evaluation of immunoassay tests in screening soil contaminated with polychlorinated biphenyls. Bull Environ Contam Toxicol 51:844–851.8257811
*Bager Y, Hemming H, Flodstom S, . 1995. Interaction of 3,4,5,3’,4’-pentachlorobiphenyl and 2,4,5,2’,4’,5’-hexachlorobiphenyl in promotion of altered hepatic foci in rats. Pharmacol Toxicol 77:149–154.8584506
*Bager Y, Kato Y, Kenne K, . 1997. The ability to alter the gap junction protein expression outside GST-P positive foci in liver of rats was associated to the tumour promotion potency of different polychlorinated biphenyls. Chem Biol Interact 103(3):199–212.9134010
*Bahn AK, Grover P, Rosenwaike I, . 1977. PCB and melanoma [Letter]. N Engl J Med 296:108.401456
*Bahn AK, Rosenwaike I, Herrmann N, . 1976. Melanoma after exposure to PCB’s [Letter]. N Engl J Med 295:450.
*Bailey RE, Gonsior SJ, Rhinehard WL. 1983. Biodegradation of the monochlorobiphenyls and biphenyl in river water. Environ Sci Technol 17(10):617–624.22288707
*Baker EL Jr., Landrigan PJ, Glueck CJ, . 1980. Metabolic consequences of exposure to polychlorinated biphenyls (PCB) in sewage sludge. Am J Epidemiol 112(4):553–563.6775528
Baker FD, Bush B, Tumasonis CF, . 1977. Toxicity and persistence of low-level PCB in adult Wistar rats, fetuses, and young. Arch Environ Contam Toxicol 5:143–156.413496
*Baker JE, Eisenreich SJ. 1990. Concentrations and fluxes of polycyclic aromatic hydrocarbons and polychlorinated biphenyls across the air-water interface of Lake Superior. Environ Sci Technol 24:342–352.
*Baker JE, Eisenreich SJ, Johnson TC, . 1985. Chlorinated hydrocarbon cycling in the benthic nepheloid layer of Lake Superior. Environ Sci Technol 19:854–861.22196612
*Balfanz E, Fuchs J, Kieper H. 1993. Sampling and analysis of polychlorinated biphenyls (PCB) in indoor air due to permanently elastic sealants. Chemosphere 26(5):871–880.
*Ballschmiter K, Zell M. 1980. Analysis of polychlorinated biphenyls (PCB) by glass capillary gas chromatography: Composition of technical Aroclor and Clophen-PCB mixtures. Fresenius Z Anal Chem 302:20–31.
*Ballschmiter K, Niemczyk R, Schaefer W, . 1987. Isomer-specific identification of polychlorinated benzenes (PCBs) and -biphenyls (PCB) in effluents of municipal waste incineration. Fresenius Z Anal Chem 328:583–587.
Ballschmiter K, Rappe C, Buser HR. 1989. Chemical properties, analytical methods and environmental levels of PCBs, PETs, PCNs and PBBs. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 47–102.
*Bandh C, Ishaq R, Broman D, . 1996. Separation for subsequent analysis of PCBs, PCDD/Fs and PAHs according to aromaticity and planarity using a two-dimensional HPLC system. Environ Sci Technol 30(1):214–219.
*Bandiera S, Farrell K, Mason G, . 1984. Comparative toxicities of the polychlorinated dibenzofuran (PCDF) and biphenyl (PCB) mixtures which persist in Yusho victims. Chemosphere 13:507–512.
Bandiera S, Safe S, Okey AB. 1982. Binding of polychlorinated biphenyls classified as either phenobarbitone-, 3-methylcholanthrene- or mixed-type inducers to cytosolic Ah receptor. Chem Biol Interact 39:259–277.6804100
*Bank PA, Cullum ME, Jensen RK, . 1989. Effect of hexachlorobiphenyl on vitamin A homeostasis in the rat. Biochim Biophys Acta 990:306–314.2923910
*Bannister R, Davis D, Zacharewski T, . 1987. Aroclor 1254 as a 2,3,7,8-tetrachlorodibenzo-p-dioxin antagonist: Effects on enzyme induction and immunotoxicity. Toxicology 46:29–42.3116725
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessment. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes D, Alford-Stevens A, Birnbaum L, . 1991. Toxicity equivalency factors for PCBs? Quality Assurance: Good Practice, Regulation, and Law 1(1):70–81.
*Barr JR, Oida T, Kimata K, . 1997. Photolysis of environmentally important PCBs. Organohalogen Compounds 33:199–204.
*Barsotti DA, Van Miller JP. 1984. Accumulation of a commercial polychlorinated biphenyl mixture (Aroclor 1016) in adult Rhesus monkeys and their nursing infants. Toxicology 30:31–44.6422585
*Barsotti DA, Marlar RJ, Allen JR. 1976. Reproductive dysfunction in Rhesus monkeys exposed to low levels of polychlorinated biphenyls (Aroclor 1248). Food Cosmet Toxicol 14:99–103.817997
*Battershill JM. 1994. Review of the safety assessment of polychlorinated biphenyls (PCBs) with particular reference to reproductive toxicity. Hum Exp Toxicol 13:581–597.7986570
*Baukal CE, Schafer LL, Papadelis EP. 1994. PCB cleanup using an oxygen/fuel-fired mobile incinerator. Environmental Progress 13(3):188–191.
*Becker GM, McNulty WP, Bell M. 1979. Polychlorinated biphenyls-induced morphologic changes in the gastric mucosa of the Rhesus monkey. Lab Invest 40:373–383.106183
*Bedard DL. 1990. Bacterial transformation of polychlorinated biphenyls. In: Kamely D, Chakrabarty A, Omenn GS, eds. Biotechnology and biodegradation. Houston, TX: Portfolio Publishing Co., 369–388.
*Bedard DL, Haberl ML. 1990. Influence of chlorine subsitution pattern on the degradation of polychlorinated biphenyls by eight bacterial strains. Microb Ecol 20:87–102.24193967
*Bedard DL, May RJ. 1996. Characterization of the polychlorinated biphenyls in the sediments of Woods Pond: Evidence for microbial dechlorination of Aroclor 1260 in situ. Environ Sci Technol 30(1):237–245.
*Bedard DL, Quensen JF. 1995. Microbial reductive dechlorination of polychlorinated biphenyls. In: Young LY, Cerniglia CE, ed. Ecological and applied microbiology; Microbial transformation and degradation of toxic organic chemicals. New York, NY: Wiley-Liss, 127–216.
*Bedard DL, Haberl ML, May RJ, . 1987. Evidence for novel mechanisms of polychlorinated biphenyl metabolism in alcaligenes eutrophus H850. Appl Environ Microbiol 53(5):1103–1112.3111366
*Bedard DL, Van Dort HM, Bunnell SC, . 1993. Stimulation of reductive dechlorination of Aroclor 1260 contaminants in anaerobic slurries of Woods Pond sediment. In: Rogers JE, Abramowicz DA, eds. Anaerobic dehalogenation and its environmental implications. Abstracts of the 1992 American Society for Microbiology Conference. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development, 19–21.
Beebe LE, Fornwald LW, Alworth WL, . 1995. Effect of dietary Aroclor 1254 exposure on lung and kidney cytochromes P450 in female rats: evidence for P4501A2 expression in kidney. Chem Biol Interact 97(3):215–227.7671339
*Beebe LE, Kim YE, Amin S, . 1993. Comparison of transplacental and neonatal initiation of mouse lung and liver tumors by N-nitrosodimethylamine (NDMA) and 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone (NNK) and promotability by a polychlorinated biphenyls mixture (Aroclor 1254). Carcinogenesis 14(8):1545–1548.8353839
*Bell FP, Iverson F, Arnold D, . 1994. Long-term effects of Aroclor 1254 (PCBs) on plasma lipid and carnitine concentrations in rhesus monkey. Toxicology 89(2):139–153.8197591
*Bell M. 1983. Ultrastructural features of the murine cutaneous microvasculature after exposure to polychlorinated biphenyls compounds (PCBs) and benzo-(a)-pyrene (BAP). Virchows Arch B Cell Pathol 42:131–142.
*Belpaeme K, Delbeke K, Zhu L, . 1996. PCBs do not induce DNA breakage in vitro in human lymphocytes. Mutagenesis 11(4):383–389.8671762
*Bemis JC, Seegal RF. 1999. Polychlorinated biphenyls and methylmercury act synergistically to reduce rat brain dopamine content in vitro. Environ Health Perspect 107(11):879–885.
*Benfenati E, Valzacchi S, Mariani G, . 1992. PCDD, PCDF, PCB, PAH, cadmium and lead in roadside soil: Relationship between road distance and concentration. Chemosphere 24(8):1077–1083.
*Benthe HF, Knop J, Schmoldt A. 1972. [Absorption and distribution of polychlorinated biphenyls (PCB) after inhalatory application]. Arch Toxikol 29:85–95. (German)4626428
*Bercovici M, Wassermann, M, Cucos S, . 1983. Serum levels of polychlorinated biphenyls and some organochlorine insecticides in women with recent and former missed abortions. Environ Res 30:169–174.6403348
*Berg V, Polder A, Skaare JU. 1998. Organochlorines in deep-sea fish from the Nordfjord. Chemosphere 38(2):275–282.
*Bergen BJ, Nelson WG, Pruell RJ. 1993. Bioaccumulation of PCB congeners by blue mussels (mytilus edulis) deployed in New Bedford Harbor, Massachusetts. Environ Toxicol Chem 12(9):1671–1681.
*Berger G S. 1994. Epidemiology of endometriosis. In: Modern surgical management of endometriosis. New York: Springer-Verlag.
*Berggrena P, Ishaq R, Zebuhr Y, . 1999. Patterns and levels of organochlorines (DDTs, PCBs, non-ortho PCBs and PCDD/Fs) in male harbour porpoises (phocoena phocoena) from the Baltic Sea, the Kattegat-Skagerrak Seas and the west coast of Norway. Mar Pollut Bull 38(12):1070–1084.
Bergman, A. 1992. Written communication (December 1) to Stephen J. Bosch, Syracuse Research Corporation, regarding studies of effects of PCBs on reproduction in mink. Department of Environmental Chemistry, Stockholm University, Stockholm, Sweden.
*Bergman A, Olsson M. 1985. Pathology of Baltic grey seal and ringed seal females with special reference to adrenocortical hyperplasia: Is environmental pollution the cause of a widely distributed disease syndrome? Finnish Game Research 44:47–62.
*Bergman A, Athanasiadou M, Bergek S, . 1992. PCB and PCB methyl sulfones in mink treated with PCB and various PCB fractions. Ambio 21(8):570–576.
*Bergman A, Hagman A, Jacobsson S, . 1984. Thermal degradation of polychlorinated alkanes. Chemosphere 13(2):237–250.
*Bergman A, Klasson-Wehler E, Kuroki H. 1994. Selective retention of hydroxylated PCB metabolites in blood. Environ Health Perspect 102(5):464–469.8593850
*Berkaw M, Sowers KR, May HD. 1996. Anaerobic ortho dechlorination of polychlorinated biphenyls by estuarine sediments from Baltimore harbor. Appl Environ Microbiol 62(7):2534–2539.16535360
Berkowitz GS, Lapinski RH, Wolff MS. 1996. The role of DDE and polychlorinated biphenyl levels in preterm birth. Arch Environ Contam Toxicol 30(1):139–41.8579383
*Bernhoft A, Nafstad I, Engen P, . 1994. Effects of pre- and postnatal exposure to 3,3’,4,4’,5-pentachlorobiphenyl on physical development, neurobehavioral and xenobiotic metabolizing enzymes in rats. Environ Toxicol Chem 13(10):1589–1597.
*Berry DL, DiGiovanni J, Juchau MR, . 1978. Lack of tumor-promoting ability of certain environmental chemicals in a two-stage mouse skin tumorigenesis assay. Res Commun Chem Pathol Pharmacol 20:101–108.208126
*Berry DL, Slaga TJ, DiGiovanni J, . 1979. Studies with chlorinated dibenzo-p-dioxins, polybrominated biphenyls, and polychlorinated biphenyls in a two-stage system of mouse skin tumorigenesis: Potent anticarcinogenic effects. Ann NY Acad Sci 320:405–414.222192
*Berry MR, Johnson LS, Jones JW, . 1997. Dietary characterizations in a study of human exposures in the lower Rio Grande Valley: I. Foods and beverages. Environ Int 23(5):675–692.
*Bertazzi PA, Riboldi L, Pesatori A, . 1987. Cancer mortality of capacitor manufacturing workers. Am J Ind Med 11:165–176.3103429
*Berti PR, Receveur O, Chan HM, . 1998. Dietary exposure to chemical contaminants from traditional food among adult Dene/Metis in the western Northwest territories, Canada. Environ Res 76:131–142.9515068
Bevelhimer MS, Adams SM, Miranda LE, . 1996. Assessing contaminant distribution and effects in a reservoir fishery. American Fisheries Society Symposium 16:119–132.
*Bidleman TF. 1981. Interlaboratory analysis of high molecular weight organochlorines in ambient air. Atmos Environ 15:619–624.
*Biegel L, Harris M, Davis D, . 1989a. 2,2’,4,4’,5,5’-hexachlorobiphenyl as a 2,3,7,8-tetrachlorodibenzo-p-dioxin antagonist in C57BL/6J mice. Toxicol Appl Pharmacol 97:561–571.2558429
*Biegel L, Howie L, Safe S. 1989b. Polychlorinated biphenyl (PCB) congeners as 2,3,7,8-TCDD antagonists: Teratogenicity studies. Chemosphere 19:955–958.
*Billings RE, McMahon RE. 1978. Microsomal biphenyl hydroxylation: the formation of 3-hydroxybiphenyl and biphenyl catechol. Mol Pharmacol 14:145–154.625282
*Biocca M, Gupta BN, Chae K, . 1981. Toxicity of selected symmetrical hexachlorobiphenyl isomers in the mouse. Toxicol Appl Pharmacol 58:461–474.6787738
*Birnbaum LS, DeVito MJ. 1995. Use of toxic equivalency factors for risk assessment for dioxins and related compounds. Toxicology 105(2–3):391–401.8571375
*Birnbaum LS, Harris MW, Crawford DD, . 1987. Teratogenic effects of polychlorinated dibenzofurans in combination in C57BL/6N mice. Toxicol Appl Pharmacol 91:246–255.3672524
*Birnbaum LS, Weber H, Harris MW, . 1985. Toxic interaction of specific polychlorinated biphenyls and 2,3,7,8-tetrachlorodibenzo-p-dioxin: Increased incidence of cleft palate in mice. Toxicol Appl Pharmacol 77:292–302.3919463
Bishop CA, Ng P, Norstrom RJ, . 1996. Temporal and geographic variation of organochlorine residues in eggs of the common snapping turtle (chelydra serpentina serpentina) (1981-1991) and comparisons to trends in the herring gull (larus argentatus) in the Great Lakes basin in Ontario, Canada. Arch Environ Contam Toxicol 31(4):512–524.8975824
*Bitman J, Cecil HC. 1970. Estrogenic activity of DDT analogs and polychlorinated biphenyls. J Agric Food Chem 18:1108–1112.5483049
Bjerregaard, P. 1995. Health and environment in Greenland and other circumpolar areas. Sci Total Environ 160/161:521–527.7892582
*Blais JM, Schindler DW, Muir DCG, . 1998. Accumulation of persistent organochlorine compounds in mountains of western Canada. Nature 395:585–588.
*Blazak WF, Marcum JB. 1975. Attempts to induce chromosomal breakage in chicken embryos with Aroclor 1242. Poultry Sci 54:310–312.806068
*Bleavins MR, Aulerich RJ, Ringer RK. 1980. Polychlorinated biphenyls (Aroclors 1016 and 1242): Effects on survival and reproduction in mink and ferrets. Arch Environ Contam Toxicol 9:627–635.6776911
*Bleavins MR, Breslin WJ, Aulerich RJ, . 1984. Placental and mammary transfer of a polychlorinated biphenyl mixture (Aroclor 1254) in the European ferret (mustela putorius furo). Environ Toxicol Chem 3:637–644.
*Blumbach J, Nethe LP. 1996. Organic components reduction (PCDD/PCDF/PCB) in flue-gases and residual materials from waste incinerators by use of carbonaceous adsorbents. Chemosphere 32(1):119–131.
*Boers JP, De Leer EWB, Gramberg L, . 1994. Levels of coplanar PCB in flue gases of high temperature processes and their occurrence in environmental samples. Fresenius J Anal Chem 348(1–2):163–166.
*Bohm V, Schulte E, Thier H-P. 1993. Polychlorinated biphenyl residues in food and human milk: Determination of co-planar and mono-ortho substituted congeners. Z Lebensm Unters Forsch 196(5):435–440.8511976
*Bohme F, Welsch-Pausch K, McLachlan MS. 1999. Uptake of airborne semivoatile organic compounds in agricultural plants: Field measurements of interspecies variability. Environ Sci Technol 33:1805–1813.
*Bolger PM. 1999. Personal communications, September 28, 1999. U.S. Food and Drug Administration Center for Food Safety and Applied Nutrition Contaminants Branch.
Bonin J, DesGranges J-L, Bishop CA, . 1995. Comparative study of contaminants in the mudpuppy (amphibia) and the common snapping turtle (reptilia), St. Lawrence River, Canada. Arch Environ Contam Toxicol 28:184–194.
*Bonnyns M, Bastomsky CH. 1976. Polychlorinated biphenyl-induced modification of lymphocyte response to plant mitogens in rats. Experientia 15(4):522–523.
*Book SA, Goldman M. 1975. Thyroidal radioiodine exposure of the fetus. Health Phys 29:874–877.811590
*Boon JP, Duinker JC. 1986. Monitoring of cyclic organochlorines in the marine environment. Environ Monit Assess 7:189–208.24254833
Boon JP, Ouderans RCHM, Duinkeys JC. 1984. Kinetics of individual polychlorinated biphenyl (PCB) components in juvenile sole (solea solea) in relation to their concentrations in food and to lipid metabolism. Comp Biochem Physiol 79:131–42.
*Bopp RF, Chillrud SN, Shuster EL, . 1998. Trends in chlorinated hydrocarbon levels in Hudson River Basin sediments. Environ Health Perspect Suppl 106(4):1075–1081.
*Bopp RF, Simpson HJ, Olsen CR, . 1982. Chlorinated hydrocarbons and radionuclide chronologies in sediments of the Hudson River and estuary, New York. Environ Sci Technol 16:666–676.
*Borchard RE, Welborn ME, Wiekhorst WB, . 1975. Pharmacokinetics of polychlorinated biphenyl components in swine and sheep after a single oral dose. J Pharm Sci 64:1294–1302.807710
*Borlakoglu JT, Walker CH. 1989. Comparative aspects of congener specific PCB metabolism. Eur J Drug Metab Pharmcokinet 14:127–131.
*Borlakoglu JT, Wilkins JPG. 1993a. Correlations between the molecular structures of polyhalogenated biphenyls and their metabolism by hepatic microsomal monooxygenases. Comp Biochem Physiol 105C(1):113–117.
*Borlakoglu JT, Wilkins JPG. 1993b. Metabolism of di-, tri-, tetra-, penta- and hexachlorobiphenyls by hepatic microsomes isolated from control animals and animals treated with Aroclor 1254, a commercial mixture of polychlorinated biphenyls (PCBs). Comp Biochem Physiol 105C(1):95–106.
*Botero JE, Meyer MW, Hurley SS, . 1996. Residues of organochlorines in mallards and blue-winged teal collected in Colombia and Wisconsin, 1984-1989. Arch Environ Contam Toxicol 31(2):225–231.8781073
*Bove FJ, Slade BA, Canady RA. 1999. Evidence of excess cancer mortality in a cohort of workers exposed to polychlorinated biphenyls. J Occup Environ Med 41(9):739–740.10491786
Bowadt S, Larsen B. 1992. Rapid screening of chlorobiphenyl congeners by GC-ECD on a carborane-polydimethylsiloxane copolymer. J High Resolut Chromatogr 15(5):350–351.
Bowerman WW, Giesy JP, Best DA, . 1995. A review of factors affecting productivity of bald eagles in the Great Lakes region: Implications for recovery. Environ Health Perspect Suppl 103(4):51–59.
*Bowes GW, Mulvihill MJ, Simoneit BRT, . 1975. Identification of chlorinated dibenzofurans in American polychlorinated biphenyls. Nature 256:305–307.806811
*Bowman RE, Heironimus MP. 1981. Hypoactivity in adolescent monkeys perinatally exposed to PCBs and hyperactive as juveniles. Neurobehav Toxicol Teratol 3:15–18.
*Bowman RE, Heironimus MP, Allen JR. 1978. Correlation of PCB body burden with behavioral toxicology in monkeys. Pharmacol Biochem Behav 9:49–56.100792
*Boyages SC. 2000. The neuromuscular system and brain in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner & Ingbar’s the thyroid: A fundamental and clinical text. Eighth edition. Philadelphia, PA: Lippincott Williams & Wilkins, 804–810.
Bradlaw JA, Casterline JL. 1979. Induction of enzyme activity in cell culture: A rapid screen for detection of planar polychlorinated organic compounds. J Assoc Off Anal Chem 62:904–916.115836
*Brandt, I, Bergman A. 1987. PCB methyl sulfones and related compounds: Identification of target cells and tissues in different species. Chemosphere 16:1671–1676.
*Brandt I, Lund J, Bergman A, . 1985. Target cells for the polychlorinated biphenyl metabolite 4,4’-bis(methylsulphonyl)-2,2’,5,5’-tetrachlorobiphenyl in lung and kidney. Drug Metab Dispos 13:490–496.2863115
*Brandt-Rauf PW, Niman HL. 1988. Serum screening for oncogene proteins in workers exposed to PCBs. Br J Ind Med 45:689–693.3143397
*Brazner J, DeVita W. 1998. PCBs, DDE, and mercury in young-of-the year littoral fishes from Green Bay, Lake Michigan. J Great Lakes Res 24(1):83–92.
*Bremle G, Larsson P. 1998. PCB in the air during landfilling of a contaminated lake sediment. Atmos Environ 32(6):1011–1019.
*Bremle G, Okla L, Larsson P. 1995. Uptake of PCBs in fish in a contaminated river system: Bioconcentration factors measured in the field. Environ Sci Technol 29:2010–2015.22191349
*Brezner E, Terkel J, Perry AS. 1984. The effect of Aroclor 1254 (PCB) on the physiology of reproduction in the female rat-I. Comp Biochem Physiol 77:65–70.
*Bright DA, Dushenko WT, Grundy SL, . 1995a. Effects of local and distant contaminant sources: Polychlorinated biphenyls and other organochlorines in bottom-dwelling animals from an Arctic estuary. Sci Total Environ 160–161:265–283.
*Bright DA, Dushenko WT, Grundy SL, . 1995b. Evidence for short-range transport of polychlorinated biphenyls in the Canadian Arctic using congener signatures of PCBs in soils. Sci Total Environ 160–161:251–263.
*Brinkman DW, Dickson JR, Wilkinson D. 1995. Full scale hydrotreatment of polychlorinated biphenyls in the presence of used lubricating oils. Environ Sci Technol 29:87–91.22200204
Brouwer A, Ahlbord UG, van Leeuwn FXR, . 1998a. Report of the WHO working group on the assessment of health risks for human infants from exposure to PCDDs, PCDFs and PCBs. Chemosphere 37(9–12):1627–1643.
Brouwer A, Klasson-Wehler E, Bokdam M, . 1990. Competitive inhibition of thyroxin binding to transthyretin by monohydroxy metabolites of 3,4,3’,4’-tetrachlorobiphenyl. Chemosphere 20:1257–1262.
*Brouwer A, Morse DC, Lans MC, . 1998b. Interactions of persistent environmental organohalogens with the thyroid hormone system: mechanisms and possible consequences for animal and human health. Toxicol Ind Health 14:59–84.9460170
*Brown AP, Ganey PE. 1995. Neutrophil degranulation and superoxide production induced by polychlorinated biphenyls are calcium dependent. Toxicol Appl Pharmacol 131:198–205.7716762
Brown AP, Schultze AE, Holdan WL, . 1996. Lipopolysaccharide-induced hepatic injury is enhanced by polychlorinated biphenyls. Environ Health Perspect 104(6):634–640.8793352
*Brown BR. 1987a. Studies on inhalation anesthetic hepatotoxicity. Crisp Data Base National Institutes of Health.
*Brown DP. 1987b. Mortality of workers exposed to polychlorinated biphenyls -An update. Arch Environ Health 42(6):333–339.3125795
*Brown DP, Jones M. 1981. Mortality and industrial hygiene study of workers exposed to polychlorinated biphenyls. Arch Environ Health 36:120–129.6787990
*Brown JF. 1994. Determination of PCB metabolic, excretion, and accumulation rates for use as indicators of biological response and relative risk. Environ Sci Technol 28:2295–2305.22176047
*Brown JF, Lawton RW. 1984. Polychlorinated biphenyl (PCB) partitioning between adipose tissue and serum. Bull Environ Contam Toxicol 33:277–280.6434008
*Brown JF, Wagner RE. 1990. PCB movement, dechlorination, and detoxication in the Acushnet estuary. Environ Toxicol Chem 9:1215–1233.
*Brown JF, Bedard DL, Brennan MJ, . 1987a. Polychlorinated biphenyl dechlorination in aquatic sediments. Science 236:709–712.17748310
*Brown JF, Fish KM, Silkworth JB, . 1998. A proposed general mechanism for rodent liver carcinogenesis by persistent organohalogen compounds at the maximum tolerated dose. Organohalogen Compounds 37:67–70.
*Brown JF, Frame GM, Olson DR, . 1995. The sources of coplanar PCBs. Organohalogen Compounds 26:427–430.
*Brown JF, Lawton RW, Ross MR, . 1989. Persistence of PCB congeners in capacitor workers and yusho patients. Chemosphere 19(1–6):829–834.
Brown JF, Silkworth JB, Mayes BA. 1997. Characterization of PCB composition, tissue accumulation, and correlations with tumorigenicity in chronically dosed male and female Sprague-Dawley rats. Schenectady, NY: General Electric Corporate Research and Development. Batelle Study No. SC920192.
*Brown JF, Wagner RE, Bedard DL, . 1984. PCB transformations in upper Hudson sediments. Northeast Environ Sci 3(3/4):166–178.
*Brown JF, Wagner RE, Bedard DL. 1988. PCB dechlorination in Hudson River sediment. Science 240:1674–1676.3132740
*Brown JF, Wagner RE, Feng H, . 1987b. Environmental dechlorination of PCBs. Environ Toxicol Chem 6:579–593.
*Brown NM, Lamartiniere CA. 1995. Xenoestrogens alter mammary gland differentiation and cell proliferation in the rat. Environ Health Perspect 103:708–713.7588483
*Brownlow CS, Que Hee SS. 1985. Comparison of solid sampling media for Aroclor 1254 vapor under dry and humid conditions. Am Ind Hyg Assoc J 46:421–426.3931447
*Brozoski TJ, Brown RM, Rosvold HE, . 1979. Cognitive deficit caused by regional depletion of dopamine in prefrontal cortex of Rhesus monkey. Science 205(31):929–931.112679
*Brubaker WW, Hites RA. 1998. Gas-phase oxidation products of biphenyl and polychlorinated biphenyls. Environ Sci Technol 32:3913–3918.
*Bruce RW, Heddle JA. 1979. The mutagenic activity of 61 agents as determined by the micronucleus, salmonella, and sperm abnormality assays. Can J Genet Cytol 21:319–333.393369
*Bruckner JV, Jiang WD, Brown JM, . 1977. The influence of ingestion of environmentally encountered levels of a commercial polychlorinated biphenyl mixture (Aroclor 1254) on drug metabolism in the rat. J Pharmacol Exp Ther 202:22–31.406382
*Bruckner JV, Khanna KL, Cornish HH. 1973. Biological responses of the rat to polychlorinated biphenyls. Toxicol Appl Pharmacol 24:434–448.4634185
*Bruckner JV, Khanna KL, Cornish HH. 1974. Effect of prolonged ingestion of polychlorinated biphenyls on the rat. Food Cosmet Toxicol 12:323–330.4140828
*Brunciak PA, Lavorgna CL, Nelson ED, . 1999. Trends and dynamics of persistent organic pollutants in the coastal atmosphere of the mid-Atlantic states. Prepr Ext Abst Div Environ Chem Am Chem Soc 39(1):64–67.
Brunner MJ, Sullivan TM, Singer AW . 1996. An assessment of the chronic toxicity and oncogenicity of Aroclor 1016, Aroclor 1242, Aroclor 1254, and Aroclor 1260 administered in diet to rats. Battelle study no. SC920192, Columbus, OH.
*Brunstrom B, Kihlstrom I, Lundkvist U. 1982. Studies of foetal death and foetal weight in guinea pigs fed polychlorinated biphenyls (PCB). Acta Pharmacol Toxicol 50(2):100–103.
*Bryant CJ, Hartle RW, Crandall MS. 1989. Polychlorinated biphenyl, polychlorinated dibenzo-p-dioxin, and polychlorinated dibenzofuran contamination in PCB disposal facilities. Chemosphere 18:569–576.
*Buchmann A, Ziegler S, Wolf A, . 1991. Effects of polychlorinated biphenyls in rat liver: Correlation between primary subcellular effects and promoting activity. Toxicol Appl Pharmacol 111:454–468.1684070
Buck GM. 1996. Epidemiologic perspective of the developmental neurotoxicity of PCBs in humans. Neurotoxicol Teratol 18(3):239–241.8725632
*Buck GM, Mendola P, Vena JE, . 1999. Paternal Lake Ontario fish consumption and risk of conception delay, New York State angler cohort. Environ Res 80:S13–S18.10092415
*Buck GM, Sever LE, Mendola P, . 1997. Consumption of contaminated sport fish from Lake Ontario and time-to-pregnancy. Am J Epidemiol 146:949–954.9400336
*Buck GM, Vena JE, Schisterman EF, . 2000. Parental consumption of contaminated sport fish from Lake Ontario and predicted fecundability. Epidemiology 11:388–393.10874544
*Buckley TJ, Liddle J, Ashley DL, . 1997. Environmental and biomarker measurements in nine homes in the lower Rio Grande Valley: Multimedia results for pesticides, metals, PAHs, and VOCs. Environ Int 23(5):705–732.
*Buhler F, Schmid P, Schlatter CH. 1988. Kinetics of PCB elimination in man. Chemosphere 17:1717–1726.
*Bunce NJ, Kumar Y, Ravanal L, . 1978. Photochemistry of chlorinated biphenyls in iso-octane solution. Journal of the Chemical Society II:880–884.
*Burgess RM, McKinney RA, Brown WA. 1996. Enrichment of marine sediment colloids with polychlorinated biphenyls: Trends resulting from PCB solubility and chlorination. Environ Sci Technol 30:2556–2566.
*Burkhard LP, Armstrong DE, Andren AW. 1985. Henry’s law constants for the polychlorinated biphenyls. Environ Sci Technol 19:590–596.22148300
*Burse VW, Groce DF, Caudill SP, . 1994. Determination of polychlorinated biphenyl levels in the serum of residents and in the homogenates of seafood from the New Bedford, Massachusetts, area: A comparison of exposure sources through pattern recognition techniques. Sci Total Environ 144:153–177.8209226
Burse VW, Kimbrough RD, Villanueva EC, . 1974. Polychlorinated biphenyls: Storage, distribution, excretion, and recovery: Liver morphology after prolonged dietary ingestion. Arch Environ Health 29:301–307.4215375
*Burse VW, Korver MP, Needham LL, . 1989. Gas chromatographic determination of polychlorinated biphenyls (as Aroclor 1254) in serum: Collaborative study. J Assoc Off Anal Chem 72(4):649–659.2547752
Burse VW, Needham LL, Korver MP, . 1983a. Gas-liquid chromatographic determination of polychlorinated biphenyls and a selected number of chlorinated hydrocarbons in serum. J Assoc Off Anal Chem 66:32–39.6402483
Burse VW, Needham LL, Lapeza CR, Jr, . 1983b. Evaluation of potential analytical approach for determination of polychlorinated biphenyls in serum: Interlaboratory study. J Assoc Off Anal Chem 66:956–968.6411677
*Buser H-R, Zook DR, Rappe C. 1992. Determination of methyl sulfone-substituted polychlorobiphenyls by mass spectrometric techniques with application to environmental samples. Anal Chem 64(10):1176–1183.
*Bush B, Bennett AH, Snow JT. 1986. Polychlorobiphenyl congeners, p,p’-DDE, and sperm function in humans. Arch Environ Contam Toxicol 15:333–341.3090950
*Bush B, Streeter RW, Sloan RJ. 1989. Polychlorobiphenyl (PCB) congeners in striped bass (morone saxatilis) from marine and estuarine waters of New York State determined by capillary gas chromatography. Arch Environ Contam Toxicol 19(1):49–61.
*Bushart SP, Bush B, Barnard EL, . 1998. Volatilization of extensively dechlorinated polychlorinated biphenyls from historically contaminated sediments. Environ Toxicol Chem 17(10):1927–1933.
*Bushnell PJ, Rice DC. 1999. Behavioral assessments of learning and attention in rats exposed perinatally to 3,3’,4,4’,5-pentachlorobiphenyl (PCB 126). Neurotoxicol Teratol 21(4):381–392.10440482
*Byrne JJ, Carbone JP, Hanson EA. 1987. Hypothyroidism and abnormalities in the kinetics of thyroid hormone metabolism in rats treated chronically with polychlorinated biphenyl and polybrominated biphenyl. Endocrinology 121:520–527.3036477
*Byrne JJ, Carbone JP, Pepe MG. 1988. Suppression of serum adrenal cortex hormones by chronic low-dose polychlorobiphenyl or polybromobiphenyl treatments. Arch Environ Contam Toxicol 17:47–53.2827589
Bysshe SE. 1990. Bioconcentration factor in aquatic organisms. In: Lyman WJ ., eds. Handbook of chemical property estimation methods. Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 5-1 to 5-30.
*Calabrese EJ, Sorenson AJ. 1977. The health effects of PCBs with particular emphasis on human high risk groups. Rev Environ Health 2:285–304.414312
*Capen CC. 2000. Anatomy. In: Braverman LE, Utiger RD, ed. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 19–43.
*Carey AE, Harvey GR. 1978. Metabolism of polychlorinated biphenyls by marine bacteria. Bull Environ Contam Toxicol 20:527–534.102386
Carey AE, Douglas P, Tai H, . 1979b. Pesticide residue concentrations in soils of five United States cities, 1971-Urban soils monitoring program. Pestic Monitor J 13:17–22.
Carey AE, Gowen JA, Tai H, . 1979a. Pesticide residue levels in soils and crops from 37 states, 1972 - National Soils Monitoring Program (IV). Pestic Monit J 12:209–229.461116
*Carroll KM, Harkness MR, Bracco AA, . 1994. Application of a permeant/polymer diffusional model to the desorption of polychlorinated biphenyls from Hudson River sediments. Environ Sci Technol 28:253–258.22176170
*Carter JW. 1984. Hypercholesterolemia induced by dietary PCBs (Aroclor 1254) in Fischer rats. Bull Environ Contam Toxicol 33:78–83.6432079
*Carter JW. 1985. Effects of dietary PCBs (Aroclor 1254) on serum levels of lipoprotein cholesterol in Fischer rats. Bull Environ Contam Toxicol 34:427–431.3919789
*Carter JW, Koo SI. 1984. Effects of dietary Aroclor 1254 (PCBs) on serum levels of lipoprotein cholesterol and tissue distribution of zinc, copper and calcium in Fischer rats. Nutr Rep Int 29:223–232.
*Casey AC, Berger DF, Lombardo JP, . 1999. Aroclor 1242 inhalation and ingestion by Sprague-Dawley rats. J Toxicol Environ Health 56:311–342.
*CDC. 1999a. New Jersey. Center for Disease Control & Prevention. July 9, 1999. http://search.cdc.gov/shd/search2.html
CDC. 1999b. Colorado. Center for Disease Control & Prevention. July 9, 1999. http://search.cdc.gov/shd/search2.html
*CDC. 1999c. Colorado. Center for Disease Control & Prevention. July 9, 1999. http://search.cdc.gov/shd/search2.html
*CDC. 1999d. Colorado. Center for Disease Control & Prevention. July 9, 1999. http://search.cdc.gov/shd/search2.html
*CDC. 1999e. Kansas. Center for Disease Control & Prevention. July 9, 1999. http://search.cdc.gov/shd/search2.html
CELDS. 1994. Computer-aided Environmental Legislative Data Systems. United States Army Corps of Engineers Environmental Technical Information Systems, University of Illinois, Urbana, IL.
*Chadwick RW, George SE, Kohan MJ, . 1993. Potentiation of 2,6-dinitrotoluene genotoxicity in Fischer-344 rats by pretreatment with Aroclor 1254. Toxicology 80(2–3):153–171.8327998
*Chakraborty D, Bhattacharyva A, Chatterjee J, . 1978. Biochemical studies on polychlorinated biphenyl toxicity in rats: Manipulation by vitamin C. Int J Vitam Nutr Res 48:22–31.415995
*Chan CH, Bruce G, Harrison B. 1994. Wet deposition of organochlorine pesticides and polychlorinated biphenyls to the Great Lakes. J Great Lakes Res 20(3):546–560.
Chan HM. 1998. A database for environmental contaminants in traditional foods in northern and Arctic Canada: development and applications. Food Addit Contam 15(2):127–134.9602917
*Chan HM, El Khoury M, Sedgemore M, . 1996. Organochlorine pesticides and polychlorinated biphenyl congeners in ooligan grease: a traditional food fat of British Columbia first nations. J Food Comp Anal 9(1):32–42.
*Chan HM, Trifonopoulos M, Ing A, . 1999. Consumption of freshwater fish in Kahnawake: Risks and benefits. Environ Res 80:S213–S222.10092436
*Chang KJ, Hsieh KH, Lee TP, . 1980. Studies on patients with polychlorinated biphenyl poisoning: 2. Determination of urinary coproporphyrin, uroporphyrin, γ-aminolevulinic acid and porphobilinogen. Res Commun Chem Pathol Pharmacol 30:547–554.6789414
*Chang KJ, Hsieh KH, Lee TP, . 1981. Immunologic evaluation of patients with polychlorinated biphenyl poisoning: Determination of lymphocyte subpopulations. Toxicol Appl Pharmacol 61:58–63.6794186
*Chang K-J, Hsieh K-H, Lee T-P, . 1982a. Immunologic evaluation of patients with polychlorinated biphenyl poisoning: Determination of phagocyte Fc and complement receptors. Environ Res 28:329–334.6811262
*Chang K-J, Hsieh K-H, Tang S-Y, . 1982b. Immunologic evaluation of patients with polychlorinated biphenyl poisoning: Evaluation of delayed-type skin hypersensitivity response and its relation to clinical studies. J Toxicol Environ Health 9:217–223.6804636
*Chao W-Y, Hsu C-C, Guo YL. 1997. Middle-ear disease in children exposed prenatally to polychlorinated biphenyls and polychlorinated dibenzofurans. Arch Environ Health 52(4):257–262.9210724
*Chapin R, Stevens J, Hughes C, . 1996. Symposium overview; endocrine modulation of reproduction. Fundam Appl Toxicol 29:1–17.8838635
*Chase KH, Wong O, Thomas D, . 1982. Clinical and metabolic abnormalities associated with occupational exposure to polychlorinated biphenyls (PCBs). J Occup Med 24:109–114.6799628
*Chauhan KR, Kodavanti PRS, McKinney JD. 2000. Assessing the role of ortho-substitution on polychlorinated biphenyl binding to transthyretin, a thyroxine transport protein. Toxicol Appl Pharmacol 162:10–21.10631123
*Cheek AO, Kow K, Chen J, . 1999. Potential mechanisms of thyroid disruption in humans: Interaction of organochlorine compounds with thyroid receptor, transthyretin, and thyroid-binding globulin. Environ Health Perspect 107(4):273–278.
*Chemfinder. 2000. Chlorodiphenyl (62% Cl) [37324-23-5]. http://www.chemfinder.com
*Chen LC, Berberian I, Koch B, . 1992. Polychlorinated and polybrominated biphenyl congeners and retinoid levels in rat tissues: Structure-activity relationships. Toxicol Appl Pharmacol 114:47–55.1316647
*Chen M, Hong CS, Bush B, . 1988. Anaerobic biodegradation of polychlorinated biphenyls by bacteria from Hudson River sediments. Ecotoxicol Environ Saf 16:95–105.3148459
*Chen PH, Luo ML, Wong CK, . 1982. Comparative rates of elimination of some individual polychlorinated biphenyls from the blood of PCB-poisoned patients in Taiwan. Food Chem Toxicol 20:417–425.6813209
*Chen R-C, Tang S-Y, Miyata H, . 1985. Polychlorinated biphenyl poisoning: Correlation of sensory and motor nerve conduction, neurologic symptoms, and blood levels of polychlorinated biphenyls, quaterphenyls, and dibenzofurans. Environ Res 37:340–348.3926478
*Chen Y-CJ, Yu M-LM, Rogan WJ, . 1994. A 6-year follow-up of behavior and activity disorders in the Taiwan Yu-chen children. Am J Public Health 84(3):415–421.8129058
*Chevreuil M, Blanchard M, Teil MJ, . 1998. Polychlorobiphenyl behaviour in the water/sediment system of the Seine river, France. Water Res 32(4):1204–1212.
*Chia LG, Chu FL. 1984. Neurological studies on polychlorinated biphenyl (PCB)-poisoned patients. Am J Ind Med 5:117–126.6422742
*Chia L-G, Chu F-L. 1985. A clinical and electrophysiological study of patients with polychlorinated biphenyl poisoning. J Neurol Neurosurg Psychiatry 48:894–901.2995592
*Chiarenzelli J, Scrudato R, Arnold G, . 1996. Volatilization of polychlorinated biphenyls from sediment during drying at ambient conditions. Chemosphere 33(5):899–911.
*Chiarenzelli J, Scrudato R, Bush B, . 1998. Do large-scale remedial and dredging events have the potential to release significant amounts of semivolatile compounds to the atmosphere? Environ Health Perspect 106:47–49.9435147
*Chiarenzelli J, Scrudato R, Wunderlich M, . 1995. Photodecomposition of PCBs absorbed on sediment and industrial waste: Implications for photocatalytic treatment of contaminated solids. Chemosphere 31(5):3259–3272.
*Chiarenzelli JR, Scrudato RJ, Wunderlich ML, . 1997. PCB volatile loss and the moisture content of sediment during drying. Chemosphere 34(11):2429–2436.
*Chin Y-P, Weber WJ Jr. 1989. Estimating the effects of dispersed organic polymers on the sorption of contaminants by natural solids. 1. A predictive thermodynamic humic substance-organic solute interaction model. Environ Sci Technol 23:978–984.
*Chiou CT, Porter PE, Schmedding DW. 1983. Partition equilibria of nonionic organic compounds between soil organic matter and water. Environ Sci Technol 17:227–231.22304639
*Choi PSK, Nack CH, Flinn JE. 1974. Distribution of polychlorinated biphenyls in an aerated biological oxidation wastewater treatment system. Bull Environ Contam Toxicol 11:12–17.4215485
*Choksi NY, Kodavanti PR, Tilson HA, . 1997. Effects of polychlorinated biphenyls (PCBs) on brain tyrosine hydroxylase activity and dopamine synthesis in rats. Fundam Appl Toxicol 39(1):76–80.9325030
*Chou SM, Miike T, Payne WM, . 1979. Neuropathy of “spinning syndrome” induced by prenatal intoxication with a PCB in mice. Ann NY Acad Sci 320:373–395.110196
Christensen ER, Lo CK. 1986. Polychlorinated biphenyls in dated sediments of Milwaukee Harbor, Wisconsin, USA. Environ Poll 12:217–232.
*Chu I, Lecavalier P, Valli T, . 1998a. Toxicity of polychlorinated biphenyl congeners in rats. In: Johansson N, Bergman A, Broman D, ., ed. Organohalogen compounds. Akademitryck, Edsbruk: Vol. 37, 105–107.
*Chu I, Lecavalier P, Yagminas A, . 1999. Mixture effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin and polychlorinated biphenyl congeners in rats. Organohalogen Compounds 42:409–412.
*Chu I, Poon R, Yagminas A, . 1998b. Subchronic toxicity of PCB 105 (2,3,3’,4,4’-pentachlorobiphenyl) in rats. J Appl Toxicol 18:285–292.9719429
*Chu I, Villeneuve DC, Becking GC, . 1980. Short-term study of the combined effects of mirex, photomirex, and kepone with halogenated biphenyls in rats. J Toxicol Environ Health 6:421–432.6156243
*Chu I, Velleneuve DC, Tagimnas A, . 1994. Subchronic toxicity of 3,3’,4,4’,5-pentachlorobiphenyl in the rat. Fundam Appl Toxicol 22:457–468.8050640
*Chu I, Villeneuve DC, Yagminas A, . 1995. Toxicity of PCB 77 (3,3’,4,4’-tetrachlorobiphenyl) and PCB 118 (2,3’,4,4’,5-pentachlorobiphenyl) in the rat following subchronic dietary exposure. Fundam Appl Toxicol 26:282–292.7589917
*Chu I, Villeneuve DC, Yagminas A, . 1996a. Toxicity of 2,2’,4,4’,5,5’-hexachlorobiphenyl in rats: Effects following a 90-day oral exposure. J Appl Toxicol 16(2):121–128.8935785
*Chu I, Villeneuve DC, Yagminas A, . 1996b. Toxicity of 2,4,4’-trichlorobiphenyl in rats following 90-day dietary exposure. J Toxicol Environ Health 49(3):301–318.8876656
*Chuang FW, Larson RA, Wessan N. 1995. Zero-valent iron promoted dechlorination of polychlorinated biphenyls. Environ Sci Technol 29(9):2460–2463.22280292
*Chui VWD, Lam-Leung SY, Chan TC. 1991. Residues of polychlorinated biphenyls (PCBs) in fish, water and sediment from Shing Mun River. Biomed Environ Sci 4:399–408.1781935
Clark DR Jr, Stafford CJ. 1981. Effects of DDE and PCB (Aroclor 1260) on experimentally poisoned female little brown bats (myotis lucifugus): lethal brain concentrations. J Toxicol Environ Health 7(6):925–934.6790723
Clark T, Clark K, Paterson S, . 1988. Wildlife monitoring, modeling, and fugacity. Environ Sci Technol 22:120–127.19995007
*Cleland GB, McElroy PJ, Sonstegard RA. 1989. Immunomodulation in C57BI/6 mice following consumption of halogenated aromatic hydrocarbon-contaminated coho salmon (Oncorhynchus kisutch) from Lake Ontario. J Toxicol Environ Health 27:477–486.2527307
*Clevenger MA, Roberts SM, Lattin DL, . 1989. The pharmacokinetics of 2,2’,5,5’-tetrachlorobiphenyl and 3,3’,4,4’-tetrachlorobiphenyl and its relationship to toxicity. Toxicol Appl Pharmacol 100:315–327.2506674
*Clevenger TE, Hemphill DD, Roberts K, . 1983. Chemical composition and possible mutagenicity of municipal sludges. J Water Pollut Control Fed 55(12):1470–1475.
*Clewell HJ III, Andersen M. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cobb GP, Wood PD. 1997. PCB concentrations in eggs and chorioallantoic membranes of loggerhead sea turtles (caretta caretta) from the Cape Romain National Wildlife Refuge. Chemosphere 34(3):539–549.9051902
Cobb GP, Wood PD, O’Quinn M. 1997. Polychlorinated biphenyls in eggs and chorioallantoic membranes of American alligators (alligator mississippiensis) from coastal South Carolina. Environ Toxicol Chem 16(7):1456–1462.
Cocco P, Kazerouni N, Zahm SH. 2000. Cancer mortality and environmental exposure to DDE in the United States. Environ Health Perspect 108(1):1–4.10620518
*Cogliano VJ. 1998. Assessing the cancer risk from environmental PCBs. Environ Health Perspect 106(6):317–323.9618347
Cole DC, Kearney J, Ryan JJ, . 1997. Plasma levels and profiles of dioxin and dioxin-like compounds in Ontario Great Lakes anglers. Chemosphere 34(5–7):1401–1409.
*Collins WT, Capen CC. 1980a. Ultrastructural and functional alterations of the rat thyroid gland produced by polychlorinated biphenyls compared with iodide excess and deficiency, and thyrotropin and thyroxine administration. Virchow Arch B Cell Pathol 33:213–231.
*Collins WT, Capen CC. 1980b. Biliary excretion of ^125^I-thyroxine and fine structural alterations in the thyroid glands of Gunn rats fed polychlorinated biphenyls (PCB). Lab Invest 43:158–164.6772880
*Collins WT, Capen CC. 1980c. Fine structural lesions and hormonal alterations in thyroid glands of perinatal rats exposed in utero and by the milk to polychlorinated biphenyls. Am J Pathol 99:125–142.6767410
*Collins WT, Capen CC, Kasza L, . 1977. Effect of polychlorinated biphenyl (PCB) on the thyroid gland of rats: Ultrastructural and biochemical investigations. Am J Pathol 89:119–136.199066
*Colombi A, Maroni M, Ferioli A, . 1982. Increase in urinary porphyrin excretion in workers exposed to polychlorinated biphenyls. J Appl Toxicol 2:117–121.
*Condon SK. 1983. Personal communications, August 25 and 28, 1983. Commonwealth of Massachusetts Department of Public Health.
*Connor K, Ramamootrhy K, Moore M, . 1997. Hydroxylated polychlorinated biphenyls (PCBs) as estrogens and antiestrogens: Structure-activity relationships. Toxicol Appl Pharmacol 145:111–123.9221830
*Connor K, Safe S, Jefcoate CR, . 1995. Structure-dependent induction of CYP2B by polychlorinated biphenyl congeners in female Sprague-Dawley rats. Biochem Pharmacol 50(11):1913–1920.8615872
*Conolly RB, Szabo S, Jaeger RJ. 1979. Vinylidene fluoride: Acute hepatotoxicity in rats pretreated with PCB or phenobarbital. Proc Soc Exp Biol Med 162:163–169.116243
*Cooke PS, Zhao Y-D, Hansen LG. 1996. Neonatal polychlorinated biphenyl treatment increases adult testis size and sperm production in the rat. Toxicol Appl Pharmacol 136:112–117.8560463
*Cordle F, Locke R, Springer J. 1982. Risk assessment in a federal regulatory agency: An assessment of risk associated with the human consumption of some species of fish contaminated with polychlorinated biphenyls (PCBs). Environ Health Perspect 45:171–182.6814904
*Corey DA, Juarez de Ku LM, Bingman VP, . 1996. Effects of exposure to polychlorinated biphenyl (PCB) from conception on growth, and development of endocrine, neurochemical, and cognitive measures in 60 day old rats. Growth Dev Aging 60:131–143.9007564
*Coristine S, Haffner GD, Ciborowski JJH, . 1996. Elimination rates of selected di-ortho, mono-ortho, and non-ortho substituted polychlorinated biphenyls in rainbow trout (oncorhynchus mykiss). Environ Toxicol Chem 15(8):1382–1387.
Corrigan FM, Murray L, Wyatt CL, . 1998. Diorthosubstituted polychlorinated biphenyls in caudate nucleus in Parkinson’s disease. Exp Neurol 150(2):339–42.9527905
*Cotham WE, Bidleman TF. 1995. Polycyclic aromatic hydrocarbons and polychlorinated biphenyls in air at an urban and a rural site near Lake Michigan. Environ Sci Technol 29(11):2782–2789.22206525
*Courval JM, DeHoog JV, Holzman CB, . 1996. Fish consumption and other characteristics of reproductive-aged Michigan anglers-a potential population for studying the effects of consumption of Great Lakes fish on reproductive health. Toxicol Ind Health 12(3–4):347–359.8843552
*Courval JM, DeHoog JV, Stein AD, . 1999. Sport-caught fish consumption and conception delay in licensed Michigan anglers. Environ Res 80:S183–S188.10092432
*Cousins IT, Jones KC. 1998. Air-soil exchange of semi-volatile organic compounds (SOCs) in the UK. Environ Pollut 102:105–118.
*Cousins IT, Beck AJ, Jones KC. 1999. A review of the processes involved in the exchange of semi-volatile organic compounds (SVOC) across the air-soil interface. Sci Total Environ 228:5–24.
*Cousins IT, Hartlieb N, Teichmann C, . 1997. Measured and predicted volatilisation fluxes of PCBs from contaminated sludge-amended soils. Environ Pollut 97(3):229–238.15093360
*Crawford DW, Bonnevie NL, Wenning RJ. 1995. Sources of pollution and sediment in Newark Bay, New Jersey. Ecotoxicol Environ Saf 36:85–100.
Creaser CS, Fernandes AR. 1986. Background levels of polychlorinated biphenyls in British soils. Chemosphere 15:499–508.
Creaser CS, Krokos F, Startin JR. 1992. Analytical methods for the determination of non-ortho substituted chlorobiphenyls: A review. Chemosphere 25(12):1981–2008.
*Crisp T, Clegg E, Cooper R, . 1998. Environmental endocrine disruption: An effects assessment and analysis. Environ Health Perspect 106(Suppl 1):11–56.9539004
*CRITFC. 1994. A fish consumption survey of the Umatilla, Nez Perce, Yakima and Warm springs tribes of the Columbia River basin. Portland, OR: Columbia River Inter-Tribal Fish Commission.
*Crofton KM, Rice DC. 1999. Low-frequency hearing loss following perinatal exposure to 3,3’,4,4’,5-pentachlorobiphenyl (PCB 126) in rats. Neurotoxicol Teratol 21(3):299–301.10386834
*Cross JN, Hardy JT, Hose JE, . 1987. Contaminant concentrations and toxicity of sea-surface microlayer near Los Angeles, California. Mar Environ Res 23:307–323.
*Cullen AC, Vorhees DJ, Altshul LM. 1996. Influence of harbor contamination on the level and composition of polychlorinated biphenyls in produce in Greater New Bedford, Massachusetts. Environ Sci Technol 30(5):1581–1588.
Cunningham PA, Smith SL,Tippett JP, . 1994. A national fish consumption advisory data base: A step toward consistency. Fisheries 19:14–23.
*Curley A, Burse VW, Grim ME, . 1971. Polychlorinated biphenyls: Distribution and storage in body fluids and tissues of Sherman rats. Environ Res 4:481–495.
*Currado GM, Harrad S. Air-to-grass transfer of PCBs. Organohalogen Compounds 41:409–411.
Custer TW, Sparks DW, Sobiech SA, . 1996. Organochlorine accumulation by sentinel mallards at the Winston-Thomas sewage treatment plant, Bloomington, Indiana. Arch Environ Contam Toxicol 30(2):163–169.
*Czaja K, Ludwicki JK, Goralczyk K, . 1997a. Effect of age and number of deliveries on mean concentration of organochlorine compounds in human breast milk in Poland. Bull Environ Contam Toxicol 59:407–413.9256394
*Czaja K, Ludwicki JK, Goralczy K, . 1997b. Organochlorine in pesticides, HCB, and PCBs in human milk in Poland. Bull Environ Contam Toxicol 58:769–775.9115141
*Czaja K, Ludwicki JK, Goralczyk K, . 1999a. Effect of changes in excretion of persistent organochlorine compounds with human breast milk on related exposure of breast-fed infants. Arch Environ Contam Toxicol 36:498–503.10227871
*Czaja K, Ludwicki JK, Robson MG, . 1999b. Concentrations of persistent organochlorine compounds in the placenta and milk of the same women. Prepr Ext Abst Div Environ Chem Am Chem Soc 39(1):150–152.
*Czygan P, Greim H, Garro AJ, . 1973. Microsomal metabolism of dimethylnitrosamine and the cytochrome P-450 dependency of its activation to a mutagen. Cancer Res 33:2983–2986.4201248
*Dahl P, Lindstrom G, Wiberg K, . 1995. Absorption of polychlorinated biphenyls, dibenzo-p-dioxins and dibenzofurans by breast-fed infants. Chemosphere 30(12):2297–2306.7620852
Daly H, Darvill T, Lonky E, . 1996. Behavioral effects of prenatal and adult exposure to toxic chemicals found in Lake Ontario fish: Two methodological approaches. Toxicol Ind Health 12:419–426.8843558
*Daly JW, Jerina DM, Witkop B. 1972. Arene oxides and the NIH shift: the metabolism, toxicity and carcinogenicity of aromatic compounds. Experientia 28:1129–1149.4117670
Danse IR, Jaeger RJ, Kava R, . 1997. Position paper of the American Council on Science and Health: Public health concerns about environmental polychlorinated biphenyls (PCBs). Ecotoxicol Environ Saf 38(2):71–84.9463054
*Dar E, Kanarek MS, Anderson HA, . 1992. Fish consumption and reproductive outcomes in Green Bay, Wisconsin. Environ Res 59(1):189–201.1425509
*Darnerud PO, Morse D, Klasson-Wehler E, . 1996a. Binding of a 3,3’, 4,4’-tetrachlorobiphenyl (CB-77) metabolite to fetal transthyretin and effects on fetal thyroid hormone levels in mice. Toxicology 106(1–3):105–114.8571380
Darnerud PO, Sinjari T, Jonsson CJ. 1996b. Foetal uptake of coplanar polychlorinated biphenyl (PCB) congeners in mice. Pharmacol Toxicol 78(3):187–192.8882353
*Daston GP, Gooch JW, Breslin WJ, . 1997. Environmental estrogens and reproductive health: A discussion of the human and environmental data. Reprod Toxicol 1(4):465–481.
Datta S, Hansen L, McConnell L, . 1998b. Pesticides and PCB contaminants in fish and tadpoles from the Kaweah River basin, California. Bull Environ Contam Toxicol 60:829–836.9606257
*Datta S, McConnell LL, Baker JE, . 1998a. Evidence for atmospheric transport and deposition of polychlorinated biphenyls to the Lake Tahoe basin, California-Nevada. Environ Sci Technol 32(10):1378–1385.
*Datta S, Ohyama K, Dunlap DY, . 1999. Evidence for organochlorine contamination in tissues of salmonids in Lake Tahoe. Ecotoxicol Environ Saf 42:94–101.9931244
*David M, Brondyk LM, Sonzogni WC. 1994. Distribution of PCB congeners in Sheboygan River (Wisconsin) sediments. J Great Lakes Res 20(3):510–522.
*Davidorf FH, Knupp JA. 1979. Epidemiology of ocular melanoma: Incidence and geographic relationship in Ohio (1967-1977). Ohio State Med J 75:561–564.113714
Davis DL, Bradlow HL. 1995. Can environmental estrogens cause breast cancer? Sci Am (October 1995):166–172.
*Davis D, Safe S. 1989. Dose-response immunotoxicities of commercial polychlorinated biphenyls (PCBs) and their interaction with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Lett 48:35–43.2501913
*Davis D, Safe S. 1990. Immunosuppressive activities of polychlorinated biphenyls in C57BL/6N mice: Structure-activity relationships as Ah receptor agonists and partial antagonists. Toxicology 63:97–111.2166363
Davis DL, Bradlow HL, Wolff M, . 1993. Medical hypothesis: Xenoestrogens as preventable causes of breast cancer. Environ Health Perspect 101(5):372–377.8119245
*De Filippis P, Chianese A, Pochetti F. 1997. Removal of PCBs from mineral oils. Chemosphere 35(8):1659–1667.
De Guise S, Martineau D, Beland P, . 1995. Possible mechanisms of action of environmental contaminants on St. Lawrence beluga whales (delphinapterus leucas). Environ Health Perspect Suppl 103(4):73–77.
*de Haan LHJ, Halfwerk S, Hovens SEL, . 1995. Inhibition of intercellular communication and induction of ethoxyresorufin-O-deethylase activity by polychlorobiphenyls, dibenzo-p-dioxins and dibenzofurans in mouse hepa1c1c7 cells. Environ Toxicol Pharmacol 1(1):27–37.
De Haan LHJ, Simons JFA, Bos AT, . 1994. Inhibition of intercellular communication by 2,3,7,8-tetrachlorodibenzo-p-dioxin and dioxin-like PCBs in mouse hepatoma cells (Hepa1c1c7): Involvement of the Ah receptor. Toxicol Appl Pharmacol 129:283–293.7992318
*Dekoning EP, Karmaus W. 2000. PCB exposure in utero and via breast milk. A review. J Expo Anal Environ Epidemiol 10:285–293.10910120
*Dellinger, JA, Gerstenberger, SL, Hansen, LK, . 1997. Ojibwa health study: Assessing the health risks from consuming contaminated Great Lakes fish. Health Conference ‘97 Great Lakes and St. Lawrence. Montreal, Quebec, Canada. (As cited in Johnson et al. 1998).
*Dellinger JA, Meyers RM, Gebhardt KJ, . 1996. The Ojibwa health study: Fish residue comparisons for Lakes Superior, Michigan, and Huron. Toxicol Ind Health 12(3–4):393–402.8843556
*Deml E, Oesterle D. 1982. Sex-dependent promoting effect of polychlorinated biphenyls on enzyme-altered islands induced by diethylnitrosamine in rat liver. Carcinogenesis 3:1449–1453.6217918
*Deml E, Oesterle D. 1987. Dose-response of promotion by polychlorinated biphenyls and chloroform in rat liver foci bioassay. Arch Toxicol 60:209–211.2887150
*Deml E, Oesterle D, Wiebel FJ. 1983. Benzo[a]pyrene initiates enzyme-altered islands in the liver of adult rats following single pretreatment and promotion with polychlorinated biphenyls. Cancer Lett 19:301–304.6136322
Denomme MA, Bandiera S, Lambert I, . 1983. Polychlorinated biphenyls as phenobarbitone-type inducers of microsomal enzymes: Structure-activity relationships for a series of 2,4-dichloro-substituted congeners. Biochem Pharmacol 32:2955–2963.6414484
*DeRosa C, Richter P, Pohl H, . 1998. Environmental exposures that affect the endocrine system: Public health implications. J Toxicol Environ Health, Part B 1:3–26.
*Desaulniers D, Poon R, Phan W, . 1997. Reproductive and thyroid hormone levels in rats following 90-day dietary exposure to PCB 28 (2,4,4’-trichlorobiphenyl) or PCB 77 (3,3’4,4’-tetrachlorobiphenyl). Toxicol Ind Health 13(5):627–638.9284533
Desaulniers D, Leingartner K, Wade M., . 1999. Effects of acute exposure to PCBs 126 and 153 on anterior pituitary and thyroid hormones and FSH isoforms in adult Sprague-Dawley male rats. Toxicol Sci 47:158–169.10220852
*des Rosiers PE, Lee A. 1986. PCBs fires: Correlation of chlorobenzene isomer and PCB homolog contents of PCB fluids with PCDD and PCDF contents of soot. Chemosphere 15:1313–1323.
DeVault DS, Clark JM, Lahvis G, . 1988. Contaminants and trends in fall run coho salmon. J Great Lakes Res 14:23–33.
*De Voogt P, Brinkman UA. 1989. Production, properties and usage of polychlorinated biphenyls. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 3–45.
De Voogt P, Klamer JC, Govers H. 1986. Simultaneous clean up and fractionation of organochlorine compounds by adsorption chromatography. J Chromatogr 363:407–411.
Devoto E, Fiore BJ, Millikan R, . 1997. Correlations among human blood levels of specific PCB congeners and implications for epidemiologic studies. Am J Ind Med 32(6):606–613.9358917
*Dewailly E, Ayotte P, Bruneau S, . 1993. Inuit exposure to organochlorines through the aquatic food chain in Arctic Quebec. Environ Health Perspect 101(7):618–620.8143594
*Dewailly E, Ayotte P, Bruneau S, . 2000. Susceptibility to infections and immune status in Inuit infants exposed to organochlorines. Environ Health Perspect 108(3):205–211.10706525
Dewailly E, Ayotte P, Laliberte C, . 1996. Polychlorinated biphenyl (PCB) and dichlorodiphenyl dichloroethylene (DDE) concentrations in the breast milk of women in Quebec. Am J Public Health 86(9):1241–1246.8806375
*Dewailly E, Mulvad G, Pedersen HS, . 1999. Concentration of organochlorines in human brain, liver, and adipose tissue autopsy samples from Greenland. Environ Health Perspect 107(10):823–828.
*Dewailly E, Ryan JJ, Laliberte C, . 1994. Exposure of remote maritime populations to coplanar PCBs. Environ Health Perspect Suppl 102(1):205–209.
*Dewailly E, Weber JP, Gingras S, . 1991. Coplanar PCBs in human milk in the province of Quebec, Canada: Are they more toxic than dioxin for breast fed infants? Bull Environ Contam Toxicol 47:491–498.1786431
*Dickhut RM, Gustafson KE. 1995. Atmospheric inputs of selected polycyclic aromatic hydrocarbons and polychlorinated biphenyls to southern Chesapeake Bay. Mar Pollut Bull 30(6):385–396.
*DiGiovanni J, Viaje A, Berry DL, . 1977. Tumor-initiating ability of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and Aroclor 1254 in the two-stage system of mouse skin carcinogenesis. Bull Environ Contam Toxicol 18:552–557.412534
*Dikshith TSS, Rockwood W, Abraham R, . 1975. Effects of a polychlorinated biphenyl (Aroclor 1254) on rat testis. Exp Mol Pathol 22:376–385.805060
Dilling WL, Miracle GE, Boggs GU. 1983. Tropospheric phototransformation rates of 2-, 3-, and 4-chlorobiphenyls. 186th ACS National Meeting. [Abstract]
*Djordjevic MV, Hoffman D, Fan J, . 1994. Assessment of chlorinated pesticides and polychlorinated biphenyls in adipose breast tissue using a supercritical fluid extraction method. Carcinogenesis 15(11):2581–2585.7955109
*Dluhy, RC. 2000. The adrenal cortex in hypothyroidism. In: Braverman LE, Utiger RD, ed. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 815–819.
*DOI. 1986. Polychlorinated biphenyl hazards to fish, wildlife, and invertebrates: A synoptic review. U.S. Department of the Interior, Fish and Wildlife Service. Biological Report 85(1.7).
*DOI. 1996. Planar PCB hazards to fish, wildlife, and invertebrates: A synoptic review. Washington, DC: U.S. Department of the Interior, National Biological Service. Biological Report 31.
*Donaldson GM, Schutt JL, Hunter P. 1999. Organochlorine contamination in bald eagle eggs and nestlings from the Canadian Great Lakes. Arch Environ Contam Toxicol 36:70–80.9828264
*Dorgan JF, Brock JW, Rothman N, . 1999. Serum organochloride pesticides and PCBs and breast cancer risk: results from a prospective analysis (USA). Cancer Causes Control 10:1–11.10334636
*Dowling DN, Pipke R, Dwyer DF. 1993. A DNA module encoding bph genes for the degradation of polychlorinated biphenyls (PCBs). FEMS Microbiol Lett 113(2):149–154.8262365
*Downs TJ, Cifuentes-Garcia E, Suffet IM. 1999. Risk screening for exposure to groundwater pollution in a wastewater irrigation district of the Mexico City region. Environ Health Perspect 107(7):553–561.10398590
*Draper WM, Wijekoon D, Stephens RD. 1991. Speciation and quantitation of aroclors in hazardous wastes based on PCB congener data. Chemosphere 22(1–2):147–163.
*Drotman DP. 1981. Human exposure to PCBs in southern Idaho: Internal report. Atlanta, GA: Centers for Disease Control. EPA 79-105-2.
*Duarte-Davidson R, Jones KC. 1994. Polychlorinated biphenyls (PCBs) in the UK population: estimated intake, exposure and body burden. Sci Total Environ 151:131–152.8073264
*Dubois M, Pfohl-Leszkowicz A, Grosse Y, Kremers P. 1995. DNA adducts and P450 induction in human, rat and avian liver cells after exposure to polychlorobiphenyls. Mutat Res 345(3–4):181–190.8552139
*Duebelbeis DO, Pieczonka G, Kapila S, . 1989. Application of a dual column reaction chromatography system for confirmatory analysis of polychlorinated biphenyl congeners. Chemosphere 19:143–148.
*Duggan RE, Corneliussen PE, Duggan MB, . 1983. Pesticide residue levels in foods in the United States from July 1, 1969 to June 30, 1976. Washington, DC: Food and Drug Administration, 10–14.
*Duignan DB, Sipes IG, Ciaccio PJ, . 1988. The metabolism of xenobiotics and endogenous compounds by the constitutive dog liver cytochrome P450 PBD-2. Arch Biochem Biophys 267:294–304.3143308
*Duignan DB, Sipes IG, Leonard TB, . 1987. Purification and characterization of dog hepatic cytochrome P-450 isozyme responsible for the metabolism of 2,2’,4,4’,5,5’-hexachlorobiphenyl. Arch Biochem Biophys 225:290–303.
*Duinker JC, Hillebrand MTJ. 1979. Behaviour of PCB, pentachlorobenzene, hexachlorobenzene, alpha-HCH, gamma-HCH, beta-HCH, dieldrin, endrin and p,p’-DDD in the Rhine-Meuse estuary and the adjacent coastal area. Neth J Sea Res 13:256–281.
Duinker JC, Schulz DE, Petrick G. 1988. Multidimensional gas chromatography with electron capture detection for the determination of toxic congeners in polychlorinated biphenyl mixtures. Anal Chem 60:478–482.3130761
*Dunnivant FM, Elzerman AW. 1988. Aqueous solubility and Henry’s law constant data for PCB congeners for evaluation of quantitative structure-property relationships (QSPRs). Chemosphere 17:525–541.
*Dunnivant FM, Eisenman AW, Jurs PC, . 1992. Quantitative structure-property relationships for aqueous solubilities and Henry’s law constants of polychlorinated biphenyls. Environ Sci Technol 26:1567–1573.
*Durell GS, Lizotte RD Jr. 1998. PCB levels at 26 New York City and New Jersey WPCPs that discharge to the New York/New Jersey Harbor estuary. Environ Sci Technol 32(8):1022–1031.
*Durfee RL. 1976. Production and usage of PCB’s in the United States. In: Proceedings of the National Conference on Polychlorinated Biphenyls, Chicago, 1975. EPA-560/6-75-004. Washington, DC: U.S. Environmental Protection Agency, 103–107.
Eduljee G, Badsha K, Price L. 1985. Environmental monitoring for PCB and heavy metals in the vicinity of a chemical waste disposal facility-I. Chemosphere 14:1371–1382.
Eduljee G, Badsha K, Scudamore N. 1986. Environmental monitoring for PCB and trace metals in the vicinity of a chemical waste disposal facility-II. Chemosphere 15:81–93.
*Eggold BT, Amrhein JF, Coshun MA. 1996. PCB accumulation by salmonine smolts and adults in Lake Michigan and its tributaries and its effect on stocking policies. J Great Lakes Res 22(2):403–413.
*Eisenreich SJ, Baker JE, Franz T, . 1992. Atmospheric deposition of hydrophobic organic contaminants to the Laurentian Great Lakes. In: Schnoor JL, ed. Fate of pesticides and chemicals in the environment. New York, NY: John Wiley & Sons, Inc., 51–78.
*Eisenreich SJ, Capel PD, Looney BB. 1983. PCB dynamics in Lake Superior water. In: Mackay D, ed. Physical behavior of PCBs in the Great Lakes. Ann Arbor, MI: Ann Arbor Science Press, 181–211.
Eisenreich SJ, Capel PD, Robbins JA, . 1989. Accumulation and diagnosis of chlorinated hydrocarbons in lacustrine sediments. Environ Sci Technol 23:1116–1126.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
*Elder VA, Proctor BL, Hites RA. 1981. Organic compounds found near dump sites in Niagara Falls, New York. Environ Sci Technol 15(10):1237–1243.22299705
*Elliott JE, Martin PA. 1998. Chlorinated hydrocarbon contaminants in grebes and seaducks wintering on the coast of British Columbia, Canada: 1988-1993. Environ Monit Assess 53:337–362.
Elliott JE, Norstrom RJ, Smith GE. 1996. Patterns, trends, and toxicological significance of chlorinated hydrocarbon and mercury contaminants in bald eagle eggs from the Pacific Coast of Canada, 1990-1994. Arch Environ Contam Toxicol 31(3):354–367.8854829
*Elo O, Vuojolahti P, Janhunen H, . 1985. Recent PCB incidents in Finland. Environ Health Perspect 60:315–319.3928359
*Emmett EA. 1985. Polychlorinated biphenyl exposure and effects in transformer repair workers. Environ Health Perspect 60:185–192.2863134
Emmett EA. 1986. Toxic responses of the skin. In: Casarett and Doull’s toxicology: The basic science of poisons. 3rd ed. New York, NY: Macmillan Publishing Company, 427–428.
*Emmett EA, Maroni M, Jeffery JS, . 1988b. Studies of transformer repair workers exposed to PCBs: II. Results of clinical laboratory investigations. Am J Ind Med 14:47–62.3136647
*Emmett EA, Maroni M, Schmith JM, . 1988a. Studies of transformer repair workers exposed to PCBs: I. Study design, PCB concentrations, questionnaire, and clinical examination results. Am J Ind Med 13:415–427.3129934
*Endicott D, Kreis RG, Mackelburg L, . 1998. Modeling PCB bioaccumulation by the zebra mussel (dreissena polymorpha) in Saginaw Bay, Lake Huron. J Great Lakes Res 24(2):411–426.
EPA. 1973a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Method 625.
EPA. 1973b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Method 608.
EPA. 1975a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.24.
EPA. 1975b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32.
*EPA. 1976a. PCBs in the United States: Industrial use and environmental distribution. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. NTIS PB252012.
EPA. 1976b. Review of PCB levels in the environment. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA 560/7/76-001. NTIS PB253735.
EPA. 1977a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.4.
*EPA. 1977b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.105.
EPA. 1977c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 750.39.
EPA. 1977d. U.S. Environmental Protection Agency. Toxic pollutants effluent standards. Code of Federal Regulations. 40 CFR 129.
EPA. 1978a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1978b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 750.11.
*EPA. 1978c. U.S. Environmental Protection Agency. Support document: Draft voluntary environmental impact statement for polychlorinated biphenyls (PCBs) manufacturing, processing, distribution in commerce and use ban regulation (Section 6(e) of TSCA).
*EPA. 1979a. U.S. Environmental Protection Agency. Polychlorinated biphenyls (PCBs) in manufacturing, processing, distribution in commerce, and use prohibition; Final rule. Federal Register 44:31514–31568.
EPA. 1979b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
EPA. 1979c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 257. 3-5.
EPA. 1979d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 750.31.
*EPA. 1979e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 761.70
*EPA 1979f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 761.60-761.65.
*EPA. 1979g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 761.20.
*EPA. 1979h. Water-related environmental fate of 129 priority pollutants, Vol. II. Washington, DC: U.S. Environmental Protection Agency, 40-2 to 43-10. EPA 440/4-79-029a.
*EPA. 1979i. Water-related environmental fate of 129 priority pollutants, Vol. I. Washington, DC: U.S. Environmental Protection Agency, 36-1 to 36-18. EPA 440/4-79-029a.
*EPA. 1980a. Hazard waste generation and commercial hazardous waste management capacity: An assessment, SW-894. Washington, DC: U.S. Environmental Protection Agency, D-4.
*EPA. 1980b. Ambient water quality criteria for polychlorinated biphenyls. Washington, DC: U.S. Environmental Protection Agency, Criteria and Standards Division, Office of Water Regulations and Standards. EPA 440/5-80-068.
EPA. 1980c. U.S. Environmental Protection Agency. Chemical imports and exports. Code of Federal Regulations. 40 CFR 707.20.
EPA. 1980d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 App. IX.
EPA. 1980e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 707.60.
*EPA. 1980f. Toxicity of the polychlorinated biphenyl Aroclor 1016 to mink. Duluth, MN: U.S. Environmental Protection Agency, Environmental Research Laboratory. EPA-600 3-80-033.
*EPA. 1981. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
*EPA. 1982a. Test methods. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S Environmental Protection Agency, Office of Research and Development, Environmental Monitoring and Support Laboratory, 608-1 to 608-11; 625-1 to 625-12. EPA 600/4-82-057.
*EPA. 1982b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 423 App. A.
EPA. 1982c. Polychlorinated biphenyls in human adipose tissue and mother’s milk. Washington, DC: U.S. Environmental Protection Agency. PB83-253179.
*EPA. 1983a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11.
EPA. 1983b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 270.10.
*EPA. 1983c. Environmental transport and transformation of polychlorinated biphenyls. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA-560/5-83-025. PB84-142579.
EPA. 1984a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 125.
EPA. 1984b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 704.43.
EPA. 1984c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 704.45.
*EPA. 1984d. Intrauterine exposure of humans to PCBs (polychlorinated biphenyls): Newborn effects. Duluth, MN: U.S. Environmental Protection Agency. EPA 600/3-84-060. NTIS PB84-188887.
EPA. 1985a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50.
*EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1985c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 797.
EPA. 1985d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 798.5265.
EPA. 1986a. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Volume III - Semi-volatile organic compounds. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA 560/5-86-037.
*EPA. 1986b. Method 8080: Organochlorine pesticides and PCB. In: Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 8080-1 to 8080-27.
EPA. 1986c. Development of advisory levels for polychlorinated biphenyls (PCBs) cleanup. Washington, DC: U.S. Environmental Protection Agency. EPA 600/6-86-02.
EPA. 1986d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
EPA. 1986e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403 App. B.
EPA. 1986f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 403, App. B.
EPA. 1986g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 286.6.
EPA. 1986h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.50.
*EPA. 1986i. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.42.
EPA. 1986j. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.42.
EPA. 1986k. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.5.
*EPA. 1987a. U.S. Environmental Protection Agency. Statement of work for organics analyses, multi-media, multiconcentration. U.S. EPA Contract Laboratory Program. Revised 8/87.
EPA. 1987b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264 App. IX.
*EPA. 1987c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.32.
*EPA. 1987d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268 App. III.
EPA. 1987e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 795.120.
*EPA. 1987f. Method 525.1: Determination of organic compounds in drinking water by liquid-solid extraction and capillary column gas chromatography/mass spectrometry. In: Methods for the determination of organic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA-600/4-88/039.
EPA. 1987g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.32.
EPA. 1987h. U.S. Environmental Protection Agency. Toxic chemical release reporting: Community right-to-know. Specific toxic chemical listings. chemicals and chemical categories to which this part applies. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1988a. Drinking water criteria document for polychlorinated biphenyls (PCBs). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. ECAO-CIN-414.
*EPA. 1988b. U.S. Environmental Protection Agency. Method 608: Organochlorine pesticides and PCBs. Code of Federal Regulations. 40 CFR 136, App. A, 354-374.
*EPA. 1988c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 761.
EPA. 1988d. U.S. Environmental Protection Agency. Toxic chemical release reporting: Community right-to-know. Code of Federal Regulations. 40 CFR 372.
*EPA. 1988e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 148.12.
EPA. 1988f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 App. VIII.
EPA. 1988g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.43.
EPA. 1988h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1988i. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 795.54.
*EPA. 1988j. Guidance for conducting remedial investigations and feasibility studies under CERCLA (Interim Final). U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA/540/G-89/004.
EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-88-066F.
EPA. 1989b. Drinking water regulations and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
*EPA. 1989c. Methods for the determination of organic compounds in drinking water. Method No. 505, 508 and 508A. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Monitoring Systems Laboratory. EPA/600/4-88-039.
*EPA. 1989d. Guidance on preparing Superfund decision documents: The proposed plan, the record of decision, explanation of significant differences, the record of decision amendment. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. NTIS PB91-921256
EPA. 1990a. Drinking water criteria document for polychlorinated biphenyls (PCBs). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. ECAO-CIN-414.
EPA. 1990b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.8.
EPA. 1990c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.2.
EPA 1990d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 761.80.
*EPA. 1990e. Guidance on remedial actions for Superfund sites with PCB contamination. U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA 540/G-90/007.
EPA. 1990f. U.S. Environmental Protection Agency. Standards of performance for volatile organic compounds (VOC) emissions from synthetic organic chemical manufacturing industry (SOCMI) distillation operation. Code of Federal Regulations. 40 CFR 60.667.
*EPA. 1990g. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-90/066A.
*EPA. 1991a. Workshop report on toxicity equivalency factors for polychlorinated biphenyl congeners. Risk Assessment Forum. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1991b. U.S. Environmental Protection Agency. National primary drinking water regulations--synthetic organic chemicals and inorganic chemicals; monitoring for unregulated contaminants; National primary drinking water regulations implementations; National secondary drinking water regulations. 40 CFR parts 141, 142, and 143. Federal Register 58:3526–3597.
EPA. 1991c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.61.
EPA. 1991d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 142.62.
EPA. 1991e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258.20.
EPA. 1991f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266 App. VII.
EPA. 1991g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268 App. Vll.
EPA. 1991h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 131.61.
EPA. 1991i. Risk assessment guidance for Superfund. Volume 1: Human health evaluation manual (part B). Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. NTIS PB92-963339.
EPA. 1992a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.45.
EPA. 1992b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 279.10.
*EPA. 1992c. National study of chemical residues in fish. Volume I. U.S. Environmental Protection Agency. EPA 823-R-92-008a.
EPA. 1992d. U.S. Environmental Protection Agency. Land disposal restrictions. Prohibitions on storage of restricted wastes. Code of Federal Regulations. 40 CFR 268.50.
EPA. 1992e. U.S. Environmental Protection Agency. National primary drinking water regulations. Maximum contaminant level goals for organic contaminants. Code of Federal Regulations. 40 CFR 141.50
EPA. 1992f. U.S. Environmental Protection Agency. Guidelines for exposure assessment; Notice. Federal Register 57(104):22888.
EPA. 1993a. U.S. Environmental Protection Agency. Federal Register. 40 FR 20802.
EPA. 1993b. U.S. Environmental Protection Agency. Federal Register. 58 FR 65622-65632.
EPA. 1993c. U.S. Environmental Protection Agency. Federal Register. 58 FR 60970-60976.
EPA. 1993d. U.S. Environmental Protection Agency. Federal Register. 58 FR 54702-54810.
EPA. 1993e. U.S. Environmental Protection Agency. Federal Register. 58 FR 54836-54862.
EPA. 1993f. U.S. Environmental Protection Agency. Federal Register. 58 FR 48092-48204.
EPA. 1993g. U.S. Environmental Protection Agency. Federal Register. 58 FR 46052-46056.
*EPA. 1993h. Guidance for assessing chemical contaminant data for use in fish advisories. U.S. Environmental Protection Agency, Office of Water. EPA 823-R-93-002.
EPA. 1994a. U.S. Environmental Protection Agency. Federal Register. 59 FR 15968-16039.
EPA. 1994b. U.S. Environmental Protection Agency. Federal Register. 59 FR 15504-15571.
EPA. 1994c. Drinking water regulations and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water.
EPA. 1994d. U.S. Environmental Protection Agency. Disposal of polychlorinated biphenyls. Federal Register. 59 FR 62788-62887.
*EPA. 1994f. Method 8080A. Organochlorine pesticides and polychlorinated biphenyls by gas chromatography. U.S. Environmental Protection Agency.
EPA. 1994g. Land disposal restrictions. Treatment standards for hazardous debris. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.45.
*EPA. 1994h. USEPA contract laboratory program: National functional guidelines for organic data review. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. NTIS PB94-963501.
*EPA. 1995a. Toxic chemical release inventory reporting form R and Instructions. U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA 745-K-95-051.
EPA. 1995b. Guidance for assessing chemical contaminant data for use in fish advisories. Vol 1: Fish sampling and analysis. Second edition. U.S. Environmental Protection Agency, Office of Science and Technology, Office of Water. EPA 823-R-95-007.
*EPA. 1995c. Method 8082. Polychlorinated biphenyls (PCBs) by capillary column gas chromatography. U.S. Environmental Protection Agency.
*EPA. 1995d. Method 4020. Screening for polychlorinated biphenyls by immunoassay. U.S. Environmental Protection Agency.
EPA. 1995e. U.S. Environmental Protection Agency. Designation, reportable quantities, and notification. List of hazardous substances and reportable quantities. Code of Federal Regulations. 40 CFR 302.4.
EPA. 1995f. U.S. Environmental Protection Agency. National primary drinking water regulations. Public notification. Polychlorinated biphenyls (PCBs). Code of Federal Regulations. 40 CFR 141.32.
*EPA. 1995g. EPA region 10 SOP for the validation of Method 1668 toxic, dioxin-like, PCB data. Seattle, WA: U.S. Environmental Protection Agency.
EPA. 1996a. U.S. Environmental Protection Agency. Disposal of polychlorinated biphenyls; import for disposal; Final rule. Federal Register. 61 FR 11096.
EPA. 1996b. National listing of fish and wildlife consumption advisories. U.S. Environmental Protection Agency, Office of Water. EPA-823-C-96-011.
*EPA. 1996c. PCBs: Cancer dose-response assessment and application to environmental mixtures. Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment, Office of Research and Development. EPA/600/P-96/001F.
*EPA. 1996d. Drinking water regulations and health advisories. Washington DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-B-96-002.
EPA. 1996e. U.S. Environmental Protection Agency. Proposed guidelines for carcinogen risk assessment; Notice. Federal Register 61(79):17960.
*EPA. 1996f. Quality assurance project plan, assessment of chemical contaminants in fish consumed by four Native American tribes in the Columbia River Basin, Revision 6.0. Seattle, WA: U.S. Environmental Protection Agency, Office of Environmental Assessment.
EPA. 1997a. U.S. Environmental Protection Agency. Land disposal restrictions. Treatment standards expressed as specified technologies. Code of Federal Regulations. 40 CFR 268.42.
EPA. 1997b. U.S. Environmental Protection Agency. Land disposal restrictions. Universal treatment standards. Code of Federal Regulations. 40 CFR 268.48.
*EPA. 1997c. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA/630/R-96/012.
*EPA. 1997d. Volume I - General Factors. Exposure Factors Handbook. Washington, DC: U.S. Environmental Protection Agency, National Center of Environmental Assessment, Office of Research and Development. EPA/600/P-95/002Fa.
*EPA. 1998a. U.S. Environmental Protection Agency. Disposal of polychlorinated biphenyls (PCBs); Final rule. Federal Register. 63 FR 35384-35474.
*EPA. 1998b. Update: Listing of fish and wildlife advisories. Fact Sheet. U.S. Environmental Protection Agency, Office of Water. EPA-823-F-98-009.
EPA. 1998c. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264 App IX.
*EPA. 1998d. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266 App V.
*EPA. 1998e. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48.
EPA. 1998f. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1998g. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.10.
*EPA. 1998h. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1998i. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32.
EPA. 1998j. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1998k. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50.
EPA. 1998l. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02.
EPA. 1998m. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 142.62.
EPA. 1998n. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.61.
EPA. 1998o. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
EPA. 1998p. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 52.679.
*EPA. 1998q. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 257.3-5.
*EPA. 1998r. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261 App VIII.
EPA. 1998s. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 129.4.
EPA. 1998t. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.8.
*EPA. 1998u. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 761.
*EPA. 1999a. National recommended water quality criteria- Correction. U.S. Environmental Protection Agency, Office of Water. EPA 822-Z-99-001.
*EPA. 1999b. PCB transformer registration database. http://www.epa.gov/opptintr/pcb/xform.htm
*EPA. 1999c. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264 App IX.
*EPA. 1999d. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1999e. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.32.
*EPA. 1999f. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.50.
*EPA. 1999g. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.61.
*EPA. 1999h. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
*EPA. 1999i. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1999j. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
*EPA. 1999k. Method 1668, Revision A: Chlorinated biphenyl congeners in water, soil, sediment, and tissue by HRGC/HRMS. U.S. Environmental Protection Agency, Office of Water. EPA-821-R-00-002.
*EPA. 1999l. Polychlorinated biphenyls (PCBs) update: Impact on fish advisories. U.S. Environmental Protection Agency, Office of Water. EPA-823-F-99-019.
*EPA. 2000. U.S. Environmental Protection Agency. Listing of fish and wildlife advisories: Advisory information. http://fish.rti.org.
*EPA-NIH. 1990. OHM-TADS (Oil and Hazardous Materials Technical Assistance Data System). Washington, DC: U.S. Environmental Protection Agency/National Institutes of Health.
*Epling GA, McVicar WM, Kumar A. 1988. Borohydride-enhanced photo dehalogenation of Aroclor 1232, 1242, 1254, and 1260. Chemosphere 17:1355–1362.
*Erickson MD. 1986. Analytical chemistry of PCBs. Boston, MA: Butterworth Publishers.
*Erickson MD. 1992. Analytical chemistry of PCBs. Boca Raton: Lewis Publishers.
*Eriksson P. 1988. Effects of 3,3’,4,4’-tetrachlorobiphenyl in the brain of the neonatal mouse. Toxicology 49:43–48.3131929
Eriksson P. 1996. Developmental neurotoxicology in the neonate--effects of pesticides and polychlorinated organic substances. Arch Toxicol Suppl 18:81–88.8678823
Eriksson P. 1997. Developmental neurotoxicity of environmental agents in the neonate. Neurotoxicology 18(3):719–726.9339819
*Eriksson P, Fredriksson A. 1996a. Developmental neurotoxicity of four ortho-substituted polychlorinated biphenyls in the neonatal mouse. Environ Toxicol Pharmacol 1(3):155–165.21781676
*Eriksson P, Fredriksson A. 1996b. Neonatal exposure to 2,2’,5,5’-tetrachlorobiphenyl causes increased susceptibility in the cholinergic transmitter system at adult age. Environ Toxicol Pharmacol 1(3):217–220.21781685
*Eriksson P, Fredriksson A. 1998. Neurotoxic effects in adult mice neonatally exposed to 3,3’4,4’5-pentachlorobiphenyl or 2,3,3’4,4’-pentachlorobiphenyl. Changes in brain nicotinic receptors and behaviour. Environ Toxicol Pharmacol 5(1):17–27.21781846
*Eriksson P, Lundkvist U, Fredricksson A. 1991. Neonatal exposure to 3,3’,4,4’-tetrachlorobiphenyl: changes in spontaneous behaviour and cholinergic muscarinic receptors in the adult mouse. Toxicology 69:27–34.1926153
*Evans TC, Kretzschmar RM, Hodges RE, . 1967. Radioiodine uptake studies of the human fetal thyroid. J Nucl Med 8:157–165.6024129
*Exon JH, Talcott PA, Koller LD. 1985. Effect of lead, polychlorinated biphenyls, and cyclophosphamide on rat natural killer cells, interleukin 2, and antibody synthesis. Fundam Appl Toxicol 5:158–164.3921421
*Expert Panel. 1994. Interoretive review of the potential adverse effects of chlorinated organic chemicals on human health and the environment. Regul Toxicol Pharmacol 20(1):S187–S307.
*Fait A, Grossman E, Self S, . 1989. Polychlorinated biphenyl congeners in adipose tissue lipid and serum of past and present transformer repair workers and a comparison group. Fundam Appl Toxicol 12:42–55.2494094
*Falandysz J. 1994. Polychlorinated biphenyl concentrations in cod-liver oil: Evidence of a steady-state condition of these compounds in the Baltic area oils and levels noted in Atlantic oils. Arch Environ Contam Toxicol 27:266–271.8060172
*Falck F, Ricci A, Wolff MS, . 1992. Pesticides and polychlorinated biphenyl residues in human breast lipids and their relation to breast cancer. Arch Environ Health 47(2):143–146.1567239
*Falconer RL, Bidleman TF. 1994. Vapor pressures and predicted particle/gas distributions of polychlorinated biphenyl congeners as functions of temperature and ortho-chlorine substitution. Atmos Environ 28(3):547–554.
*Falconer RL, Bidleman TF. 1995. Preferential sorption of non- and mono-ortho-polychlorinated biphenyls to urban aerosols. Environ Sci Technol 29:1666–1673.22276893
*Falk C, Hanrahan L, Anderson HA, . 1999. Body burden levels of dioxin, furans, and PCBs among frequent consumers of Great Lakes sport fish. Environ Res 80:S19–S25.10092416
*Faqi AS, Dalsenter PR, Mathar W, . 1998. Reproductive toxicity and tissue concentrations of 3,3’,4,4’-tetrachlorobiphenyl (PCB 77) in male adult rats. Hum Exp Toxicol 17(3):151–156.9587783
*Fava F, Di Gioia D, Marchetti L, . 1993. Aerobic mineralization of chlorobenzoates by a natural polychlorinated biphenyl-degrading mixed bacterial culture. Appl Microbiol Biotechnol 40(4):541–548.
FDA. 1992. Action levels for poisonous or deleterious substances in human food and animal feed. Washington, DC: U.S. Food and Drug Administration.
FDA. 1994. U.S. Food and Drug Administration. Tolerance for unavoidable contaminants poisonous or deleterious substances. Code of Federal Regulations. 21 CFR 509, Subpart B.
FDA. 1996a. U.S. Food and Drug Administration. Unavoidable contaminants in food for human consumption and food-packaging material. Code of Federal Regulations. 21 CFR 109.
*FDA. 1996b. Red meat adulterated with PCBs. Compliance Policy Guide. Section 565.200. Office of Regulatory Affairs, U.S. Food and Drug Administration.
*FDA. 1996c. Unavoidable contaminants in food for human consumption and food packaging material: Tolerances for polychlorinated biphenyls (PCBs). U.S. Food and Drug Administration. 21CFR109.30.
*FDA. 1998a. U. S. Food and Drug Administration. Use of polychlorinated biphenyls (PCB’s) in the production, handling, and storage of animal feed. Code of Federal Regulations. 21 CFR 500.45.
*FDA. 1998b. U. S. Food and Drug Administration. Use of polychlorinated biphenyls (PCB’s) in establishments manufacturing food-packaging materials. Code of Federal Regulations. 21 CFR 509.15.
*FDA. 1998c. U. S. Food and Drug Administration. Temporary tolerances for polychlorinated biphenyls (PCB’s). Code of Federal Regulations. 21 CFR 509.30.
*FDA. 1999a. U. S. Food and Drug Administration. Bottled water. Code of Federal Regulations. 21 CFR 165.110.
FDA. 1999b. U. S. Food and Drug Administration. Equipment and utensils. Code of Federal Regulations. 21 CFR 110.40.
FEDRIP. 1998. Federal Research In Progress. September 1998.
*FEDRIP. 2000. Federal Research In Progress.
*Feeley MM, Jordan SA. 1998. Dietary and tissue residue analysis and contaminant intake estimations in rats consuming diet composed of Great Lakes salmon: A multigeneration study. Regul Toxicol Pharmacol 27(1 Part 2):S8–S17.9618330
*Feeley MM, Jordan SA, Gilman AP. 1998. The Health Canada Great Lakes multigeneration study-summary and regulatory considerations. Regul Toxicol Pharmacol 27:S90–S98.9618337
*Fein GG, Jacobson JL, Jacobson SW, . 1984a. Intrauterine exposure of humans to PCBs: Newborn effects. U.S. Environmental Protection Agency, Duluth, MN. EPA 600/53-84-060. NTIS PB84-188-887.
*Fein GG, Jacobson JL, Jacobson SW, . 1984b. Prenatal exposure to polychlorinated biphenyls: Effects on birth size and gestational age. J Pediatr 105:315–320.6431068
*Felt GR, Mueller WF, Iatropoulos MJ, . 1977. Chronic toxicity of 2,4,5’-trichlorobiphenyl in young Rhesus monkeys: I. Body distribution, elimination, and metabolism. Toxicol Appl Pharmacol 41:619–627.411198
*Feltz HR. 1980. Significance of bottom material data in evaluation water quality. In: Contaminants and sediments. Vol 1. Fate and transport, case studies, modeling, toxicity. Ann Arbor, MI: Ann Arbor Science, 271–287.
Feng H, Cochran JK, Lwiza H, . 1998. Distribution of heavy metal and PCB contaminants in the sediments of an urban estuary: The Hudson River. Mar Environ Res 45(1):69–88.
*Fensterheim RJ. 1993. Documenting temporal trends of polychlorinated biphenyls in the environment. Regul Toxicol Pharmacol 18:181–201.8278640
Finklea J, Priester LE, Creason JP, . 1972. I. Polychlorinated biphenyl residues in human plasma expose a major urban pollution problem. Am J Public Health 62:645–651.4623477
Finley BL, Trowbridge KR, Burton S, . 1997. Preliminary assessment of PCB risks to human and ecological health in the lower Passaic River. J Toxicol Environ Health 52(2):95–118.9310144
*Fiore BJ, Anderson H, Hanrahan MS. 1989. Sport fish consumption and body burden levels of chlorinated hydrocarbons: A study of Wisconsin anglers. Arch Environ Health 44(2):82–88.2784657
*Fischbein A. 1985. Liver function tests in workers with occupational exposure to polychlorinated biphenyls (PCBs): Comparison with Yusho and Yu-Cheng. Environ Health Perspect 60:145–150.2863132
*Fischbein A, Wolff MS. 1987. Conjugal exposure to polychlorinated biphenyls (PCBs). Br J Ind Med 44(4):284–286.3105572
*Fischbein A, Rizzo JN, Solomon SJ, . 1985. Oculodermatological findings in workers with occupational exposure to polychlorinated biphenyls (PCBs). Br J Ind Med 42:426–430.3924093
*Fischbein A, Wolff MS, Bernstein J, . 1982. Dermatological findings in capacitor manufacturing workers exposed to dielectric fluids containing polychlorinated biphenyls (PCBs). Arch Environ Health 37:69–74.6462115
*Fischbein A, Wolff MS, Lilis R, . 1979. Clinical findings among PCB-exposed capacitor manufacturing workers. Ann NY Acad Sci 320:703–715.110206
*Fischer LJ, Seegal RF, Ganey PE, . 1998. Symposium overview: Toxicity of non-coplanar PCBs. Toxicol Sci 41(1):49–61.9520341
*Fish KM, Principe JM. 1994. Biotransformations of Aroclor 1242 in Hudson River test tube microcosms. Appl Environ Microbiol 60(12):4289–4296.7811068
*Fish KM, Mayes BA, Brown JFJ, . 1997. Biochemical measurements on hepatic tissues from SD rats fed Aroclors 1016, 1242, 1254, and 1250. Toxicologist 36(1):87.
*Fishbein L. 1974. Toxicity of chlorinated biphenyls. Ann Rev Pharmacol 14:139–156.
*Fitzgerald EF, Brix KA, Deres DA, . 1996. Polychlorinated biphenyl (PCB) and dichlorodiphenyl dichloroethylene (DDE) exposure among Native American men from contaminated Great Lakes fish and wildlife. Toxicol Ind Health 12(3–4):361–368.8843553
*Fitzgerald EF, Deres DA, Hwang SA, . 1999. Local fish consumption and serum PCB concentrations among Mohawk men at Akwesasne. Environ Res 80:S97–S103.10092423
Fitzgerald EF, Hwang S-A, Brix KA, . 1995. Fish PCB concentrations and consumption patterns among Mohawk women at Akwesasne. J Expo Anal Environ Epidemiol 5(1):1–19.7663146
*Fitzgerald EF, Hwang S-A, Bush B, . 1998. Fish consumption and breast milk PCB concentrations among Mohawk women at Akwesasne. Am J Epidemiol 148(2):164–172.9676698
*Fitzgerald EF, Standfast SJ, Youngblood LG, . 1986. Assessing the health effects of potential exposure to PCBs, dioxins, and furans from electrical transformer fires: The Binghamton state office building medical surveillance program. Arch Environ Health 41:368–376.3113345
*Fitzgerald EF, Weinstein AL, Youngblood LG, . 1989. Health effects three years after potential exposure to the toxic contaminants of an electrical transformer fire. Arch Environ Health 44:214–221.2506840
*Flanagan WP, May RJ. 1993. Metabolite detection as evidence for naturally occurring aerobic PCB biodegradation in Hudson River sediments. Environ Sci Technol 27(10):2207–2212.
*Foley RE. 1992. Organochlorine residues in New York waterfowl harvested by hunters in 1983-1984. Environ Monit Assess 21:37–48.24234343
*Foman SJ. 1966. Body composition of the infant. Part I: The male “reference infant”. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 239–246.
*Foman, SJ, Haschke F, Ziegler EE . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Foreman WT, Bidleman TF. 1987. An experimental system for investigating vapor-particle partitioning of trace organic pollutants. Environ Sci Technol 21:869–875.
*Fox ME, Khan RM, Thiessen PA. 1996. Loadings of PCBs and PAHs from Hamilton Harbour to Lake Ontario. Water Qual Res J Can 31(3):593–608.
*Frame G. 1997. Congener-specific PCB analysis. Anal Chem 69:468A–475A.
*Frame GM. 1999. Improved procedure for single DB-XLB column GC-MS-SIM quantitation of PCB congener distributions and characterization of two different preparations sold as “Aroclor 1254”. J High Resolut Chromatogr 22(10):533–540.
*Frame GM, Cochran JW, Bowadt SS. 1996. Complete PCB congener distributions for 17 Aroclor mixtures determined by 3 HRGC systems optimized for comprehensive, quantitative, congener-specific analysis. J High Resolut Chromotogr 19(12):657–668.
Frank R, Braun HE. 1990. Organochlorine residues in bird species collected dead in Ontario 1972-1988. Bull Environ Contam Toxicol 44:932–939.2112968
Frank R, Braun HE, Thorpe B. 1993. Comparison of DDE and PCB residues in the general diet and in human blood - Ontario 1986-87. Bull Environ Contam Toxicol 51(1):146–152.8318765
Frank R, Braun HE, Van Hove Holdrinet M, . 1982. Agriculture and water quality in the Canadian Great Lakes Basin: V. Pesticide use in 11 agricultural watersheds and presence in stream water, 1975-1977. J Environ Qual 11:497–505.
*Franklin MR, Phillips JD, Kushner JP. 1997. Cytochrome P450 induction, uroporphyrinogen decarboxylase depression, porphyin accumulation and excretion, and gender influence in a 3-week rat model of porphyria cutanea tarda. Toxicol Appl Pharmacol 147:289–299.9439724
*Franz TP, Eisenreich SJ. 1993. Wet deposition of polychlorinated biphenyls to Green Bay, Lake Michigan. Chemosphere 26(10):1767–1788.
*Franz TP, Eisenreich SJ. 1998. Snow scavenging of polychlorinated biphenyls and polycyclic aromatic hydrocarbons in Minnesota. Environ Sci Technol 32:1771–1778.
*Franz TP, Eisenreich SJ, Holsen TM. 1998. Dry deposition of particulate polychlorinated biphenyls and polycylic aromatic hydrocarbons to Lake Michigan. Environ Sci Technol 32:3681–3688.
*Freeman GB, Lordo RA, Singer AW, . 2000. An assessment of neurotoxicity of Aroclors 1016, 1242, 1254, and 1260 administered in diet to Sprague-Dawley rats for one year. Toxicol Sci 53:377–391.10696786
Freeman GB, Singer AW, Lordo RA, . 1998. An assessment of Aroclors 1016, 1242, 1254, and 1260 administered in diet to Sprague-Dawley rats for one year. (Submitted to Toxicol. Sci., July 1998)
*Fries GF, Marrow GS. 1984. Metabolism of chlorobiphenyls in soil. Bull Environ Contam Toxicol 33:6–12.6432078
*Froese KL, Verbrugge DA, Snyder SA, . 1997. PCBs in the Detroit River water column. J Great Lakes Res 23(4):440–449.
*Frumkin H, Orris P. 1999. Evidence of excess cancer mortality in a cohort of workers exposed to polychlorinated biphenyls. J Occup Environ Med 41(9):739–745.10491786
FSTRAC. 1990. Federal State Toxicology and Regulatory Alliance Committee. Summary of state and federal drinking water standards and guidelines. U.S. Environmental Protection Agency, Chemical Communication Subcommittee.
*FSTRAC. 1999. Federal-State Toxicology and Risk Analysis Committee. Arizona. U. S. Environmental Protection Agency, Office of Water. July 9, 1999. http://www.epa.gov/ostwater/fstrac/states.html
*Fu YA. 1984. Ocular manifestation of polychlorinated biphenyls intoxication. Am J Ind Med 5:127–132.6422743
*Funatsu I, Yamashita F, Yoshikane T, . 1971. A chlorobiphenyl induced fetopathy. Fukuoka Ishi 62(6):139–149.
*Fuoco R, Colombini MP, Samcova E. 1993. Individual determination of ortho and non-ortho substituted polychlorobiphenyls (PCBs) in sediments by high performance liquid chromatographic pre-separation and gas chromatography/ECD detection. Chromatographia 36:65–70.
*Furr AK, Lawrence AW, Tong SCS, . 1976. Multielement and chlorinated hydrocarbon analysis of municipal sewage sludges of American cities. Environ Sci Tech 10(7):683–687.
*Furst P, Furst C, Wilmers K. 1994. Human milk as a bioindicator for body burden of PCDDs, PCDFs, organochlorine pesticides, and PCBs. Environ Health Perspect Suppl 102(1):187–193.
*Furukawa K, Matsumura F. 1976. Microbial metabolism of polychlorinated biphenyls. Studies on the relative degradability of polychlorinated biphenyl components by alkaligenes sp. J Agric Food Chem 24(2):251–256.815303
*Furukawa K, Tonomura K, Kamibayashi A. 1978. Effect of chlorine substitution on the biodegradability of polychlorinated biphenyls. Appl Environ Microbiol 35:223–227.16345265
*Gage JC, Holm S. 1976. The influence of molecular structure on the retention and excretion of polychlorinated biphenyls by the mouse. Toxicol Appl Pharmacol 36:555–560.821179
*Gallenberg LA, Vodicnik MJ. 1987. Potential mechanisms for redistribution of polychlorinated biphenyls during pregnancy and lactation. Xenobiotica 17:299–310.3107224
Gammon MD, Wolff MS, Neugut AI, . 1996. Treatment for breast cancer and blood levels of chlorinated hydrocarbons. Cancer Epidemiol Biomarkers Prev 5(6):467–471.8781744
*Gan DR, Berthouex PM. 1994. Disappearance and crop uptake of PCBs from sludge-amended farmland. Water Environ Res 66(1):54–69.
*Ganey PE, Sirois JE, Denison M, . 1993. Neutrophil function after exposure to polychlorinated biphenyls in vitro. Environ Health Perspect 101:430–434.8119254
*Gans JG, Pintauro SJ. 1986. Liver scarring induced by polychlorinated biphenyl administration to mice previously treated with diethylnitrosamine. Proc Soc Exp Biol Med 183:207–213.3094019
*Gao X, Son D-S, Terranova PF, . 1999. Toxic equivalency factors of polychlorinated dibenzo-p-dioxins in an ovulation model: Validation of the toxic equivalency concept for one aspect of endocrine disruption. Toxicol Appl Pharmacol 157:107–116.10366543
*Gao X, Terranova PF, Rozman KK. 2000. Effects of polychlorinated dibenzofurans, biphenyls, and their mixture with dibenzo-p-dioxins on ovulation in the gonadotropin-primed immature rat: Support for the toxic equivalency concept. Toxicol Appl Pharmacol 163:115–124.10698669
*Gardner AM, Chen JT, Roach JAG, . 1973. Polychlorinated biphenyls: Hydroxylated urinary metabolites of 2,5,2’,5’-tetrachlorobiphenyl identified in rabbits. Biochem Biophys Res Commun 55:1377–1384.4358938
*Garner CE, Matthews HB. 1998. The effect of chlorine substitution on the dermal absorption of polychlorinated biphenyls. Toxicol Appl Pharmacol 149(2):150–158.9571983
*Garthoff H, Friedman L, Farber TM, . 1977. Biochemical and cytogenetic effects in rats caused by short-term ingestion of Aroclor 1254 or Firemaster BP6. J Toxicol Environ Health 3:769–796.201769
*Garthoff LH, Cerra FE, Marks EM. 1981. Blood chemistry alterations in rats after single and multiple gavage administration of polychlorinated biphenyl. Toxicol Appl Pharmacol 60:33–44.6792745
Gartner LW, Arias IM. 1966. Studies of prolonged neonatal jaundice in the breast-fed infant. J Pediatr 68:54–66.5901345
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985a. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1979 - September 1980. J Assoc Off Anal Chem 68:1184–1197.4086442
*Gartrell MJ, Craun JC, Podrebarac DS, . 1985b. Pesticides, selected elements, and other chemicals in adult total diet samples. October 1979 - September 1979. J Assoc Off Anal Chem 68:862–873.4055631
Gartrell MJ, Craun JC, Podrebarac DS, . 1985c. Pesticides, selected elements, and other chemicals in infant and toddler diet samples, October 1979 - September 1980. J Assoc Off Anal Chem 68:1163–1183.4086441
*Gartrell MJ, Craun JC, Podrebarac DS, . 1986a. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980 - March 1982. J Assoc Off Anal Chem 69:146–161.3949687
*Gartrell MJ, Craun JC, Podrebarac DS, . 1986b. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980 - March 1982. J Assoc Off Anal Chem 69:123–145.3949685
*Gebauer MB, Weseloh DV. 1993. Accumulation of organic contaminants in sentinel mallards utilizing confined disposal facilities at Hamilton Harbour, Lake Ontario, Canada. Arch Environ Contam Toxicol 25:234–243.
*Gellert RJ, Wilson C. 1979. Reproductive function in rats exposed prenatally to pesticides and polychlorinated biphenyls (PCB). Environ Res 18:437–443.92403
*General Electric Company. 1995a. An assessment of the chronic toxicity and oncogenicity of Aroclor-1016, Aroclor-1242, Aroclor-1254, and Aroclor-1260 administered in diet to rats. Volume I: Final neurotoxicity and neuropathology report. Environmental Research Center, General Electric Company. Battelle Study No. SC920192.
*General Electric Company. 1995b. An assessment of the chronic toxicity and oncogenicity of Aroclor-1016, Aroclor-1242, Aroclor-1254, and Aroclor-1260 administered in diet to rats. Volume II: Final neurotoxicity and neuropathology report. Environmental Research Center, General Electric Company. Battelle Study No. SC920192.
*General Electric Company. 1997a. An assessment of the chronic toxicity and oncogenicity of Aroclor-1016, Aroclor-1242, Aroclor-1254, and Aroclor-1260 administered in diet to rats. Volume I. Environmental Research Center, General Electric Company. Batelle Study No. SC920192.
*General Electric Company. 1997b. An assessment of the chronic toxicity and oncogenicity of Aroclor-1016, Aroclor-1242, Aroclor-1254, and Aroclor-1260 administered in diet to rats. Volume II. Environmental Research Center, General Electric Company. Batelle Study No. SC920192.
*Gerhard I, Daniel B, Link S, . 1998. Chlorinated hydrocarbons in women with repeated miscarriages. Environ Health Perspect 106:675–681.9755145
Gerstenberger SL, Gallina MP, Dellinger JA. 1997. Polychlorinated biphenyl congeners are selected organochlorines in Lake Superior fish, USA. Environ Toxicol Chem 16(11):2222–2228.
Geyer H, Scheunert I, Korte F. 1986. Bioconcentration potential of organic environmental chemicals in humans. Regul Toxicol Pharmacol 6:313–347.3101145
*Geyer HJ, Rimkus GG, . 1999. Bioaccumulation and occurrence of endocrine-disrupting chemicals (EDCs), persistent organic pollutants (POPs)… In: Hutzinger O, Beek B, eds. Handbook of environmental chemistry. Volume 2. Part J. Springer-Verlag.
*Giam CS, Chan HS, Neff GS, . 1978. Phthalate ester plasticizers: A new class of marine pollutant. Science 199:419–421.413194
*Gibson DT, Cruden DL, Haddock JD, . 1993. Oxidation of polychlorinated biphenyls by Pseudomonas sp. strain LB400 and Pseudomonas pseudoalcaligenes KF707. J Bacteriol 175(14):4561–4564.8331086
*Gierthy JF, Arcaro KF, Floyd M. 1997. Assessment of PCB estrogenicity in a human breast cancer cell line. Chemosphere 34(5–7):1495–1505.9134682
*Giesy JP, Kannan K. 1998. Dioxin-like and non-dioxin-like toxic effects of polychlorinated biphenyls (PCBs): Implications for risk assessment. Crit Rev Toxicol 28(6):511–569.9861526
*Giesy JP, Bowerman WW, Mora MA, . 1995. Contaminants of fishes from Great Lakes-influenced sections and above dams of three Michigan rivers: III. Implications for health of bald eagles. Arch Environ Contam Toxicol 29(3):309–321.7487154
*Giesy JP, Jude DJ, Tillitt DE, . 1997. Polychlorinated dibenzo-p-dioxins, dibenzofurans, biphenyls and 2,3,7,8-tetrachlorodibenzo-p-dioxin equivalents in fishes from Saginaw Bay, Michigan. Environ Toxicol Chem 16(4):713–724.
*Giesy JP, Jude DJ, Tillitt DE, . 1997. Polychlorinated dibenzo- p-dioxins, dibenzofurans, biphenyls and 2,3,7,8-tetrachlorodibenzo- p-dioxin equivalents in fishes from Saginaw Bay, Michigan. Environ Toxicol Chem 16(4):713–724.
Giesy JP, Ludwig JP, Tillit DE. 1994. Dioxins, dibenzofurans, PCBs and colonial, fish-eating water birds. In: Schecter A, ed. Dioxins and health. New York, NY: Plenum Press, 249–307.
*Gillan KA, Hasspieler BM, Russell RW, . 1998. Ecotoxicological studies in amphibian populations of southern Ontario. J Great Lakes Res 24(1):45–54.
Gillette JR. 1967. Individually different responses to drugs according to age, sex and functional or pathological state. In: Wolstenholme G, Porter R, eds. Drug responses in man. Boston, MA: Little, Brown & Company, 24–54.
*Gilroy C, Connell BJ, Singh A, . 1998. PCB congener 77-induced ultrastructural alterations in the rat liver: a quantitative study. Toxicology 127:179–185.9699804
*Gilroy C, Singh A, Chu I, . 1996. Toxicity of PCB 156 in the rat liver: an ultrastructural and biochemical study. J Submicrosc Cytol Pathol 28(1):27–32.8929624
*Girvin DC, Scott AJ. 1997. Polychlorinated biphenyl sorption by soils: Measurement of soil-water partition coefficients at equilibrium. Chemosphere 35(9):2007–2025.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101:65–71.
*Gladen BC, Rogan WJ. 1991. Effects of perinatal polychlorinated biphenyls and dichlorodiphenyl dichloroethene on later development. J Pediatr 119:58–63.1906100
*Gladen BC, Rogan WJ, Hardy P, . 1988. Development after exposure to polychlorinated biphenyls and dichlorodiphenyl dichloroethene transplacentally and through human milk. J Pediatr 113:991–995.3142988
*Gladen BC, Taylor JS, Wu Y-C, . 1990. Dermatological findings in children exposed transplacentally to heat-degraded polychlorinated biphenyls in Taiwan. Br J Dermatol 122:799–808.2142435
*GLWQB. 1985. Report to the International Joint Commision: Report on Great Lakes water quality. Kingston, Ontario: Great Lakes Water Quality Board.
*Goldey ES, Crofton KM. 1998. Thyroxine replacement attentuates hypothyroxinemia, hearing loss, and motor deficits following developmental exposure to Aroclor 1254 in rats. Toxicol Sci 45:94–105.9848116
*Goldey ES, Kehn LS, Lau C, . 1995. Development exposure to polychlorinated biphenyls (Aroclor 1254) reduces circulating thyroid hormone concentrations and causes hearing deficits in rats. Toxicol Appl Pharmacol 135:77–88.7482542
*Goldman PS, Rosvold HE, Vest B, . 1971. Analysis of the delayed-alternation deficit produced by dorsolateral prefrontal lesions in the Rhesus monkey. J Comp Physiol Psychol 77(2):212–220.5000659
Goldstein JA, Safe S. 1989. Mechanism of action and structure-activity relationships for the chlorinated dibenzo-p-dioxins and related compounds. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 239–293.
*Goldstein JA, Hickman P, Jue DL. 1974. Experimental hepatic porphyria induced by polychlorinated biphenyls. Toxicol Appl Pharmacol 27:437–448.4211999
*Golomb D, Ryan D, Underhill J, . 1997. Atmospheric deposition of toxics onto Massachusetts Bay -- II. Polycyclic aromatic hydrocarbons. Atmos Environ 31(9):1361–1368.
Golub MS, Donald JM, Reyes JA. 1991. Reproductive toxicity of commercial PCB mixtures: LOAELs and NOAELs from animal studies. Environ Health Perspect 94:245–253.1954934
*Goto M, Sugiura K, Hattori M, . 1974. Metabolism of 2,3,-dichlorobiphenyl-^14^C and 2,4,6-trichlorobiphenyl-^14^C in the rat. Chemosphere 5:227–232.
*Gould JC, Cooper KR, Scanes CG. 1997. Effects of polychlorinated biphenyl mixtures and three specific congeners on growth and circulating growth-related hormones. Gen Comp Endocrinol 106(2):221–30.9169118
*Grant DL, Phillips WEJ. 1974. The effect of age and sex on the toxicity of Aroclor® 1254, a polychlorinated biphenyl, in the rat. Bull Environ Contam Toxicol 12:145–152.4215511
Grant DL, Phillips WEJ, Villeneuve DC. 1971. Metabolism of a polychlorinated biphenyl (Aroclor® 1254) mixture in the rat. Bull Environ Contam Toxicol 6:102–112.5005159
*Gray K, Longnecker M, Klebanoff M, . 2000. In utero exposure to background levels of polychlorinated biphenyls and cognitive functioning among school-aged children. Am J Epidemiol 151(11):S24.
*Gray LE, Kelce WR, Monosson E, . 1995. Exposure to TCDD during development permanently alters reproductive function in male Long Evans rats and hamsters: Reduced ejaculated and epididymal sperm numbers and sex accessory gland weights in offspring with normal androgenic status. Toxicol Appl Pharmacol 131:108–118.7878665
Gray LE Jr. 1996. Comments on “developmental neurotoxicity of PCBs in humans: What do we know and where do we go from here”? Neurotoxicol Teratol 18(3):243–5; Discussion 271-6.8725633
Gray LE Jr. 1998. Chemical-induced alterations of sexual differentiation: a review of effects in humans and rodents. J Clean Technol Environ Toxicol Occup Med 7(2):121–145.
*Gray LE Jr, Ostby J, Marshall R, . 1993. Reproductive and thyroid effects of low-level polychlorinated biphenyl (Aroclor 1254) exposure. Fundam Appl Toxicol 20(3):288–294.8504902
*Green S, Carr JV, Palmer KA, . 1975a. Lack of cytogenetic effects in bone marrow and spermatogonial cells in rats treated with polychlorinated biphenyls (Aroclors 1242 and 1254). Bull Environ Contam Toxicol 13:14–22.805607
*Green S, Sauro FM, Friedman L. 1975b. Lack of dominant lethality in rats treated with polychlorinated biphenyls (Aroclors 1242 and 1254). Food Cosmet Toxicol 13:507–510.811517
*Gregor D, Teixeira C, Rowsell R. 1996. Deposition of atmospherically transported polychlorinated biphenyls in the Canadian Arctic. Chemosphere 33(2):227–244.
*Greizerstein HB, Gigliotti P, Vena J . 1997. Standardization of a method for the routine analysis of polychlorinated biphenyl congeners and selected pesticides in human serum and milk. J Analytical Toxicol 21:125–133.
*Greizerstein HB, Stinson C, Mendola P, . 1999. Comparison of PCB congeners and pesticide levels between serum and milk from lactating women. Environ Res 80:280–286.10092447
*Griffin RA, Chou SFJ. 1981. Movement of PCB’s and other persistent compounds through soil. Water Sci Technol 13:1153–1163.
*Gschwend PM, Wu S. 1985. On the constancy of sediment-water partition coefficients of hydrophobic organic pollutants. Environ Sci Technol 19(1):90–96.
*Grimvall E, Rylander L, Nilsson-Ehle P, . 1997. Monitoring of polychlorinated biphenyls in human blood plasma: Methodological developments and influence of age, lactation, and fish consumption. Arch Environ Contam Toxicol 32:329–336.9096084
*Grundy SL, Bright DA, Dushenko WT, . 1996. Weathering and dispersal of polychlorinated biphenyls from a known source in the Canadian Arctic. Environ Sci Technol 30(9):2661–2666.
*Guilbeault B, Sondossi M, Ahmad D, . 1994. Factors affecting the enhancement of PCB degradative ability of soil microbial populations. Int Biodeterior Biodegrad 33(1):73–91.
*Gunderson EL. 1988. FDA total diet study, April 1982-April 1984: Dietary intakes of pesticides, selected elements and other chemicals. J Assoc Off Anal Chem 71:1200–1209.3240978
*Gunderson EL. 1995. FDA total diet study, July 1986-April 1991: Dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 78:1353–1363.
*Gunkel G, Mast P-G, Nolte C. 1995. Pollution of aquatic ecosystems by polychlorinated biphenyls (PCB). Limnologica 25(3/4):321–331.
*Guo YL, Lai T-J, Chen S-J, . 1995. Gender-related decrease in Raven’s progressive matrices scores in children prenatally exposed to polychlorinated biphenyls and related contaminants. Bull Environ Contam Toxicol 55:8–13.7663094
*Guo YL, Lai TJ, Ju SH, . 1993. [No title available]. Dioxin ‘93 14:235.
*Guo YL, Ryan JJ, Lau BPY, . 1997. Blood serum levels of PCBs and PCDFs in Yucheng women 14 years after exposure to a toxic rice oil. Arch Environ Contam Toxicol 33:104–108.9216878
*Guo YL, Yu M-L, Hsu C-C, . 1999. Chloracne, goiter, arthritis, and anemia after polychlorinated biphenyl poisoning: 14-year follow-up of the Taiwan Yucheng cohort. Environ Health Perspect 107(9):715–719.10464071
*Guo YL, Yu M-L, Ryan JJ. 1996. Different congeners of PCBs/PCDFs may have contributed to different health outcomes in the Yucheng cohort. Neurotoxicol Teratol 18(3):255–256.8725636
*Gustavson K, Jonsson P. 1999. Some halogenated organic compounds in sediments and blue mussel (Mytilus edulis) in Nordic Seas. Mar Pollut Bull 38(8):723–736.
*Gustavsson P, Hogstedt C. 1997. A cohort study of Swedish capacitor manufacturing workers exposed to polychlorinated biphenyls (PCBs). Am J Ind Med 32(3):234–239.9219652
*Gustavsson P, Hogstedt C, Rappe C. 1986. Short-term mortality and cancer incidence in capacitor manufacturing workers exposed to polychlorinated biphenyls (PCBs). Am J Ind Med 10:341–344.3098097
*Gutenmann HW, Rutzke M, Kuntz HT, . 1994. Elements and polychlorinated biphenyls in sewage sludges of large cities in the United States. Chemosphere 28(4):725–728.
*Gutleb AC, Appelman J, Bronkhorst MC, . 1999. Delayed effects of pre- and early-life time exposure to polychlorinated biphenyls on tadpoles of two amphibian species (xenopus laevis and rana temporaria). Environ Toxicol Pharmacol 8:1–14.21781936
*Guttes S, Failing K, Neumann K, . 1998. Chlororganic pesticides and polychlorinated biphenyls in breast tissue of women with benign and malignant breast disease. Arch Environ Contam Toxicol 35:140–147.9601932
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haag-Gronlund M, Johansson N, Fransson-Steen R, . 1998. Interactive effects of three structurally different polychlorinated biphenyls in a rat liver tumor promotion bioassay. Toxicol Appl Pharmacol 152:153–165.9772211
Haag-Gronlund M, Warngard L, Flodstrom S, . 1997. Promotion of altered hepatic foci by 2,3’,4,4’,5-pentachlorobiphenyl in Sprague-Dawley female rats. Fundam Appl Toxicol 35(1):120–130.9024679
*Haake JM, Safe S, Mayura K, . 1987. Aroclor 1254 as an antagonist of the teratogenicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Lett 38:299–306.2821658
Haglund P, Asplund L, Jarnberg U, . 1990. Isolation of toxic polychlorinated biphenyls by electron donor-acceptor high-performance liquid chromatography on a 2-(1-pyrenyl)ethyldimethylsilylated silica column. J Chromatogr 507:389–398.2166062
*Hagmar L, Becher G, Heikkila A, . 1998. Consumption of fatty fish from the Baltic Sea and PCB in whole venous blood, plasma and cord blood from delivering women in the Aland/Turkey archipelago. J Toxicol Environ Health 53:581–591.
Hagmar L, Hallberg T, Leja M, . 1995. High consumption of fatty fish from the Baltic Sea is associated with changes in human lymphocyte levels. Toxicol Lett 77:335–342.7618159
Hakansson H, Manzoor E, Ahlborg UG. 1992. Effects of technical PCB preparations and fractions thereof on vitamin A levels in the mink (mustela vison). Ambio 21(8):588–590.
*Hall AJ, Duck CD, Law RJ, . 1999. Organochlorine contaminants in Caspian and harbour seal blubber. Environ Pollut 106:203–212.15093047
*Halsall CJ, Gevao B, Howsam M, . 1999. Temperature dependence of PCBs in the UK atmosphere. Atmos Environ 33:541–552.
*Haluska L, Barancikova G, Balaz S, . 1995. Degradation of PCB in different soils by inoculated alcaligenes xylosoxidans. Sci Total Environ 175(3):275–285.8578309
Hanneman WH, Legare ME, Tiffany-Castiglioni E, . 1996. The need for cellular, biochemical, and mechanistic studies. Neurotoxicol Teratol 18(3):247–250.8725634
*Hanrahan LP, Falk C, Anderson HA, . 1999. Serum PCB and DDE levels of frequent Great Lakes sport fish consumers-A first look. Environ Res 80:S26–S37.10092417
*Hansch C, Leo AJ. 1985. Medchem Project. Issue No. 26. Claremont, CA: Pomona College.
*Hansen H, De Rosa CT, Pohl H, . 1998. Public health challenges posed by chemical mixtures. Environ Health Perspect 106(Suppl. 6):1271–1280.9860881
*Hansen LG. 1979. Selective accumulation and depletion of polychlorinated biphenyl components: Food animal implications. Ann NY Acad Sci 320:238–246.110193
*Hansen LG. 1987a. Food chain modification of the composition and toxicity of polychlorinated biphenyl (PCB) residues. Rev Environ Toxicol 3:149–212.
*Hansen LG. 1987b. Environmental toxicology of polychlorinated biphenyls. In: Safe S, ed. Polychlorinated biphenyls (PCBs): Mammalian and environmental toxicology. Berlin, Germany: Springer-Verlag, 15–48.
*Hansen LG. 1998. Stepping backward to improve assessment of PCB congener toxicities. Environ Health Perspect Suppl 106(1):171–189.
*Hansen LG. 1999. The ortho side of PCBs: Occurrence and disposition. Boston, MA: Kluwer Academic Publishers.
*Hansen LG, O’Keefe PW. 1996. Polychlorinated dibenzofurans and dibenzo-p-dioxins in subsurface soil, superficial dust, and air extracts from a contaminated landfill. Arch Environ Contam Toxicol 31(2):271–276.8785012
*Hansen LG, Welborn ME. 1977. Distribution, dilution and elimination of polychlorinated biphenyl analogs in growing swine. J Pharm Sci 66:497–501.404418
*Hansen LG, Byerly CS, Metcalf RL, . 1975. Effect of a polychlorinated biphenyl mixture on swine reproduction and tissue residues. Am J Vet Res 36:23–26.803802
*Hansen LG, Green D, Cochran J, . Chlorobiphenyl (PCB) composition of extracts of subsurface soil, superficial dust and air from a contaminated landfill. F J Anal Chem 357:442–448.
*Hansen LG, Li MH, Saeed A, . 1995. Environmental polychlorinated biphenyls: Acute toxicity of landfill soil extract to female prepubertal rats. Arch Environ Contam Toxicol 29(3):334–343.7487157
*Hansen LG, Welborn ME, Borchard RE, . 1977. Tissue distribution of PCB components in swine and sheep fed three different rations containing Aroclors 1242 and 1254. Arch Environ Contam Toxicol 5:257–278.405931
*Hansen LG, Wilson DW, Byerly CS. 1976. Effects on growing swine and sheep of two polychlorinated biphenyls. Am J Vet Res 37:1021–1024.822761
Hany J, Lilienthal H, Roth-Harer A, . 1999a. Behavioral effects following single and combined maternal exposure to PCB 77 (3,4,3’,4’-tetrachlorobiphenyl) and PCB 47 (2,4,2’,4’-tetrachlorobiphenyl) in rats. Neurotoxicol Teratol 21(2):147–156.10192275
*Hany J, Lilienthal H, Sarasin A, . 1999b. Developmental exposure of rats to a reconstituted PCB mixture or Aroclor 1254: Effects on organ weights, aromatase activity, sex hormone levels, and sweet preference behavior. Toxicol Appl Pharmacol 158:231–243.10438656
*Haque R, Schmedding. 1976. Studies on the adsorption of selected polychlorinated biphenyl isomers on several surfaces. J Environ Sci Health B 11:129–137.818149
*Hara I. 1985. Health status and PCBs in blood of workers exposed to PCBs and of their children. Environ Health Perspect 59:85–90.3921370
*Haraguchi K, Athanasiadou M, Bergman A, . 1992. PCB and PCB methyl sulfones in selected groups of seals from Swedish waters. Ambio 21:546–549.
*Haraguchi K, Kato Y, Kimura R, . 1999a. Tissue distribution of methylsulfonyl metabolites derived from 2,2’,4,5,5’-penta- and 2,2’,3,4’,5’,6-hexachlorobiphenyls in rats. Arch Environ Contam Toxicol 37:135–142.10341051
*Haraguchi K, Koga N, Yoshimura H, . 1999b. Comparative metabolism of polychlorinated biphenyls (Kanechlor-500) in rats, hamsters and guinea pigs. Organohalogen Compounds 42:177–179.
*Haraguchi K, Kuroki H, Masuda Y. 1986. Capillary gas chromatographic analysis of methylsulphone metabolites of polychlorinated biphenyls retained in human tissues. J Chromatogr 361:239–252.3090081
*Hard HJ, Barnes C, Larsson G, . 1995. Solution structure of a mammalian PCB-binding protein in complex with a PCB. Nat Struct Biol 2:983–989.7583672
Hardell L, Lindstrom G, van Bavel B, . 1998. Some aspects of the etiology of non-Hodgkin’s lymphoma. Environ Health Perspect Suppl 106(2):679–681.
*Hardell L, Van Bavel B, Lindstrom G, . 1996. Higher concentrations of specific polychlorinated biphenyl congeners in adipose tissue from non-Hodgkin’s lymphoma patients compared with controls without a malignant disease. Int J Oncol 9(4):603–608.21541557
*Harding LE, Harris ML, Stephen CR, . 1999. Reproductive and morphological condition of wild mink (mustela vison) and river otters (lutra canadensis) in relation to chlorinated hydrocarbon contamination. Environ Health Perspect 107(2):141–147.9924010
*Harkness MR, McDermott JB, Abramowicz A, . 1993. In situ stimulation of aerobic PCB biodegradation in Hudson River sediments. Science 259:503–507.8424172
*Harner T, Kylin H, Bidleman TF, . 1998. Polychlorinated naphthalenes and coplanar polychlorinated biphenyls in Arctic air. Environ Sci Technol 32:3257–3265.
*Harner T, Mackay D, Jones KC. 1995. Model of the long-term exchange of PCBs between soil and the atmosphere in the southern UK. Environ Sci Technol 29(5):1200–1209.22192012
*Harper N, Connor K, Safe S. 1993a. Immunotoxic potencies of polychlorinated biphenyl (PCB), dibenzofuran (PCDF) and dibenzo-p-dioxin (PCDD) congeners in C57BL/6 and DBA/2 mice. Toxicology 80:217–227.8328002
*Harper N, Connor K, Steinberg M, . 1995. Immunosuppressive activity of polychlorinated biphenyl mixtures and congeners: Nonadditive (antagonistic) interactions. Fundam Appl Toxicol 27:131–139.7589923
*Harper N, Howie L, Connor K, . 1993b. Immunosupressive effects of highly chlorinated biphenyls and diphenyl ethers on T-cell dependent and independent antigens in mice. Toxicology 85:123–135.8303708
*Harrad SJ, Sewart AS, Boumphrey R, . 1992. A method for the determination of PCB congeners 77, 126 and 169 in biotic and abiotic matrices. Chemosphere 24(8):1147–1154.
Harris M, Zacharewski T, Safe S. 1993. Comparative potencies of Aroclors 1232, 1242, 1248, 1254, and 1260 in male Wistar rats--assessment of the toxic equivalency factor (TEF) approach for polychlorinated biphenyls (PCBs). Fundam Appl Toxicol 20(4):456–463.8314461
*Hart KM, Tremp J, Molinar E, . 1993. The occurrence and the fate of organic pollutants in the atmosphere. Water Air Soil Pollut 68(1–2):91–112.
*Hartkamp-Commandeur LCM, Gerritse J, Govers HAJ, . 1996. Reductive dehalogenation of polychlorinated biphenyls by anaerobic microorganisms enriched from Dutch sediments. Chemosphere 32(7):1275–1286.
*Hashimoto K, Akasaka S, Takagi Y, . 1976. Distribution and excretion of [^14^C]polychlorinated biphenyls after their prolonged administration to male rats. Toxicol Appl Pharmacol 37:415–423.973219
*Hassett JP, Milicic E, Jota MAT. 1984. Equilibrium and kinetic studies of binding of a PCB compound by dissolved organic matter. Am Chem Soc Abstr Pap :ENVR 86.
*Hassoun E, d’Argy R, Dencker L, . 1984. Teratogenicity of 2,3,7,8-tetrachlorodibenzofuran in BXD recombinant inbred strains. Toxicol Lett 23:37–42.6485016
*Hatton RE. 1979. Chlorinated biphenyls and related compounds. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology, Vol. 5. New York, NY: John Wiley and Sons, 844–848.
*Hattula ML. 1985. Mutagenicity of PCBs and their pyrosynthetic derivatives in cell-mediated assay. Environ Health Perspect 60:255–257.3928351
*Haugen J-E, Wania F, Lei YD. 1999. Polychlorinated biphenyls in the atmosphere of southern Norway. Environ Sci Technol 33:2340–2345.
*Hayes MA. 1987. Carcinogenic and mutagenic effects of PCBs. In: Safe S, Hytzinger O, eds. Environmental toxin series. Vol 1: Polychlorinated biphenyls (PCBs: Mammalian and environmental toxicology). Heidelberg: Springer-Verlag, 77–95.
*HazDat. 1998. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*HazDat. 2000. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Heaton SN, Bursian SJ, Giesy JP, . 1995a. Dietary exposure of mink to carp from Saginaw Bay, Michigan. 1. Effects on reproduction and survival, and the potential risks to wild mink populations. Arch Environ Contam Toxicol 28:334–343.7726645
*Heaton SN, Bursian SJ, Giesy JP, . 1995b. Dietary exposure of mink to carp from Saginaw Bay, Michigan: 2. Hematology and liver pathology. Arch Environ Contam Toxicol 29:411–417.7487160
*Hebert CE, Gamberg M, Elkin BT, . 1996. Polychlorinated dibenzodioxins, dibenzofurans and non-ortho substituted polychlorinated biphenyls in caribou (rangifer tarandus) from the Canadian Arctic. Sci Total Environ 183(3):195–204.
*Hebert CE, Gloosehenko V, Haffner GD, . 1993. Organic contaminants in snapping turtle (chelydra serpentiana) populations from southern Ontario, Canada. Arch Environ Contam Toxicol 24:35–43.
*Hebert CE, Shutt JL, Norstrom RJ. 1997. Dietary changes cause temporal fluctuations in polychlorinated biphenyl levels in herring gull eggs from Lake Ontario. Environ Sci Technol 31(4):1012–1017.
*Hebert CE, Weseloh DV, Kot L, . 1994. Organochlorine contaminants in a terrestrial foodweb on the Niagara Peninsula, Ontario, Canada 1987- 89. Arch Environ Contam Toxicol 26:356–366.
*Heddle JA, Bruce WR. 1977. Comparison of tests for mutagenicity or carcinogenicity using assays for sperm abnormalities, formation of micronuclei and mutations in salmonella. In: Hiatt HH, ., eds. Cold Spring Harbor conference on cell proliferation: Volume 4: Origins of human cancer. Cold Spring Harbor, NY: Cold Spring Harbor Lab, 1549–1557.
Heinrich-Hirsch B, Beck H, Chahoud I, . 1997. Tissue distribution, toxicokinetics and induction of hepatic drug metabolizing enzymes in male rats after a single s.c. dose of 3,4,3’,4’-tetrachlorobiphenyl (PCB-77). Chemosphere 34(5–7):1523–1534.9134684
*Heit M, Klusek C, Baron J. 1984. Evidence of deposition of anthropogenic pollutants in remote Rocky Mountain lakes. Water Air Soil Pollut 22:403–416.
*Helzlsouer KJ, Alberg AJ, Huang H-Y, . 1999. Serum concentrations of organochlorine compounds and the subsequent development of breast cancer. Cancer Epidemiol Biomarkers Prev 8:525–532.10385143
*Hemming H, Bager Y, Flodstrom S, . 1995. Liver tumour promoting activity of 3,4,5,3’,4’-pentachlorobiphenyl and its interaction with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Eur J Pharmacol 292:241–249.7796862
*Hemming H, Flodstrom S, Fransson-Steen R, . 1992. Inhibition of intercellular communication in cells in culture by polychlorinated compounds. Chemosphere 25(7–10):939–945.
*Hemming H, Flodstrom S, Warngard L, . 1993. Relative tumour promoting activity of three polychlorinated biphenyls in rat liver. Eur J Pharmacol 248(2):163–174.7901043
*Hennig B, Slim R, Toborek M, . 1999. PCB-mediated endothelial cell dysfunction: Implications in atherosclerosis. Organohalogen Compounds 42:505–508.
Henning MH, Ebert ES, Keenan RE, . 1997. Assessment of effects of PCB-contaminated floodplain soils on reproductive success of insectivorous songbirds. Chemosphere 34(5–7):1121–1137.
*Hermanson MH, Hites RA. 1989. Long-term measurements of atmospheric polychlorinated biphenyls in the vicinity of Superfund dumps. Environ Sci Technol 23:1253–1258.
*Herr DW, Goldey ES, Crofton KM. 1996. Developmental exposure to Aroclor 1254 produces lowfrequency alterations in adult rat brainstem auditory evoked responses. Fundam Appl Toxicol 33:120–128.8812251
*Hess P, de Boer J, Cofino WP, . 1995. Critical review of the analysis of non- and mono-ortho-chlorobiphenyls. J Chromatogr 703:417–465.
*Hesso A, Hameila M, Tornaeus J, . 1992. Polychlorinated dioxins, furans and non-ortho polychlorinated biphenyls in blood of exposed laboratory personnel. Chemosphere 25(7–10):1053–1059.
*Hickey WJ, Searles DB, Focht DD. 1993. Enhanced mineralization of polychlorinated biphenyls in soil inoculated with chlorobenzoate-degrading bacteria. Appl Environ Microbiol 59(4):1194–1200.8476293
*Hicks HE. 1996. The Great Lakes: A historical overview. Toxicol Ind Health 12(2/3):303–313.8843548
*Higson FK. 1992. Microbial degradation of biphenyl and its derivatives. Adv Appl Microbiol 37:135–164.1642156
*Hilbert G, Lillemark L, Balchen S, . 1998. Reduction of organochlorine contaminants from fish oil during refining. Chemosphere 37(7):1241–1252.9734319
*Hill RH Jr. 1985. Effects of polyhalogenated aromatic compounds on porphyrin metabolism. Environ Health Perspect 60:139–143.4029097
*Hillery BR, Basu I, Sweet CW, . 1997. Temporal and spatial trends in a long-term study of gas-phase PCB concentrations near the Great Lakes. Environ Sci Technol 31(6):1811–1816.
*Hippelein M, McLachlan MS. 1998. Soil/air partitioning of semivolatile organic compounds. 1. Method development and influence of physical-chemical properties. Environ Sci Technol 32:310–316.
*Hippelein M, Kaupp H, Door G, . 1993. Testing of a sampling system and analytical method for determination of semivolatile organic compounds in ambient air. Chemosphere 26(12):2255–2263.
*Hirose M, Shirai T, Tsuda H, . 1981. Effect of phenobarbital, polychlorinated biphenyl and sodium saccharin on hepatic and renal carcinogenesis in unilaterally nephrectomized rats given N-ethyl-N-hydroxyethylnitrosamine orally. Carcinogenesis 2:1299–1302.6799217
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J. Nat Cancer Inst 84:313–320.1738181
*Hofelt CS, Shea D. 1997. Accumulation of organochlorine pesticides and PCBs by semipermeable membrane devices and mytilus edulis in New Bedford harbor. Environ Sci Technol 31(1):154–159.
*Hoff RM, Muir DCG, Grist NP. 1992. Annual cycle of polychlorinated biphenyls and organohalogen pesticides in air in Southern Ontario. 1: Air contamination data. Environ Sci Technol 26:266–275.
*Hoff RM, Strachan WMJ, Sweet CW, . 1996. Atmospheric deposition of toxic chemicals to the Great Lakes: A review of data through 1994. Atmos Environ 30(20):3505–3527.
Hoffman DJ, Rice CP, Kubiak TJ. 1996. PCBs and dioxins in birds. In: Beyer WE, Heinz GH, Redmon-Norwood AW, eds. Environmental contaminants in wildlife: Interpreting tissue concentrations. Boca Raton, FL: CRC Press, 165–207.
*Holene E, Nafstad I, Skaare JU, . 1995. Behavioral effects of pre- and postnatal exposure to individual polychlorinated biphenyl congeners in rats. Environ Toxicol Chem 14(6):967–976.
*Holene E, Nafstad I, Skaare JU, . 1998. Behavioral hyperactivity in rats following postnatal exposure to sub-toxic doses of polychlorinated biphenyl congeners 153 and 126. Behav Brain Res 94:213–224.9708851
*Holene E, Nafstad I, Skaare JU, . 1999. Behavioural effects in female rats of postnatal exposure to sub-toxic doses of polychlorinated biphenyl congener 153. Acta Paediatr Scand Suppl 429:55–63.
Hollander D. 1997. Environmental effects on reproductive health: The endocrine disruption hypothesis. Fam Plann Perspect 29(2):82–6, 89.9099572
*Hollifield HC. 1979. Rapid nephelometric estimate of water solubility of highly insoluble organic chemicals of environmental interest. Bull Environ Contam Toxicol 23:579–586.497467
*Holsbeek L, Joiris CR, Debacker V, . 1999. Heavy metals, organochlorines and polycyclic aromatic hydrocarbons in sperm whales stranded in the southern North Sea during the 1994/1995 winter. Mar Pollut Bull 38(4):304–313.
*Holsen TM, Noll KE. 1992. Dry deposition of atmospheric particles: Application of current models to ambient data. Environ Sci Technol 26:1807–1815.
*Holsen TM, Noll KE, Lu S, . 1991. Dry deposition of polychlorinated biphenyls in urban areas. Environ Sci Technol 25:1075–1078.
*Holson RR, Pearce B. 1992. Principles and pitfalls in the analysis of prenatal treatment effects in multiparous species. Neurotoxicol Teratol 14:221–228.1635542
*Hong C-S, Bush B, Xiao J. 1992a. Isolation and determination of mono-ortho and non-ortho substituted PCBs (coplanar PCBs) in human milk by HPLC porous graphitic carbon and GC-ECD. Chemosphere 24(4):465–473.
*Hong C-S, Bush B, Xiao J. 1992b. Coplanar PCBs in fish and mussels from marine and estuarine waters of New York State. Ecotoxicol Environ Saf 23(1):118–131.1375144
*Hong C-S, Calambokidis J, Bush B, . 1996. Polychlorinated biphenyls and organochlorine pesticides and harbor seal pups from the inland waters of Washington State. Environ Sci Technol 30(3):837–844.
*Hong CS, Wang Y, Bush B. 1998. Kinetics and products of the TiO_2_ photocatalytic degradation of 2-chlorobiphenyl in water. Chemosphere 36(7):1653–1667.9503582
Hong CS, Xiao J, Casey AC, . 1994. Mono-ortho- and non-ortho substituted polychlorinated biphenyls in human milk from Mohawk and control women: Effects of maternal factors and previous lactation. Arch Environ Contam Toxicol 27:431–437.7944559
Honrath RE, Sweet CI, Plouff CJ. 1997. Surface exchange and transport processes governing atmospheric PCB levels over Lake Superior. Environ Sci Technol 31(3):842–852.
*Hood A, Hashmi R, Klaassen CD. 1999. Effects of microsomal enzyme inducers on thyroid-follicular cell proliferation, hyperplasia, and hypertrophy. Toxicol Appl Pharmacol 160:163–170.10527915
*Hoopingarner R, Samuel A, Krause D. 1972. Polychlorinated biphenyl interactions with tissue culture cells. Environ Health Perspect 1:155–158.17539075
*Hori M, Kondo H, Ariyoshi N, . 1997. Species-specific alteration of hepatic glucose 6-phosphate dehydrogenase activity with coplanar polychlorinated biphenyl: Evidence for an Ah-receptor-linked mechanism. Chemosphere 35(5):951–958.9297786
*Hornbuckle KC, Achman DR, Eisenreich SJ. 1993. Over-water and over-land polychlorinated biphenyls in Green Bay, Lake Michigan. Environ Sci Technol 27:87–98.
*Hornshaw TC, Safronoff J, Ringer RK, . 1986. LC_50_ test results in polychlorinated biphenyl-fed mink: Age, season, and diet comparisons. Arch Environ Contam Toxicol 15:717–723.3098191
*Hornung MW, Miller L, Goodman B, . 1998. Lack of developmental and reproductive toxicity of 2,3,3’,4,4’-pentachlorobiphenyl (PCB 105) in ring-necked pheasants. Arch Environ Contam Toxicol 35:646–653.9776783
Hornykiewicz O. 1973. Parkinson’s disease: from brain homogenate to treatment. Fed Proc 32:183–190.4143953
*Horzempa LM, Di Toro DM. 1983. The extent of reversibility of polychlorinated biphenyl adsorption. Water Res 17(8):851–859.
Houghton DL, Ritter L. 1995. Organochlorine residues and risk of breast cancer. J Am Coll Toxicol 14(2):71–89.
*Hovinga ME, Sowers M, Humphrey HEB. 1992. Historical changes in serum PCB and DDT levels in an environmentally-exposed cohort. Arch Environ Contam Toxicol 22(4):362–366.1489385
*Hovinga ME, Sowers M, Humphrey HEB. 1993. Environmental exposure and lifestyle predictors of lead, cadmium, PCB, and DDT levels in Great Lakes fish eaters. Arch Environ Health 48(2):98–104.8476311
*Høyer AP, Grandjean P, Jorgensen T, . 1998. Organochlorine exposure and risk of breast cancer. Lancet 352:1816–1820.9851382
*HSDB. 1995. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program (via TOXNET), Bethesda, MD. January 1995.
*HSDB. 2000. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program, Bethesda, MD. July 2000.
*Hsieh S-F, Yen Y-Y, Lan S-J, . 1996. A cohort study on mortality and exposure to polychlorinated biphenyls. Arch Environ Health 51(6):417–424.9012319
*Hsu C-C, Yu M-LM, Chen Y-CJ, . 1994. The Yu-Cheng rice oil poisoning incident. In: Schecter A, ed. Dioxins and health. New York, NY: Plenum Press, 661–684.
*Hsu ST, Ma CI, Hsu SKH, . 1985. Discovery and epidemiology of PCB poisoning in Taiwan: A four-year followup. Environ Health Perspect 59:5–10.3921364
*Hu K, Bunce NJ. 1999. Metabolism of polychlorinated dibenzo- p-dioxins and related dioxin-like compounds. J Toxicol Environ Health 2:183–210.
*Huang A, Lin S, Inglis R, . 1998b. Pre- and postnatal exposure to 3,3’,4,4’-tetrachlorobiphenyl: II. effects on the reproductive capacity and fertilizing ability of eggs in female mice. Arch Environ Contam Toxicol 34(2):209–214.9469864
*Huang A, Powell D, Chou K. 1998a. Pre- and postnatal exposure to 3,3’,4,4’-tetrachlorobiphenyl: I. effects on breeding ability and sperm fertilizing ability in male mice. Arch Environ Contam Toxicol 34(2):204–208.9469863
*Huang IW, Hong CS, Bush B. 1996. Photocatalytic degradation of PCBs in TiO_2_ aqueous suspensions. Chemosphere 32(9):1869–1881.8680826
*Huang S, Gibson GG. 1992. Species and congener specific induction of hepatic cytochrome P4504A by polychlorinated biphenyls. Biochem Pharmacol 43:637–639.1540218
*Huang Y-W, Karasov WH, Patnode KA, . 1999. Exposure of northern leopard frogs in the Green Bay ecosystem to polychlorinated biphenyls, polychlorinated dibenzo-p-dioxins, and polychlorinated dibenzofurans is measured by direct chemistry but not hepatic ethoxyresorufin-O-deethylase activity. Environ Toxicol Chem 18(10):2123–2130.29857620
*Huckins JN, Schwartz TR, Petty JD. 1988. Determination, fate, and potential significance of PCBs in fish and sediment samples with emphasis of selected AHH-inducing congeners. Chemosphere 17:1995–2016.
*Huestis SY, Servos MR, Whittle DM, . 1996. Temporal and age-related trends in levels of polychlorinated biphenyl congeners and organochlorine contaminants in Lake Ontario lake trout (salvelinus namaycush). J Great Lakes Res 22(2):310–330.
*Hughes MF, Shrivastava SP, Sumler MR, . 1992. Dermal absorption of chemicals: Effect of application of chemicals as a solid, aqueous paste, suspension, or in volatile vehicle. J Toxicol Environ Health. 37:57–71.1522614
*Huisman M, Koopman-Esseboom C, Fidler V, . 1995a. Perinatal exposure to polychlorinated biphenyls and dioxins and its effect on neonatal neurological development. Early Hum Dev 41:111–127.7601016
*Huisman M, Koopman-Esseboom C, Lanting CI, . 1995b. Neurological condition in 18-month-old children perinatally exposed to polychlorinated biphenyls and dioxins. Early Hum Dev 43:165–176.8903761
*Humphrey HEB. 1983. Population studies of PCBs in Michigan residents. In: D’Itri FM, Kamrin MA, eds. PCBs: Human and environmental hazards. Boston, MA: Butterworth, 299–310.
*Humphrey HEB. 1988. Chemical contaminants in the Great Lakes: The human health aspect. In: Evans MS, ed. Toxic contaminants and ecosystem health: A Great Lakes focus. New York, NY: John Wiley and Sons, 153–165.
*Humphrey HEB, Budd ML. 1996. Michigan’s fisheater cohorts: A prospective history of exposure. Toxicol Ind Health 12(3–4):499–505.8843566
*Humphrey HEB, Gardiner JC, Pandya JR, . 2000. PCB congener profile in the serum of humans consuming Great Lakes fish. Environ Health Perspect 108(2):167–172.10656858
*Hunter DJ, Hankinson SE, Laden F, . 1997. Plasma organochlorine levels and the risk of breast cancer [see comments]. N Engl J Med 337(18):1253–1257.9345073
Huntley SL, Iannuzzi TJ, Avantaggio JD, . 1997. Combined sewer overflow (CSOs) as sources of sediment contamination in the lower Passaic River, New Jersey. II. Polychlorinated dibenzo-p-dioxins, polychlorinated dibenzofurans, and polychlorinated biphenyls. Chemosphere 34(2):233–250.
*Hurme TS, Puhakka JA. 1997. Polychlorinated biphenyl biotransformations by aerobic and anaerobic boreal lake sediment microorganisms. In: Alleman BC, Leeson A, eds. In situ and on-site bioremediation: Volume 2. Columbus, OH: Battelle Press, 427–432.
*Hutton JJ, Meier J, Hackney C. 1979. Comparison of the in vitro mutagenicity and metabolism of dimethylnitrosamine and benzo[a]pyrene in tissues from inbred mice treated with phenobarbital, 3-methylcholanthrene or polychlorinated biphenyls. Mutat Res 66:75–94.106274
Hutzinger O, Safe S, Zitko V. 1972. Photochemical degradation of chlorobiphenyls (PCBs). Environ Health Perspect 1:15–20.17539073
*Hutzinger O, Safe S, Zitko V, eds. 1974. The chemistry of PCBs. Boca Raton, FL: CRC Press.
*Iannuzzi TJ, Huntley SL, Bonnevie NL, . 1995. Distribution and possible sources of polychlorinated biphenyls in dated sediments from the Newark Bay Estuary, New Jersey. Arch Environ Contam Toxicol 28:108–117.
Iannuzzi TJ, Huntley SL, Schmidt CW, . 1997. Combined sewer overflows (CSOs) as sources of sediment contamination in the lower Passaic River, New Jersey. I. Priority pollutants and inorganic chemicals. Chemosphere 34(2):213–231.
*IARC. 1978. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Volume 18: Polychlorinated biphenyls and polybrominated biphenyls. World Health Organization, Lyon, France.
IARC. 1982. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Supplement 4: Chemicals, industrial processes and industries associated with cancer in humans: IARC monographs, volumes 1 to 29. World Health Organization, Lyon, France.
*IARC. 1987. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Supplement 7: Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. World Health Organization, Lyon, France.
*Iatropoulus MJ, Bailey J, Adams HP, . 1978. Response of nursing infant Rhesus to Clophen A-30 or hexachlorobenzene given to their lactating mothers. Environ Res 16:38–47.98325
*Imamura M, Tung TC. 1984. A trial of fasting: cure for PCB poisoned patients in Taiwan. Am J Ind Med 5:147–153.6422746
*Imanishi J, Nomura H, Matsubara M, . 1980. Effect of polychlorinated biphenyl on viral infections in mice. Infect Immun 29(1):275–277.6156912
*IRIS. 1999a. Integrated Risk Information System. Aroclor 1254. U.S. Environmental Protection Agency. http://www.epa.goc/ngispgm3/iris/subst/0289.htm
*IRIS. 1999b. Integrated Risk Information System. Aroclor 1016. U.S. Environmental Protection Agency. http://www.epa.goc/ngispgm3/iris/subst/0462.htm
*IRIS. 1999c. Integrated Risk Information System. Polychlorinated biphenyls (PCBs). U.S. Environmental Protection Agency. http://www.epa.goc/ngispgm3/iris/subst/0294.htm
*IRIS. 1999d. Integrated Risk Information System. Aroclor 1248. U.S. Environmental Protection Agency. http://www.epa.goc/ngispgm3/iris/subst/0649.htm
*IRIS. 2000. Integrated Risk Information System. Polychlorinated biphenyls (PCBs). U.S. Environmental Protection Agency. http://www.epa.goc/ngispgm3/iris/subst/0294.htm
*IRPTC. 1985. Treatment and disposal methods for waste chemicals. IRPTC FILE. International Registry of Potentially Toxic Chemicals, United Nations Environment Programme, Geneva, Switzerland, 20, 262–264.
*Irvine KN, Loganathan BG. 1998. Localized enrichment of PCB levels in street dust due to redistribution by wind. Water Air Soil Pollut 105:603–615.
*Ito N, Nagasaki H, Arai M, . 1973. Histopathologic studies on liver tumorigenesis in mice by technical polychlorinated biphenyls and its promoting effect on liver tumors induced by benzene hexachloride. J Natl Cancer Inst 51:1637–1646.4128486
Ito N, Nagasaki H, Makiura S, . 1974. Histopathologic studies on liver tumorigenesis in rats treated with polychlorinated biphenyls. Gann 65(6):545–549.4219193
*Iwata Y, Gunther FA, Westlake WE. 1974. Uptake of a PCB (Aroclor 1254) from soil by carrots under field conditions. Bull Environ Contam Toxicol 11(6):523–528.4215507
*Iwata Y, Westlake WE, Gunther FA. 1973. Varying persistence of polychlorinated biphenyls in six California soils under laboratory conditions. Bull Environ Contam Toxicol 9:204–211.4205357
*Jackson JA, Diliberto JJ, Birnbaum LS. 1993. Estimation of octanol-water partition coefficients and correlation with dermal absorption for several polyhalogenated aromatic hydrocarbons. Fundam Appl Toxicol 21:334–344.8258387
*Jacobs LW, O’Connor GA, Overcash MA, . 1987. Effects of trace organics in sewage sludges on soil-plant systems and assessing their risk to humans. In: Land application of sludge. Food chain implications. Lewis Publishers, Inc., 103–143.
*Jacobs MN, Santillo D, Johnston PA, . 1998. Organochlorine residues in fish oil dietary supplements: Comparison with industrial grade oils. Chemosphere 37(9–12):1709–1721.9828299
*Jacobson JL. 1985. Human exposure to PCBs--congeners and developmental effect. Crisp Data Base National Institutes of Health.
*Jacobson JL, Jacobson SW. 1996a. Intellectual impairment in children exposed to polychlorinated biphenyls in utero. N Engl J Med 335(11):783–789.8703183
*Jacobson JL, Jacobson SW. 1996b. Sources and implications of interstudy and interindividual variability in the developmental neurotoxicity of PCBs. Neurotoxicol Teratol 18(3):257–264, 271–6.8725637
*Jacobson JL, Jacobson SW. 1997. Evidence for PCBs as neurodevelopmental toxicants in humans. Neurotoxicology 18(2):415–424.9291491
*Jacobson JL, Fein GG, Jacobson SW, . 1984b. The transfer of polychlorinated biphenyls (PCBs) and polybrominated biphenyls (PBBs) across the human placenta and into maternal milk. Am J Public Health 74:378–379.6322600
*Jacobson JL, Jacobson SW, Humphrey HEB. 1990a. Effects of in utero exposure to polychlorinated biphenyls and related contaminants on cognitive functioning in young children. J Pediatr 116:38–45.2104928
*Jacobson JL, Jacobson SW, Humphrey HEB. 1990b. Effects of exposure to PCBs and related compounds on growth and activity in children. Neurotoxicol Teratol 12:319–326.2118230
*Jacobson JL, Jacobson SW, Padgett RJ, . 1992. Effects of prenatal PCB exposure on cognitive processing efficiency and sustained attention. Dev Psychol 28(2):297–306.
*Jacobson JL, Jacobson SW, Schwartz PM, . 1984a. Prenatal exposure to an environmental toxin: A test of the multiple effects model. Dev Psychol 20:523–532.
*Jacobson SW, Fein GG, Jacobson JL, . 1985. The effect of intrauterine PCB exposure on visual recognition memory. Child Dev 56:853–860.3930167
Jaffe R, Stemmler EA, Eitzer BD, . 1985. Anthropogenic, polyhalogenated, organic compounds in sedentary fish from Lake Huron and Lake Superior tributaries and embayments. J Great Lakes Res 11:156–162.
*James RC, Busch H, Tamburro CH, . 1993. Polychlorinated biphenyl exposure and human disease. J Occup Med 35:136–148.8433185
*Jan J, Tratnik M. 1988. Polychlorinated biphenyls in residents around the river Krupa, Slovenia, Yugoslavia. Bull Environ Contam Toxicol 41:809–814.3148344
*Jansen HT, Cooke PS, Porcelli J, . 1993. Estrogenic and antiestrogenic actions of PCBs in the female rat: in vitro and in vivo studies. Reprod Toxicol 7(3):237–248.8318755
*Jarman WM, Burns SA, Bacon CE, . 1996. High levels of HCB and DDE associated with reproductive failure in prairie falcons (Falco mexicanus) from California. Bull Environ Contam Toxicol 57:8–15.8661453
*Jarman WM, Johnson GW, Bacon CE, . 1997. Levels and patterns of polychlorinated biphenyls in water collected from the San Francisco Bay and estuary, 1993-95. Fresenius J Anal Chem 359(3):254–260.
*Jelinek CF, Corneliussen PE. 1976. Levels of PCB’s in the U.S. food supply. In: Proceedings of the National Conference on Polychlorinated Biphenyls, Chicago, 1975. Washington, DC: U.S. Environmental Protection Agency, 147–154. EPA-560/6-75-004.
Jensen AA. 1983. Chemical contaminants in human milk. Res Rev 89:1–94.
*Jensen AA. 1987. Polychlorobiphenyls (PCBs), polychlorodibenzo-p-dioxins (PCDDs) and polychlorodibenzofurans (PCDFs) in human milk, blood and adipose tissue. Sci Total Environ 64:259–293.3110947
*Jensen AA. 1989. Background levels in humans. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 345–380.
Jensen RG, Clark RM, Ferris AM. 1980. Composition of the lipids in human milk: A review. Lipids 15:345–355.6993828
*Jensen S, Sundström G. 1974. Structures and levels of most chlorobiphenyls in two technical PCB products and in human adipose tissue. Ambio 3:70–76.
*Jensen S, Jansson B, Olsson M. 1979. Number and identity of anthropogenic substances known to be present in Baltic seals and their possible effects on reproduction. Ann NY Acad Sci 320:436–448.110197
*Jeremiason JD, Eisenreich SJ, Baker JE, . 1998. PCB decline in settling particles and benthic recycling of PCBs and PAHs in Lake Superior. Environ Sci Technol 32:3249–3256.
*Jeremiason JD, Hornbuckle KC, Eisenreich SJ. 1994. PCBs in Lake Superior, 1978-1992: Decreases in water concentrations reflect loss by volatilization. Environ Sci Technol 28(5):903–914.22191833
*Johansen HR, Becher G, Polder A, . 1994. Congener-specific determination of polychlorinated biphenyls and organochlorine pesticides in human milk from Norwegian mothers living in Oslo. J Toxicol Environ Health 42(2):157–171.8207752
*Johanson CE. 1980. Permeability and vascularity of the developing brain: cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansson M, Nilsson S, Lund B-O. 1998. Interactions between methylsulfonyl PCBs and the glucocorticoid receptor. Environ Health Perspect 106(12):769–772.9831536
*Johansson N, Haag-Gronlund M, Fransson-Steen R, . 1999. Interactive effects of different polychlorinated biphenyls in rat. In:Organohalogen Compounds 42:229–233.
*Johnson BL, DeRosa CT. 1999. Conclusion: Public health implications. Environ Res A80:S246–S248.
*Johnson BL, Hicks HE, Cibulas W, . 2000. Public health implications of exposure to polychlorinated biphenyls (PCBs). http://www.astdr.cdc.gov/DT/pcb007.html
*Johnson BL, Hicks HE, De Rosa CT. 1999. Key environmental human health issues in the Great Lakes and St. Lawrence River basins. Environ Res 80:S2–S12.10092414
*Johnson BL, Hicks HE, Jones DE, . 1998. Public health implications of persistent toxic substances in the Great Lakes and St. Lawrence basins. J Great Lakes Res 24(2):698–722.
*Johnson KL, Cummings AM, Birnbaum LS. 1997. Promotion of endometriosis in mice by polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls. Environ Health Perspect 105(7):750–755.9294722
Johnstone RM, Court GS, Fesser AC, . 1996. Long-term trends and sources of organochlorine contamination in Canadian Tundra peregrine falcons, falco peregrinus tundrius. Environ Pollut 93(2):109–120.15091349
*Jones CJ, Backlin BM, Stoddart RW, . 1997. Environmental pollutants as aetiological agents in female reproductive pathology: Placental glycan expression in normal and polychlorinated biphenyl (PCB) - exposed mink (mustela vison). Placenta 18(8):689–699.9364605
*Jones DH, Lewis DH, Eurell TE, . 1979. Alteration of the immune response of channel catfish (ictalurus punctatus) by polychlorinated biphenyls. In: Symposium on pathobiology of environmental pollutants: Animal models and wildlife as monitors. Washington, DC: National Academy of Sciences, 385–386.
Jones KC. 1988. Determination of polychlorinated biphenyls in human foodstuffs and tissues: Suggestions for a selective congener analytical approach. Sci Total Environ 68:141–159.3129782
*Jones KC, Duarte-Davidson R. 1997. Transfers of airborne PCDD/Fs to bulk deposition collectors and herbage. Environ Sci Technol 31:2937–2943.
*Jones KC, Sanders G, Wild SR, . 1992. Evidence for a decline of PCBs and PAHs in rural vegetation and air in the United Kingdom. Nature 356:137–140.
*Juarez de Ku LM, Sharma-Stokkermans M, Meserve LA. 1994. Thyroxine normalizes polychlorinated biphenyl (PCB) dose-related depression of choline acetyltransferase (ChAT) activity in hippocampus and basal forebrain of 15-day-old rats. Toxicology 94:19–30.7801322
Kaiser C, Lorenz W, Bahadir M. 1993. Residues in recycled goods from shredded plastics. II. Communication. Fresenius Environ Bull 2(7):363–369.
*Kakela R, Kakela A, Hyvarinen H, . 1999. Vitamins A_1_, A_2_, and E in minks exposed to polychlorinated biphenyls (Aroclor 1242) and copper, via diet based on freshwater or marine fish. Environ Toxicol Chem 18(11):2595–2599.
*Kalina I, Sram RJ, Konecna H, . 1991. Cytogenetic analysis of peripheral blood lymphocytes in workers occupationally exposed to polychlorinated biphenyls. Teratog Carcinog Mutagen 11:77–82.1686676
*Kamei M, Ohgaki S, Kanbe T, . 1996. Highly hydrogenated dietary soybean oil modifies the responses to polychlorinated biphenyls in rats. Lipids 31(11):1151–1156.8934447
*Kaminsky LS, Kennedy MW, Adams SM, . 1981. Metabolism of dichlorobiphenyls by highly purified isozymes of rat liver cytochrome P-450. Biochemistry 20:7379–7384.6798990
*Kamrin MA, Ringer RK. 1994. PCB residues in mammals: A review. Toxicol Environ Chem 41:63–84.
*KAN-DO Office and Pesticides Team. 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready-to-eat foods. J AOAC Int 78(3):614–631.7756874
*Kannan K, Tanabe S, Borrell A, . 1993. Isomer-specific analysis and toxic evaluation of polychlorinated biphenyls in striped dolphins affected by an epizootic in the western Mediterranean Sea. Arch Environ Contam Toxicol 25:227–233.8368865
*Kannan K, Tanabe S, Giesy JP, . 1997. Organochlorine pesticides and polychlorinated biphenyls in foodstuffs from Asian and oceanic countries. Rev Environ Contam Toxicol 152:1–55.9297984
*Kannan K, Yamashita N, Imagawa T, . 2000. Polychlorinated naphthalenes and polychlorinated biphenyls in fishes from Michigan waters including the Great Lakes. Environ Sci Technol 34:566–572.
*Karickhoff SW. 1981. Semi-empirical estimation of sorption of hydrophobic pollutants on natural sediments and soils. Chemosphere 10:833–846.
Kashimoto T, Miyata H. 1986. Differences between Yusho and other kinds of poisoning involving only PCBs. In: Waid JS, ed. PCBs and the environment, Vol. III. Boca Raton: CRC Press, 2–26.
*Kasza L, Collins WT, Capen CC, . 1978. Comparative toxicity of polychlorinated biphenyl and polybrominated biphenyl in the rat thyroid gland: Light and electron microscopic alterations after subacute dietary exposure. J Environ Pathol Toxicol 1:587–599.214505
*Kato N, Yoshida A. 1980. Effect of dietary PCB on hepatic cholesterogenesis in rats. Nutr Rep Int 21:107–112.
*Kato N, Kawai K, Yoshida A. 1981a. Effect of dietary level of ascorbic acid on the growth, hepatic lipid peroxidation, and serum lipids in guinea pigs fed polychlorinated biphenyls. J Nutr 111:1727–1733.6793700
*Kato N, Kawai K, Yoshida A. 1982b. Effects of dietary polychlorinated biphenyls and protein level on liver and serum lipid metabolism of rats. Agric Biol Chem 46:703–707.
*Kato N, Mochizuki S, Kawai K, . 1982a. Effect of dietary level of sulfur-containing amino acids on liver drug-metabolizing enzymes, serum cholesterol and urinary ascorbic acid in rats fed PCB. J Nutr 112:848–854.6804611
*Kato N, Tani T, Yoshida A. 1981b. Effect of dietary quality of protein on liver microsomal mixed function oxidase system, plasma cholesterol and urinary ascorbic acid in rats fed PCB. J Nutr 111:123–133.6778977
*Kato S, McKinney JD, Matthews HB. 1980. Metabolism of symmetrical hexachlorobiphenyl isomers in the rat. Toxicol Appl Pharmacol 53:389–398.6770495
*Kato Y, Haraguchi K, Kawashima M, . 1995. Induction of hepatic microsomal drug-metabolizing enzymes by methylsulphonyl metabolites of polychlorinated biphenyl congeners in rats. Chem Biol Interact 95:257–268.7728896
*Kearney JP, Cole DC, Ferron LA, . 1999. Blood PCB, p,p-DDE, and mirex levels in Great Lakes fish and waterfowl consumers in two Ontario communities. Environ Res 80(A):S138–S149.10092427
*Kelly AG, Cruz I, Wells DE. 1993. Polychlorobiphenyls and persistent organochlorine pesticides in sea water at the pg l^1^ level. Sampling apparatus and analytical methodology. Anal Chim Acta 276(1):3–13.
*Kennish MJ, Ruppel BE. 1996. Polychlorinated biphenyl contamination in selected estuarine and coastal marine finfish and shellfish of New Jersey. Estuaries 19(2A):288–295.
*Kester MHA, Bulduk S, Tibboel D, . 2000. Potent inhibition of estrogen sulfotransferase by hydroxylated PCB metabolites: A novel pathway explaining the estrogenic activity of PCBs. Endocrinology 141(5):1897–1900.10803601
*Kholkute SD, Rodriguez J, Dukelow WR. 1994a. Effects of polychlorinated biphenyls (PCBs) on in vitro fertilization in the mouse. Reprod Toxicol 8:69–73.8186627
Kholkute SD, Rodriguez J, Dukelow WR. 1994b. Reproductive toxicity of Aroclor-1254: Effects on oocyte, spermatozoa, in vitro fertilization, and embryo development in the mouse. Reprod Toxicol 8:487–493.7881200
Kidwell JM, Phillips LJ, Birchard GF. 1995. Comparative analyses of contaminant levels in bottom feeding and predatory fish using the National Contaminant Biomonitoring Program data. Bull Environ Contam Toxicol 54:919–923.7647509
Kihlstrom JE, Lundberg C, Orberg J, . 1975. Sexual functions of mice neonatally exposed to DDT or PCB. Environ Physiol Biochem 5:54–57.806450
*Kihlstrom JE, Olsson M, Jensen SJ, . 1992. Effects of PCB and different fractions of PCB on the reproduction of the mink (mustela vison). Ambio 21(8):563–569.
Kilburn KH, Warshaw RH, Hanscom B. 1994. Balance measured by head (and trunk) tracking and a force platform in chemically (PCB and TCE) exposed and referent subjects. Occup Environ Med 51(6):381–385.8044229
Kim NK, Stone DW. 1980. Organic chemicals and drinking water. New York State Department of Health, Albany, NY, 101.
*Kimbrough RD. 1987. Human health effect of polychlorinated biphenyls (PCBs) and polybrominated biphenyls (PBBs). Ann Rev Pharmacol Toxicol 27:87–111.3034142
*Kimbrough RD. 1995. Polychlorinated biphenyls (PCBs) and human health: An update. Crit Rev Toxicol 25:133–166.7612174
*Kimbrough RD, Linder RE. 1974. Induction of adenofibrosis and hepatomas in the liver of Balb/cJ mice by polychlorinated biphenyls (Aroclor 1254). J Natl Cancer Inst 53:547–552.4367249
*Kimbrough RD, Doemland ML, LeVois ME. 1999a. Mortality in male and female capacitor workers exposed to polychlorinated biphenyls. J Occup Environ Med 41(3):161–171.10091139
*Kimbrough RD, Doemland ML, LeVois ME. 1999b. Author’s reply to letter to the editor re: “Evidence of excess cancer mortality in a cohort of workers exposed to polychlorinated biphenyls”. J Occup Environ Med 41(9):739–745.10491786
*Kimbrough RD, Linder RE, Gaines TB. 1972. Morphological changes in livers of rats fed polychlorinated biphenyls: Light microscopy and ultrastructure. Arch Environ Health 25:354–364.4346789
*Kimbrough RD, Squire RA, Linder RE, . 1975. Induction of liver tumors in Sherman strain female rats by polychlorinated biphenyl Aroclor 1260. J Natl Cancer Inst 55:1453–1459.173869
*Kimura NT, Kanematsu T, Baba T. 1976. Polychlorinated biphenyl(s) as a promotor in experimental hepatocarcinogenesis in rats. Z Krebsforsch 87:257–266.
King TL, Haines BK, Uthe JF. 1996. Non-, mono-, and di-o-chlorobiphenyl concentrations and their toxic equivalents to 2,3,7,8-tetrachlorodibenzo(p)dioxin in Aroclors and digestive glands from American lobster (homarus americanus) captured in Atlantic Canada. Bull Environ Contam Toxicol 57:465–472.8672074
*Kiviranta H, Purkunen R, Vartiainen T. 1999. Levels and trends of PCDD/Fs and PCBs in human milk in Finland. Chemosphere 38(2):311–323.10901657
*Klasson KT, Barton JW, Evans BS, . 1996. Reductive microbial dechlorination of indigenous polychlorinated biphenyls in soil using a sediment-free inoculum. Biotechnology Progress 12:310–315.8652118
*Klasson-Wehler E, Bergman A, Brandt I, . 1989a. 3,3’,4,4’-Tetrachlorobiphenyl: Excretion and tissue retention of hydroxylated metabolites in the mouse. Drug Metab Dispos 17:441–448.2571487
*Klasson-Wehler E, Bergman A, Kowalski B, . 1987. Metabolism of 2,3,4’,6-tetrachlorobiphenyl: Formation and tissue localization of mercapturic acid pathway metabolites in mice. Xenobiotica 17:477–486.3111106
*Klasson-Wehler E, Jonsson J, Bergman A, . 1989b. 3,3’,4,4’-tetrachlorobiphenyl and 3,3’,4,4’,5-pentachlorobiphenyl-tissue-localization and metabolic fate in the mouse. Chemosphere 19:809–812.
*Klasson-Wehler E, Lindberg L, Jonsson CJ, . 1993. Tissue retention and metabolism of 2,3,4,3’,4’-pentachlorobiphenyl in mink and mouse. Chemosphere 27:2397–2412.
*Kleinert SJ. 1976. Sources of polychlorinated biphenyls in Wisconsin. In: Proceedings of the National Conference on Polychlorinated Biphenyls, Chicago, 1975. Washington, DC: U.S. Environmental Protection Agency, 124–126. EPA-560/6-75-004.
Kling D, Gamble W. 1980. In vivo inhibition of citrate cleavage enzyme by polychlorinated biphenyls. Experientia 37:1258–1259.
*Kling D, Gamble W. 1982. Cholesterol biosynthesis in polychlorinated biphenyl-treated rats. Environ Res 27:10–15.6802634
*Kling D, Kunkle J, Roller AS, . 1978. Polychlorinated biphenyls: In vivo and in vitro modifications of cholesterol and fatty acid biosynthesis. J Environ Pathol Toxicol 1:813–828.32219
*Kluwe WM, Herrmann CL, Hook JB. 1979. Effects of dietary polychlorinated biphenyls and polybrominated biphenyls on the renal and hepatic toxicities of several chlorinated hydrocarbon solvents in mice. J Toxicol Environ Health 5:605–615.226724
*Knap AH, Binkley KS. 1991. Chlorinated organic compounds in the troposphere over the western North Atlantic Ocean measured by aircraft. Atmos Environ 25A:1507–1516.
*Kocan A, Petrik J, Chovancova J, . 1994. Method for the group separation of non-ortho-, mono-ortho and multi-ortho-substituted polychlorinated biphenyls and polychlorinated dibenzo-p-dioxins/polychlorinated dibenzofurans using activated carbon chromatography. J Chromatogr 665:139–153.
*Kodavanti PR, Tilson HA. 1997. Structure-activity relationships of potentially neurotoxic PCB congeners in the rat. Neurotoxicology 18(2):425–441.9291492
*Kodavanti PRS, Derr-Yellin EC, Mundy WR, . 1998. Repeated exposure of adult rats to Aroclor 1254 causes brain region-specific changes in intracellular Ca2+ buffering and protein kinase C activity in the absence of changes in tyrosine hydroxylase. Toxicol Appl Pharmacol 153:186–198.9878590
*Kodavanti PRS, Shin D-S, Tilson HA, . 1993. Comparative effects of two polychlorinated biphenyl congeners on calcium homeostasis in rat cerebellar granule cells. Toxicol Appl Pharmacol 123:97–106.8236268
*Kodavanti PRS, Ward TR, McKinney JD, . 1995. Increased [^3^H]phorbol ester binding in rat cerebellar granule cells by polychlorinated biphenyl mixtures and congeners: Structure-activity relationships. Toxicol Appl Pharmacol 130:140–148.7839361
*Kodavanti PRS, Ward TR, McKinney JD, . 1996a. Increased [^3^H]phorbol ester binding in rat cerebellar granule cells and inhibition of ^45^Ca^2+^ sequestration in rat cerebellum by polychlorinated diphenyl ether congeners and analogs: Structure-activity relationships. Toxicol Appl Pharmacol 138:251–261.8658526
*Kodavanti PRS, Ward TR, McKinney JD, . 1996b. Inhibition of microsomal and mitochondrial Ca^2+^-sequestration in rat cerebellum by polychlorinated biphenyl mixtures and congeners: Structure-activity relationships. Arch Toxicol 70:150–157.8825671
*Koester CJ, Hites RA. 1992. Photodegredation of polychlorinated dioxins and dibenzofurans adsorbed to fly ash. Environ Sci Technol 26:502–507.
*Koga N, Beppu M, Ishida C, . 1989. Further studies on metabolism in vivo of 3,4,3’,4’-tetrachlorobiphenyl in rats: identification of minor metabolites in rat feces. Xenobiotica 19:1307–1318.2515663
Koga N, Beppu M, Yoshimura H. 1990. Metabolism in vivo of 3,4,5,3’,4’-pentachlorobiphenyl and toxicological assessment of the metabolite in rats. J Pharmacobiodyn 13:497–506.2132573
*Koga N, Shin’yama A, Ishida C, . 1992. A new metabolite of 2,4,3’,4’-tetrachlorobiphenyl in rat feces. Chem Pharm Bull 40(12):3338–3339.
Koga Y, Tsuda M, Ariyoshi N, . 1994. Induction of bilirubin UDP-glucuronyltransferase and CYP4A1 P450 by co-planar PCBs: Different responsiveness of guinea pigs and rats. Chemosphere 28:639–645.
*Kohl SD, Rice JA. 1998. The binding of contaminants to humin: a mass balance. Chemosphere 36(2):251–261.
Kokoszka L, Flood J. 1985. A guide to EPA-approved PCB disposal methods. Chem Eng 92:41–43.
*Koller LD. 1977. Enhanced polychlorinated biphenyl lesions in Moloney leukemia virus-infected mice. Clin Toxicol 11:107–116.406114
*Komori M, Nishio K, Kitada M . 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Kono TK, Yamana Y. 1979. [Ocular symptoms of oil disease patients (report 4): Investigation 10 years after onset.] Fukuoka Igaku Zasshi 70:181–186. (Japanese)113314
*Koopman-Esseboom C, Huisman M, Weisglas-Kuperus N, . 1994b. PCB and dioxin levels in plasma and human milk of 418 Dutch women and their infants. Predictive value of PCB congener levels in maternal plasma for fetal and infant’s exposure to PCBs and dioxins. Chemosphere 28(9):1721–1732.
*Koopman-Esseboom C, Morse DC, Weisglas-Kuperus N, . 1994a. Effects of dioxins and polychlorinated biphenyls on thyroid hormone status of pregnant women and their infants. Pediatr Res 36(4):468–473.7816522
*Koopman-Esseboom C, Weisglas-Kuperus N, de Ridder MAJ, . 1996. Effects of polychlorinated biphenyl/dioxin exposure and feeding type on infants’ mental and psychomotor development. Pediatrics 97:700–706.8628610
*Korach KS, Sarver P, Chae K, . 1988. Estrogen receptor-binding activity of polychlorinated hydroxybiphenyls: Conformationally restricted structural probes. Mol Pharmacol 33:120–126.3122017
*Korrick SA, Altshul L. 1998. High breast milk levels of polychlorinated biphenyls (PCBs) among four women living adjacent to a PCB-contaminated waste site. Environ Health Perspect 106(8):513–518.9681980
*Koslowski SE, Metcalfe CD, Lazar R, . 1994. The distribution of 42 PCBs, including three coplanar congeners, in the food web of the western basin of Lake Erie. J Great Lakes Res 20(1):260–270.
Kosson DS, Dienemann EA, Ahlert RC. 1985. Characterization and treatability studies of an industrial landfill leachate (Kin-buc I). Proceedings of the Industrial Waste Conference 39:329–341.
*Kostyniak PJ, Stinson C, Greizerstein HB, . 1999. Relation of Lake Ontario fish consumption, lifetime lactation, and parity to breast milk polychlorobiphenyl and pesticide concentrations. Environ Res 80:S166–S174.10092430
Kovacevic R, Vojinovic-Miloradov M, Teodorovic I, . 1995. Effect of PCBs on androgen production by suspension of adult rat leydig cells in vitro. J Steroid Biochem Mol Biol 52(6):595–597.7779764
*Kramer VJ, Helferich WG, Bergman A, . 1997. Hydroxylated polychlorinated biphenyl metabolites are anti-estrogenic in a stably transfected human breast adenocarcinoma (MCF7) cell line. Toxicol Appl Pharmacol 144:363–374.9194421
*Kraul I, Karlog O. 1976. Persistent organochlorinated compounds in human organs collected in Denmark 1972-73. Acta Pharmacol Toxicol 38:38–48.
*Krauthacker B, Reiner E, Votava-Raic A, . 1998. Organochlorine pesticides and PCBs in human milk collected from mothers nursing hospitalized children. Chemosphere 37(1):27–32.9637005
*Kreiss K. 1985. Studies on populations exposed to polychlorinated biphenyls. Environ Health Perspect 60:193–199.3928345
*Kreiss K, Roberts C, Humphrey HEB. 1982. Serial PBB levels, PCB levels, and clinical chemistries in Michigan’s PBB cohort. Arch Environ Health 37:141–147.6284069
*Kreiss K, Zack MM, Kimbrough RD, . 1981. Association of blood pressure and polychlorinated biphenyl levels. J Am Med Assoc 245:2505–2509.
*Krieger N, Wolff MS, Hiatt RA, . 1994. Breast cancer and serum organochlorines: a prospective study among white, black, and Asian women. J Natl Cancer Inst 86(8):589–599.8145274
*Kremer H, Lilienthal H, Hany J, . 1999. Sex-dependent effects of maternal PCB exposure on the electroretinogram in adult rats. Neurotoxicol Teratol 21(1):13–19.10023797
*Krishnan K, Andersen M. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd edition. New York, NY: Raven Press, Ltd, 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang R, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
*Krishnan V, Safe S. 1993. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), and dibenzofurans (PCDFs) as antiestrogens in MCF-7 human breast cancer cells: Quantitative structure-activity relationships. Toxicol Appl Pharmacol 120(1):55–61.7685553
Krutovskikh VA, Mesnil M, Mazzoleni G, . 1995. Inhibition of rat liver gap junction intercellular communication by tumor-promoting agents in vivo: Association with aberrant localization of connexin proteins. Lab Invest 72:571–577.7745951
*Kucklick JR, Baker JE. 1998. Organochlorines in Lake Superior’s food web. Environ Sci Technol 32:1192–1198.
*Kuehl DW, Haebler R. 1995. Organochlorine, organobromine, metal and selenium residues in bottlenose dolphins (tursiops truncatus) collected during an unusual mortality event in the Gulf of Mexico, 1990. Arch Environ Contam Toxicol 28:494–499.7755403
*Kuehl DW, Butterworth B, Marquis PJ. 1994. A national study of chemical residues in fish. III: Study results. Chemosphere 29(3):523–535.
*Kuhnlein HV, Receveur O, Muir CDG, . 1995. Arctic indigenous women consume greater than acceptable levels of organochlorines. J Nutr 125:2501–2510.7562084
*Kuiper J, Hanstveit AO. 1988. Biodegradation rates of xenobiotic compounds in plankton communities. In: Capuzzo JM, Kester DR, eds. Oceanic processes in marine pollution. Volume 1. Malabar, FL: Robert E. Krieger Publishing Company, 79–88.
*Kuipers B, Cullen WR, Mohn WM. 1999. Reductive dechlorination of nonachlorobiphenyls and selected octachlorobiphenyls by microbial enrichment cultures. Environ Sci Technol 33:3579–3585.
*Kunita N, Hori S, Obana H, . 1985. Biological effects of PCBs, PCQs and PCDFs present in the oil causing Yusho and Yu-Cheng. Environ Health Perspect 59:79–84.3921369
*Kuo C-E, Liu S-M, Liu C. 1999. Biodegradation of coplanar polychlorinated biphenyls by anaerobic microorganisms from estuarine sediments. Chemosphere 39(9):1445–1458.10481246
*Kurachi M, Mio T. 1983a. On fluctuation of PCBs under various unnatural conditions in mice. Agric Biol Chem 47:1173–1181.
*Kurachi M, Mio T. 1983b. On the formation of a conjugate of PCBs with glutathione and its further metabolism in mice or rats. Agric Biol Chem 47:1193–1199.
*Kuratsune M. 1989. Yusho, with reference to Yu-Cheng. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 381–400.
Kuratsune M, Shapiro R. 1984. PCB poisoning in Japan and Taiwan. Am J Ind Med 5:1–153.
*Kuratsune M, Nakamura Y, Ikeda M, . 1987. Analysis of deaths seen among patients with Yusho-A preliminary report. Chemosphere 16:2085–2088.
*Kuroiwa Y, Murai Y, Santa T. 1969. [Neurological and nerve conduction velocity studies on 23 patients with chlorobiphenyl poisoning.] Fukuoka Igaku Zasshi 60:462–463. (Japanese)
*Kurokawa Y, Matsueda T, Nakamura M, . 1996. Characterization of non-ortho coplanar PCBs, polychlorinated dibenzo-p-dioxins and dibenzofurans in the atmosphere. Chemosphere 32(3):491–500.
*Kusuda M. 1971. A study on the sexual functions of women suffering from rice-bran oil poisoning. Sanka to Fujinka 38:1062–1072.
*Kutz FW, Wood PH, Bottimore DP. 1991. Residues in human adipose tissue. Rev Environ Contam Toxicol 120:61–81.
*Kuwabara K, Yakushiji T, Watanabe I, . 1979. Increase in the human blood PCB levels promptly following ingestion of fish containing PCBs. Bull Environ Contam Toxicol 21:273–278.109143
*Lackmann GM, Angerer J, Salzberger U, . 1999. Influence of maternal age and duration of pregnancy on serum concentrations of polychlorinated biphenyls and hexachlorobenzene in full-term neonates. Biol Neonate 76:214–219.10473895
*Lacorte S, Eggens ML. 1993. Influence of diet on the bioaccumulation of PCBs. Sci Total Environ Suppl(Pt 1):479–489.
*Lai T-J, Guo Y-L, Yu M-L, . 1994. Cognitive development in Yucheng children. Chemosphere 29(9–11):2405–2411.7850389
*Laib RJ, Rose J, Brunn H. 1991. Hepatocarcinogenicity of PCB congeners: I. Initiation and promotion of enzyme-altered rat liver foci by 2,2’,4,5’-tetra- and 2,2’,4,4’,5,5’-hexachlorobiphenyl. Toxicol Environ Chem 34:19–22.
*Lake CA, Lake JL, Haebler R, . 1995a. Contaminant levels in harbor seals from the northeastern United States. Arch Environ Contam Toxicol 29:128–134.7794010
*Lake JL, McKinney R, Lake CA, . 1995b. Comparisons of patterns of polychlorinated biphenyl congeners in water, sediment, and indigenous organisms from New Bedford Harbor, Massachusetts. Arch Environ Contam Toxicol 29:207–220.
*Lake JL, Pruell RJ, Osterman FA. 1992. An examination of dechlorination processes and pathways in New Bedford Harbor sediments. Mar Environ Res 33(1):31–47.
*Lambert GH, Hsu CC, Humphrey H, . 1992. Cytochrome P450IA2 in-vivo induction: A potential biomarker of polyhalogenated biphenyls and their related chemical’s effects on the human. Chemosphere 25:197–200.
*Lan S-J, Yen Y-Y, Yang C-H, . 1987. A study of the birth weights of transplancental Yu-Cheng babies. Kaohsiung J Med Sci 3:273–282.
Langer P, Kausitz J, Tajtakova M, . 1997. Decreased blood level of β_2_-microglobulin in the employees of a factory which produced polychlorinated biphenyls. Chemosphere 34(12):2595–2600.9204542
*Langer P, Tajtakova M, Fodor G, . 1998. Increased thyroid volume and prevalence of thyroid disorders in an area heavily polluted by polychlorinated biphenyls. Eur J Endocrinol 139:402–409.9820616
Lans MC, Klasson-Wehler E, Willemsen M, . 1993. Structure-dependent, competitive interaction of hydroxy-polychlorobiphenyls, -dibenzo-p-dioxins and -dibenzofurans with human transthyretin. Chem Biol Interact 88(1):7–21.8330325
Lans MC, Spiertz C, Brouwer A, . 1994. Different competition of thyroxine binding to transthyretin and thyroxine-binding globulin by hydroxy-PCBs, PCDDs and PCDFs. Eur J Pharmacol 270:129–136.8039542
*Lanting CI, Fidler V, Huisman M, . 1998a. Determinants of polychlorinated biphenyl levels in plasma from 42-month-old children. Arch Environ Contam Toxicol 35:135–139.9601931
*Lanting CI, Huisman M, Muskiety FAJ, . 1998b. Polychlorinated biphenyls in adipose tissue, liver, and brain from nine stillborns of varying gestational ages. Pediatr Res 44:222–225.9702918
*Lanting CI, Patandin S, Fidler V, . 1998c. Neurological condition in 42-month-old children in relation to pre- and postnatal exposure to polychlorinated biphenyls and dioxins. Early Hum Dev 50:283–292.9548032
*Larsen BR, Turrio-Baldassarri L, Nilsson T, . 1994. Toxic PCB congeners and organochlorine pesticides in Italian human milk. Ecotoxicol Environ Saf 28:1–13.7523063
*Larsen JC. 1995. Levels of pollutants and their metabolites: exposure to organic substances. Toxicology 101:11–27.7631320
*Larsson P. 1985. Contaminated sediments of lakes and oceans act as sources of chlorinated hydrocarbons for release to water and atmosphere. Nature 317:347–349.
*Larsson P, Lemkemeier K. 1989. Microbial mineralization of chlorinated phenols and biphenyls in sediment-water systems from humic and clear-water lakes. Water Res 23:1081–1085.
*Larsson P, Okla L. 1989. Atmospheric transport of chlorinated hydrocarbons to Sweden in 1985 compared to 1973. Atmos Environ 23:1699–1711.
*Larsson P, Sodergren A. 1987. Transport of polychlorinated biphenyls (PCBs) in freshwater mesocosms from sediment to water and air. Water Air Soil Pollut 36:33–46.
*Lawrence C. 1977. PCB? and melanoma [Letter]. N Engl J Med 296:108.401456
*Lawrence J and Toxine HM. 1977. Polychlorinated biphenyl concentrations in sewage and sludges of some waste treatment plants in southern Ontario. Bull Environ Contam Toxicol 17:49–56.402165
*Lawton RW, Brown JF, Ross MR, . 1985b. Comparability and precision of serum PCB measurements. Arch Environ Health 40:29–37.3922318
*Lawton RW, Ross MR, Feingold J, . 1985a. Effects of PCB exposure on biochemical and hematological findings in capacitor workers. Environ Health Perspect 60:165–184.2863133
*Lawton RW, Ross MR, Feingold J, . 1986. Spirometric findings in capacitor workers occupationally exposed to polychlorinated biphenyls (PCBs). J Occup Med 28:453–456.3088230
*Lead WA, Steinnes E, Bacon JR, . 1997. Polychlorinated biphenyls in the UK and Norwegian soils: spatial and temporal trends. Sci Total Environ 193:229–236.
*Lebel G, Dodin S, Ayotte P, . 1998. Organochlorine exposure and the risk of endometriosis. Fertil Steril 69(2):221–228.9496332
*Le Bel GL, Williams DT. 1986. Determination of halogenated contaminants in human adipose tissue. J Assoc Off Anal Chem 69:451–458.3722093
Leblanc GA. 1995. Trophic-level differences in the bioconcentration of chemicals: Implications in assessing environmental biomagnification. Environ Sci Technol 29:154–160.22200214
*Lecavalier P, Chu I, Yagminas A, . 1997. Subchronic toxicity of 2,2’,3,3’,4,4’-hexachlorobiphenyl in rats. J Toxicol Environ Health 51(3):265–277.9183382
*Lee, H-B, Peart TE. 1994. Optimization of supercritical carbon dioxide extraction for polychlorinated biphenyls and chlorinated benzenes from sediments. J Chromatogr 663:87–95.
*Lee MC, Griffin RA, Miller ML, . 1979. Adsorption of water-soluble polychlorinated biphenyl Aroclor 1242 and used capacitor fluid by soil materials and coal chars. J Environ Sci Health A14:415–442.
*Lee W-J, Su C-C, Sheu H-L, . 1996. Monitoring and modeling of PCB dry deposition in urban area. Journal of Hazardous Materials 49:57–88.
Leece B, Denomme MA, Towner R, . 1985. Polychlorinated biphenyls: Correlation between in vivo and in vitro quantitative structure-activity relationships (QSARs). J Toxicol Environ Health 16:379–388.3936939
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: implications for practice. Pediatr Clin North Am 44:55–77.9057784
*Leister DL, Baker JE. 1994. Atmospheric deposition of organic contaminants to the Chesapeake Bay. Atmos Environ 28(8):1499–1520.
*Leoni V, Fabiani L, Marinelli G, . 1989. PCB and other organochlorine compounds in blood of women with or without miscarriage: A hypothesis of correlation. Ecotoxicol Environ Safety 17:1–11.2496968
*Leonzio C, Fossi MC, Casini S. 1996a. Porphyrins as biomarkers of methylmercury and PCB exposure in experimental quail. Bull Environ Contam Toxicol 56:244–250.8720096
*Leonzio C, Monaci F, Fossi MC, . 1996b. Multiresponse biomarker evaluation of interactions between methylmercury and arochlor 1260 in quail. Ecotoxicology 5:365–376.24193919
*Lester R, Schmid R. 1964. Bilirubin metabolism. New Engl J Med 270:779–786.14107318
*Letcher RJ, Norstrom RJ, Bergman A. 1995. Geographical distribution and identification of methylsulphone PCB and DDE metabolites in pooled polar bear (ursus maritimus) adipose tissue from western hemisphere Arctic and Subarctic regions. Sci Total Environ 160:409–420.7892578
*Letcher RJ, Norstrom RJ, Muir DCG. 1998. Biotransformation versus bioaccumulation: Sources of methyl sulfone PCB and 4,4’-DDE metabolites in the polar bear food chain. Environ Sci Technol 32:1656–1661.
*Letz G. 1983. The toxicology of PCB’s: An overview for clinicians. West J Med 138:534–540.6223449
*Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. I. New York, NY: Stockton Press, 153–164.
*Leung H-W, Ku RH, Paustenbach DJ, . 1988. A physiologically based pharmacokinetic model for 2,3,7,8-tetrachlorodibenzo-p-dioxin in C57BL/6J and DBA/2J mice. Toxicol Lett 42:15–28.2838936
*Levengood JM, Ross SC, Stahl ML, . 1999. Organochlorine pesticide and polychlorinated biphenyl residues in Canada geese (branta canadensis) from Chicago, Illinois. Vet Hum Toxicol 41(2):71–75.10192133
*Levin ED, Schantz SL, Bowman RE. 1988. Delayed spatial alternation deficits resulting from perinatal PCB exposure in monkeys. Arch Toxicol 62:267–273.3149182
*Lewis RG, Martin BE, Sgontz DL, . 1985. Measurements of fugitive atmospheric emissions of polychlorinated biphenyls from hazardous waste landfills. Environ Sci Technol 19:986–991.
Li MH, Hansen LG. 1995. Uterotropic and enzyme induction effects of 2,2’,5-trichlorobiphenyl. Bull Environ Contam Toxicol 54(4):494–500.7767025
*Li MH, Hansen LG. 1996a. Responses of prepubertal female rats to environmental PCBs with high and low dioxin equivalencies. Fundam Appl Toxicol 33(2):282–293.8921347
*Li MH, Hansen LG. 1996b. Enzyme induction and acute endocrine effects in prepubertal female rats receiving environmental PCB/PCDF/PCDD mixtures. Environ Health Perspect 104(7):712–722.8841756
*Li M-H, Hansen LG. 1997. Consideration of enzyme and endocrine interactions in the risk assessment of PCBs. Reviews in Toxicology 1:71–156.
*Li M-H, Rhine C, Hansen LG. 1998. Hepatic enzyme induction and acute endocrine effects of 2,3,3’,4’,6’-pentachlorobiphenyl in prepubertal female rats. Arch Environ Contam Toxicol 35:97–103.9601926
*Li M-H, Zhao Y-D, Hansen LG. 1994. Multiple dose toxicokinetic influence on the estrogenicity of 2,2’,4,4’,5,5’-hexachlorobiphenyl. Bull Environ Contam Toxicol 53:583–590.8000188
*Liang Y, Wong MH, Shutes RBE, . Ecological risk assessment of polychlorinated biphenyl contamination in the Mai Po Marshes Nature Reserve, Hong Kong. Wat Res 33(6):1337–1346.
*Liberti L, Petruzzelli D, Tiravanti G. 1992. Accidental road spilling of polychlorobiphenyls-A case history. Water Sci Technol 25(3):239–246.
*Liem AKD. 1999. Basic aspects of methods for the determination of dioxins and PCBs in foodstuffs and human tissues. Trends in Analytical Chemistry 18(6):429–439.
*Lilienthal H, Winneke G. 1991. Sensitive periods for behavioral toxicity of polychlorinated biphenyls: Determination by cross-fostering in rats. Fundam Appl Toxicol 17:368–375.1765224
*Lilienthal H, Neuf M, Munoz C, . 1990. Behavioral effects of pre- and postnatal exposure to a mixture of low chlorinated PCBs in rats. Fundam Appl Toxicol 15:457–467.2124194
*Liljegren G, Hardell L, Lindstrom G, . 1998. Case-control study on breast cancer and adipose tissue concentrations of congener specific polychlorinated biphenyls, DDE and hexachlorobenzene. Eur J Cancer Prev 7:135–140.9818775
*Lin JM, Que Hee SS. 1985. Optimization of perchlorination conditions for some representative polychlorinated biphenyls. Anal Chem 57:2130–2134.
*Lin JM, Que Hee SS. 1987. Change in chromatogram patterns after volatilization of some Aroclors, and the associated quantitation problems. Am Ind Hyg Assoc J 48:599–607.3113221
*Linder RE, Gaines TB, Kimbrough RD. 1974. The effect of polychlorinated biphenyls on rat reproduction. Food Cosmet Toxicol 12:63–77.4218577
*Litterst CL, Farber TM, Baker AM, . 1972. Effect of polychlorinated biphenyls on hepatic microsomal enzymes in the rat. Toxicol Appl Pharmacol 23:112–122.4341899
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*Lober M, Cleverly D, Schaum J, . 1994. Development and validation of an air-to-beef food chain model for dioxin-like compounds. Sci Total Environ 156:39–65.7801108
*Lockhart WL, Muir CG, Wilkinson P, . 1998. Chemical contaminants in fish and sediment core samples from the Dnipro River, Ukraine, 1994. Water Qual Res J Can 33(4):489–509.
*Loganathan BG, Irvine KN, Kannan K, . 1997. Distribution of selected PCB congeners in the Babcock Street sewer district: a multimedia approach to identify PCB sources in combined sewer overflows (CSOS) discharging to the Buffalo River, New York. Arch Environ Contam Toxicol 33(2):130–140.9294240
*Loganathan BG, Kannan K, Watanabe I, . 1995. Isomer-specific determination and toxic evaluation of polychlorinated biphenyls, polychlorinated/brominated dibenzo-p-dioxins and dibenzofurans, polybrominated biphenyl ethers, and extractable organic halogen in carp from the Buffalo River, New York. Environ Sci Technol 29(7):1832–1838.22176457
*Lohmann R, Jones KC. 1998. Dioxins and furans in air and deposition: a review of levels, behaviour and processes. Sci Total Environ 219:53–81.9770324
Lokietz H, Dowben RM, Hsia DYY. 1963. Studies on the effect of Novobiocin and glucuronyl transferase. Pediatrics 32:47–51.
*Longcope C. 2000. The male and female reproductive systems in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner & Ingbar’s the thyroid: A fundamental and clinical text. Eighth edition. Philadelphia, PA: Lippincott Williams & Wilkins, 824–827.
*Longnecker MP, Gladen BC, Patterson DG, . 2000. Polychlorinated biphenyl (PCB) exposure in relation to thyroid hormone levels in neonates. Epidemiology 11:249–254.10784239
Longnecker MP, Rogan WJ, Lucier G. 1997. The human health effects of DDT (dichlorodiphenyltrichloroethane) and PCBs (polychlorinated biphenyls) and an overview of organochlorines in public health. Annu Rev Public Health 18:211–244.9143718
*Lonky E, Reihman J, Darvill T, . 1996. Neonatal behavioral assessment scale performance in humans influenced by maternal consumption of environmentally contaminated Lake Ontario fish. J Great Lakes Res 22(2):198–212.
*Loo JCK, Tryphonas H, Jordan N, . 1989. Effects of Aroclor 1254® on hydrocortisone levels in adult Rhesus monkeys (macaca mulatta). Bull Environ Contam Toxicol 43:667–669.2508804
*Loomis D, Browning SR, Schenck AP, . 1997. Cancer mortality among electric utility workers exposed to polychlorinated biphenyls. Occup Environ Med 54(10):720–728.9404319
*Loose LD, Pittman KA, Benitz KF, . 1977. Polychlorinated biphenyl and hexachlorobenzene induced humoral immunosuppression. J Reticuloendothel Soc 22(3):253–267.411925
*Loose LD, Pittman KA, Benitz KF, . 1978b. Environmental chemical-induced immune dysfunction. Ecotoxicol Environ Saf 2:173–198.103706
*Loose LD, Silkworth JB, Charbonneau T, . 1981. Environmental chemical-induced macrophage dysfunction. Environ Health Persp 39:79–91.
*Loose LD, Silkworth JB, Mudzinski SP, . 1979. Modification of the immune response by organochloride xenobiotics. Drug Chem Toxicol 2:111–132.121284
*Loose LD, Silkworth JB, Pittman KA, . 1978a. Impaired host resistance to endotoxin and malaria in polychlorinated biphenyl- and hexachlorobenzene-treated mice. Infect Immun 20:30–35.97225
*Looser R, Ballschmiter K. 1998. Biomagnification of polychlorinated biphenyls (PCBs) in freshwater fish. Fresenius Journal of Analytical Chemistry 360:816–819.
*Lopez-Avila V, Schoen S, Milanes J, . 1988. Single-laboratory evaluation of EPA method 8080 for determination of chlorinated pesticides and polychlorinated biphenyls in hazardous wastes. J Assoc Off Anal Chem 71:375–386.2838450
Lopshire RF, Watson JT, Enke CG. 1996. Composition-selective detection of polychlorinated biphenyls (PCBs) by oxygen-chlorine exchange reaction in a tandem mass spectrometer. Toxicol Ind Health 12:375–391.8843555
*Lorber MN, Winters DL, Griggs J, . 1998. A national survey of dioxin-like compounds in the United States milk supply. Organohalogen Compounds 38:125–129.
*Lordo RA, Dinh KT, Schwemberger JG. 1996. Semivolatile organic compounds in adipose tissue: Estimated averages for the U.S. population and selected subpopulations. Am J Public Health 86(9):1253–1259.8806377
*Lu F-J, Chang K-J, Lin S-C, . 1980. [Studies on patients with polychlorinated biphenyl poisoning: Determination of urinary coproporphyrin, uroporphyrin, γ-aminolevulinic acid and porphobilinogen.] J Formosan Med Assoc 79:990–995. (Chinese)
*Lu Y-C, Wu Y-C. 1985. Clinical findings and immunological abnormalities in Yu-Cheng patients. Environ Health Perspect 59:17–29.3921359
*Lubet RA, Nims RW, Beebe LE, . 1992. Induction of hepatic CYP1A activity as a biomarker for environmental exposure to Aroclor® 1254 in feral rodents. Arch Environ Contam Toxicol 22(3):339–344.1616319
*Lucier GW, Nelson KG, Everson RB, . 1987. Placental markers of human exposure to polychlorinated biphenyls and polychlorinated dibenzofurans. Environ Health Perspect 76:79–87.2834196
Luebeck EG, Moolgavkar SH, Buchmann A, . 1991. Effects of polychlorinated biphenyls in rat liver: Quantitative analysis of enzyme-altered foci. Toxicol Appl Pharmacol 111:469–484.1684071
*Lund J, Brandt I, Poellinger L, . 1985. Target cells for the polychlorinated biphenyl metabolite 4,4’-bis(methylsulfonyl)-2,2’,5,5’-tetrachlorobiphenyl: Characterization of high affinity binding in rat and mouse lung cytosol. Mol Pharmacol 27:314–323.3918256
*Lunden A, Noren K. 1998. Polychlorinated naphthalenes and other organochlorine contaminants in Swedish human milk, 1972-1992. Arch Environ Contam Toxicol 34:414–423.9543513
*Lundkvist U. 1990. Clinical and reproductive effects of Clophen A50 (PCB) administered during gestation on pregnant guinea pigs and their offspring. Toxicology 6:249–257.
*Luotamo M. 1988. Isomer-specific biological monitoring of polychlorinated biphenyls. Scand J Work Environ Health 14(Suppl 1):60–62.3134691
*Luotamo M, Iarvisalo J, Aitio A. 1985. Analysis of polychlorinated biphenyls (PCBs) in human serum. Environ Health Perspect 60:327–332.3928361
*Luotamo, M, Jarvisalo J, Aitio A. 1991. Assessment of exposure to polychlorinated biphenyls: analysis of selected isomers in blood and adipose tissue. Environ Res 54:121–134.1903103
*Luotamo M, Patterson DG Jr, Needham LL, . 1993. Concentrations of PCB congeners in sera from workers with past and present exposure. Chemosphere 27(1–3):171–177.
*Luster MI, Portier C, Pait DG, . 1992. Risk assessment in immunotoxicology: I. Sensitivity and predictability of immune tests. Fundam Appl Toxicol 18:200–210.1534777
*Lutz RJ, Dedrick RL. 1987. Physiologic pharmacokinetic modeling of polychlorinated biphenyls. Environ Toxicol Series 1:111–131.
*Lutz RJ, Dedrick RL, Matthews HB, . 1977. A preliminary pharmacokinetic model for several chlorinated biphenyls in the rat. Drug Metab Dispos 5:386–396.19218
*Lutz RJ, Dedrick RL, Tuey D, . 1984. Comparison of the pharmacokinetics of several polychlorinated biphenyls in mouse, rat, dog, and monkey by means of a physiological pharmacokinetic model. Drug Metab Dispos 12:527–535.6149901
Ma CY, Bayne CK. 1993. Differentiation of Aroclors using linear discrimination for environmental samples analyzed by electron capture negative ion chemical ionization mass spectrometry. Anal Chem 65(6):772–777.
*Maack L, Sonzogni WC. 1988. Analysis of polychlorobiphenyl congeners in Wisconsin fish. Arch Environ Contam Toxicol 17:711–719.3147615
*Macdonald RW, Barrie LA, Bidleman TF, . 2000. Contaminants in the Canadian Arctic: 5 years of progress in understanding sources, occurrence and pathways. Sci Total Environ 254:98–234.
*Mackay D. 1989. Modeling the long-term behavior of an organic contaminant in a large lake: Application to PCBs in Lake Ontario. J Great Lakes Res 15:283–297.
*MacLellan K, Singh A, Chu I, . 1994a. Subchronic toxicity of 3,3’,4,4’-tetrachlorobiphenyl in the rat liver: An electron microscope study. Histol Histopathol 9:453–459.7981493
*MacLellan K, Singh A, Chu I, . 1994b. Subchronic toxicity of pentachlorobiphenyl congeners n. 126 or 118 in the rat liver. An electron microscope study. J Submicrosc Cytol Pathol 26(2):279–291.8019951
*MacLellan K, Singh A, Chu I, . 1994c. Toxicity of 2,2’,4,4’,5,5’-hexachlorobiphenyl in the rat liver: An electron microscope study. Histol Histopathol 9:461–468.7981494
*MacLeod KE. 1981. Polychlorinated biphenyls in indoor air. Environ Sci Technol 15:926–928.22284003
*Madenjian CP, Schmidt LJ, Chernyak SM, . 1999. Variation in net trophic transfer efficiencies among 21 PCB congeners. Environ Sci Technol 33:3768–3773.
*Madra S, Mann F, Francis JE, . 1996. Modulation by iron of hepatic microsomal and nuclear cytochrome P450, and cytosolic glutathione S-transferase and peroxidase in C57BL/10ScSn mice induced with polychlorinated biphenyls (Aroclor 1254). Toxicol Appl Pharmacol 136(1):79–86.8560483
*Madra S, Styles J, Smith AG. 1995. Perturbation of hepatocyte nuclear populations induced by iron and polychlorinated biphenyls in C57BL/10ScSn mice during carcinogenesis. Carcinogenesis 16(4):719–727.7728949
Maier WE, Kodavanti PRS, Harry J, . 1994. Sensitivity of adenosine triphosphatases in different brain regions to polychlorinated biphenyl congeners. J Appl Toxicol 14:225–229.8083484
*Makepeace DK, Smith DW, Stanley SJ. 1995. Urban stormwater quality: Summary of contaminant data. Critical Reviews in Environmental Science and Technology 25(2):93–139.
*Makiura S, Aoe H, Sugihara S, . 1974. Inhibitory effect of polychlorinated biphenyls on liver tumorigenesis in rats treated with 3’-methyl-4-dimethylaminoazobenzene, N-2-fluorenylacetamide, and diethylnitrosamine. J Natl Cancer Inst 53:1253–1257.4372378
*Malkin R. 1995. Occupational and environmental lead and PCB exposure at a scrap metal dealer. Environ Res 70(1):20–23.8603654
*Manchester-Neesvig JB, Andren AW, Edgington DN. 1996. Patterns of mass sedimentation and of deposition of sediment contaminated by PCBs in Green Bay. J Great Lakes Res 22(2):444–462.
*Mannisto MK, Puhakka JA, Ferguson JF. 1997. Degradation of Aroclor 1221, 1242 and anaerobically transformed Aroclor 1254 by aerobic marine sediment microorganisms. In: Alleman BC, Leeson A, eds. In situ and on-site bioremediation: Volume 2. Columbus, OH: Battelle Press, 421–426.
Marczylo T, Ioannides C. 1997. Induction of the rat hepatic cytosolic arylamine oxidase by a series of polychlorinated biphenyls: association with the Ah locus. Toxicol Lett 92(2):81–91.9295230
*Mariani E, Bargagna A, Longobardi M. 1994. Gas chromatographic determination of chlorinated pesticides and PCBs in complex cosmetic matrices. Il Farmaco 49(6):441–442.8074786
*Mariussen E, Anderson JM, Fonnum F. 1999. The effect of polychlorinated biphenyls on the uptake of dopamine and other neurotransmitters into rat brain synaptic vesicles. Toxicol Appl Pharmacol 161:274–282.10620485
*Maroni M, Colombi A, Feriolo A, . 1993. Evaluation of porphyrinogenesis and enzyme induction in workers exposed to PCB. Med Lav 75:188–199.
*Maroni M, Columbi A, Arbosti G, . 1981a. Occupational exposure to polychlorinated biphenyls in electrical workers. II Health effects. Br J Ind Med 38:55–60.6451237
*Maroni M, Columbi A, Arbosti G, . 1981b. Occupational exposure to polychlorinated biphenyls in electrical workers. I Environmental and blood polychlorinated biphenyls concentrations. Br J Ind Med 38:49–54.6781529
Maronpot RR, Montgomery CA, Boorman GA, . 1986. National Toxicology Program nomenclature for hepatoproliferative lesions of rats. Toxicol Pathol 14:263–273.3764323
*Maruya KA, Lee RF. 1998. Aroclor 1268 and toxaphene in fish from a southeastern U.S. estuary. Environ Sci Technol 32(8):1069–1075.
*Massachusetts Department of Public Health. 1987. Final report of Greater New Bedford PCB health effects study 1984-1987. Boston, MA: Massachusetts Department of Public Health.
*Masuda Y. 1994. The Yusho rice oil poisoning incident. In: Schecter A., ed. Dioxins and health. New York, NY: Plenum Press, 633–659.
*Masuda Y, Kagawa R, Kuroki H, . 1978. Transfer of polychlorinated biphenyls from mothers to foetuses and infants. Food Cosmet Toxicol 16:543–546.103790
*Masuda Y, Kagawa R, Kuroki H, . 1979. Transfer of various polychlorinated biphenyls to the foetuses and offspring of mice. Food Cosmet Toxicol 17:623–627.121097
Matsusue K, Ishii Y, Ariyoshi N, . 1997. A highly toxic PCB produces unusual changes in the fatty acid composition of rat liver. Toxicol Lett 91(2):99–104.9175845
*Matthews HB. 1982. Aryl halides. In: Jakoby WB, Bend JR, Caldwell J, eds. Metabolic basis of detoxification. Metabolism of functional groups. New York: Academic Press, 51–68.
*Matthews HB, Anderson MW. 1975. Effect of chlorination on the distribution and excretion of polychlorinated biphenyls. Drug Metab Dispos 3:371–380.241618
*Matthews HB, Dedrick RL. 1984. Pharmacokinetics of PCBs. Ann Rev Pharmacol Toxicol 24:85–103.6428301
*Matthews HB, Surles JR, Carver JG, . 1984. Halogenated biphenyl transport by blood components. Fundam Appl Toxicol 4:420–428.6430742
*May HD, Boyle AW, Price WA, . 1992. Subculturing of a polychlorinated biphenyl-dechlorinating anaerobic enrichment on solid media. Appl Environ Microbiol 58(12):4051–4054.1476444
May RJ, Mondello FJ. 1999. Metabolite detection as a tool for the determination of naturally occurring aerobic PCB biodegradation. Schenectady, NY: General Electric Company, Corporate Research and Development. May 14, 1999.
*Mayes BA, McConnell EE, Neal BH, . 1998. Comparative carcinogenicity in Sprague-Dawley rats of the polychlorinated biphenyl mixtures Aroclors 1016, 1242, 1254, and 1260. Toxicol Sci 41(1):62–76.9520342
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mazhitova Z, Jensen S, Ritzen M, . 1998. Chlorinated contaminants, growth and thyroid function in schoolchildren from the Aral Sea region in Kazakhstan. Acta Paediatr 87:991–995.9764896
*McConnell E, Hass JR, Altman N, . 1979. A spontaneous outbreak of polychlorinated biphenyl (PCB) toxicity in Rhesus monkeys (macaca mulatta): Toxicopathology. Lab Animal Sci 29:666–673.
*McConnell L, Bidleman T, Cotham W, . 1998. Air concentrations of organochlorine insecticides and polychlorinated biphenyls over Green Bay, WI, and the four lower Great Lakes. Environ Pollut 101:391–399.
*McCormack KM, Melrose P, Rickert DE, . 1979. Concomitant dietary exposure to polychlorinated biphenyls and polybrominated biphenyls: Tissue distribution and arylhydrocarbon hydroxylase activity in lactating rats. Toxicol Appl Pharmacol 47:95–104.218325
McCoy G, Finlay MF, Rhone A, . 1995. Chronic polychlorinated biphenyls exposure on three generations of oldfield mice (peromyscus polionotus): Effects on reproduction, growth, and body residues. Arch Environ Contam Toxicol 28(4):431–435.7755397
*McFarland VA, Clarke JU. 1989. Environmental occurrence, abundance, and potential toxicity of polychlorinated biphenyl congeners: Considerations for a congener-specific analysis. Environ Health Perspect 81:225–239.2503374
*McGroddy SE, Farrington JW, Gschwend PM. 1996. Comparison of the in situ and desorption sediment-water partitioning of polycyclic aromatic hydrocarbons and polychlorinated biphenyls. Environ Sci Technol 30:172–177.
*McIntyre AE, Lester JN. 1982. Polychlorinated biphenyl and organochlorine insecticide concentrations in forty sewage sludges in England. Environ Pollut 3:225–230.
*McKinley MK, Kedderis LB, Birnbaum LS. 1993. The effect of pretreatment on the biliary excretion of 2,3,7,8-tetrachlorodibenzo-p-dioxin, 2,3,7,8-tetrachlorodibenzofuran, and 3,3’,4,4’-tetrachlorobiphenyl in the rat. Fundam Appl Toxicol 21:425–432.8253296
McKinney JD, Waller CL. 1994. Polychlorinated biphenyls as hormonally active structural analogues. Environ Health Perspect 102:290–297.8033869
*McLachlan J. 1997. Synergistic effect of environmental estrogens: Report withdrawn. Science 277:462–463.9254413
*McLachlan MS. 1993. Digestive tract absorption of polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls in a nursing infant. Toxicol Appl Pharmacol 123(1):68–72.8236263
*McLachlan MS, Hinkel M, Reissinger M, . 1994. A study of the influence of sewage sludge fertilization on the concentrations of PCDD/F and PCB in soil and milk. Environ Pollut 85:337–343.15091665
McLachlan M, Mackay D, Jones PH. 1990. A conceptual model of organic chemical volatilization at waterfalls. Environ Sci Technol 24:252–257.
*McLean MR, Robertson LW, Gupta RC. 1996. Detection of PCB adducts by the P-postlabeling technique. Chem Res Toxicol 9:165–171.8924587
*McNulty WP, Becker GM, Cory HT. 1980. Chronic toxicity of 3,4,3’,4- and 2,5,2’5’-tetrachlorobiphenyls in Rhesus macaques. Toxicol Appl Pharmacol 56:182–190.6781105
Mehlman MA, Friend B, Tobin RB. 1974a. The effect of polychlorinated biphenyls on liver gluconeogenic enzyme activities in rats during exposure to cold. Toxicology 2:301–308.4369298
Mehlman MA, Yin L, Nielsen RC. 1974b. Metabolic changes in “frozen-clamped” livers of rats caused by ingestion of polychlorinated biphenyls. Toxicol Appl Pharmacol 27:300–307.4152956
Mehlman MA, Tobin RB, Friend B, . 1975. The effects of a polychlorinated biphenyl mixture (aroclor 1254) on liver gluconeogenic enzymes of normal and alloxan-diabetic rats. Toxicology 5:89–95.171802
*Meigs JW, Albom JJ, Kartin BL. 1954. Chloracne from an unusual exposure to Aroclor. J Am Med Assoc 154:1417–1418.13151867
*Melino G, Vernole P, Antinori M, . 1992. Immunological and cytogenetic damage in workers accidentally exposed to polychlorinated biphenyls (PCB). Clin Chem Enzymol Commun 4(5):341–353.
*Mendola P, Buck GM, Sever LE, . 1997. Consumption of PCB-contaminated freshwater fish and shortened menstrual cycle length. Am J Epidemiol 146(11):955–960.9400337
*Mendola P, Buck GM, Vena JE, . 1995a. Consumption of PCB-contaminated sport fish and risk of spontaneous fetal death. Environ Health Perspect 103:498–502.7656880
*Mendola P, Vena JE, Buck GM. 1995b. Exposure characterization, reproductive and developmental health in the New York State angler cohort study. Great Lakes Res Rev 1(2):41–43.
Mergler D, Belanger S, Larribe F, . 1998. Preliminary evidence of neurotoxicity associated with eating fish from the upper St. Lawrence River lakes. Neurotoxicology 19(4–5):691–702.9745930
*Mes J. 1994. Temporal changes in some chlorinated hydrocarbon residue levels of Canadian breast milk and infant exposure. Environ Pollut 84(3):261–268.15091697
*Mes J, Davies DJ. 1979. Presence of polychlorinated biphenyl and organochlorine pesticide residues and the absence of polychlorinated terphenyls in Canadian human milk samples. Bull Environ Contam Toxicol 21:381–387.109148
*Mes J, Arnold DL, Bryce F, . 1989. The effect of long-term feeding of Aroclor® 1254 to female Rhesus monkeys on their polychlorinated biphenyl tissue levels. Arch Environ Contam Toxicol 18:858–865.2515810
*Mes J, Arnold DL, Bryce F. 1994. Determination of polychlorinated biphenyls in postpartum blood, adipose tissue, and milk from female Rhesus monkeys and their offspring after prolonged dosing with Aroclor® 1254. J Anal Toxicol 18(1):29–35.8127081
*Mes J, Arnold DL, Bryce F. 1995a. The elimination and estimated half-lives of specific polychlorinated biphenyl congeners from the blood of female monkeys after discontinuation of daily dosing with Aroclor® 1254. Chemosphere 30:789–800.7889352
*Mes J, Arnold DL, Bryce F. 1995b. Postmortem tissue levels of polychlorinated biphenyls in female Rhesus monkeys after more than six years of daily dosing with Aroclor® 1254 and in their non-dosed offspring. Arch Environ Toxicol 29:69–76.
*Mes J, Arnold DL, Bryce F. 1995c. Female Rhesus monkeys dosed with Aroclor®1254: Analysis of polychlorinated biphenyl congeners in dam’s milk and in the blood of dams and their offspring before, during, and after gestation. J Anal Toxicol 19:209–217.8531465
*Mes J, Davies DJ, Doucet J, . 1993. Specific polychlorinated biphenyl congener distribution in breast milk of Canadian women. Environ Technol 14(6):555–565.
*Mes J, Davies DJ, Turton D, . 1986. Levels and trends of chlorinated hydrocarbon contaminants in the breast milk of Canadian women. Food Additives Contaminants 3(4):313–322.3803638
*Mes J, Doyle JA, Adam BR, . 1984. Polychlorinated biphenyls and organochlorine pesticides in milk and blood of Canadian women during lactation. Arch Environ Contam Toxicol 13:217–223.6426410
Meserve LA, Murray BA, Landis JA. 1992. Influence of maternal ingestion of Aroclor 1254® (PCB) or FireMaster BP- 6® (PBB) on unstimulated and stimulated corticosterone levels in young rats. Bull Environ Contam Toxicol 48(5):715–720.1324039
*Metcalfe TL, Metcalfe CD. 1997. The trophodynamics of PCBs, including mono- and non-ortho congeners, in the food web of North-Central Lake Ontario. Sci Total Environ 201:245–272.9241874
Metcalfe-Smith JL, Maguire RJ, Batchelor SP. 1995. Polychlorinated biphenyl congeners and chlorinated pesticides in fish from the Yamaska River basin, Quebec. Water Qual Res J Can 30(2):179–204.
*Meylan W, Howard PH, Boethling RS. 1992. Molecular topology/fragment contribution method for predicting soil sorption coefficients. Environ Sci Technol 26(8):1560–1567.
*Miller DB, Gray LE Jr, Andrews JE, . 1993b. Repeated exposure to the polychlorinated biphenyl (Aroclor 1254) elevates the basal serum levels of corticosterone but does not affect the stress-induced rise. Toxicology 81(3):217–222.8212027
Miller DT, Condon SK, Kutzner S, . 1991. Human exposure to polychlorinated biphenyls in Greater New Bedford, Massachusetts: A prevalence study. Arch Environ Contam Toxicol 20:410–416.1907125
*Miller MA, Kassulke NM, Walkowski MD. 1993a. Organochlorine concentrations in Laurentian Great Lakes salmonines: Implications for fisheries management. Arch Environ Contam Toxicol 25:212–219.
Mills AG, Jefferies TM. 1993. Rapid isolation of polychlorinated biphenyls from milk by a combination of supercritical-fluid extraction and supercritical-fluid chromatography. J Chromatogr 643(1–2):409–418.8360309
*Miyata H, Aozasa O, Ohta S, . 1993. Estimated daily intakes of PCDDs, PCDFs and non-ortho coplanar PCBs via drinking water in Japan. Chemosphere 26(8):1527–1536.
*Mizutani T, Hidaka K, Ohe T, . 1977. A comparative study on accumulation and elimination of tetrachlorobiphenyl isomers in mice. Bull Environ Contam Toxicol 18:452–461.411531
Monjan AA, Collector MI. 1977. Stress-induced modulation of the immune response. Science 186:307–308.
*Monosmith CL, Hermanson MH. 1996. Spatial and temporal trends of atmospheric organochlorine vapors in the central and upper Great Lakes. Environ Sci Technol 30:3464–3472.
*Monsanto Chemical Company. 1985. Monsanto material safety data: Polychlorinated biphenyls (PCBs). St. Louis, MO: Monsanto Company.
*Moore JA, Hardisty JF, Banas DA, . 1994. A comparison of liver tumor diagnoses from seven PCB studies in rats. Regul Toxicol Pharmacol 20:362–370.7724839
*Moore M, Mustain M, Daniel K, . 1997. Antiestrogenic activity of hydroxylated polychlorinated biphenyl congeners identified in human serum. Toxicol Appl Pharmacol 142:160–168.9007045
Mora MA. 1995. Residues and trends of organochlorine pesticide and polychlorinated biphenyls in birds from Texas 1965-88. Fish and Wildlife Research 14:1–26.
Morales NM, Matthews HB. 1979. In vivo binding of 2,3,6,2’,3’,6’-hexachlorobiphenyl and 2,4,5,2’,4’,5’-hexachlorobiphenyl to mouse liver macromolecules. Chem Biol Interact 27:99–110.113111
*Morgan RW, Ward JM, Hartman PE. 1981. Aroclor 1254-induced intestinal metaplasia and adenocarcinoma in the glandular stomach of F344 rats. Cancer Res 41:5052–5059.6796264
Morita M, Nakagawa J, Rappe C. 1978. Polychlorinated dibenzofuran (PCDF) formation from PCB mixture by heat and oxygen. Bull Environ Contam Toxicol 19:665–670.98186
*Morris PJ, Mohn WW, Quensen JF III, . 1992. Establishment of polychlorinated biphenyl-degrading enrichment culture with predominantly meta dechlorination. Appl Environ Microbiol 58(9):3088–3094.1444423
*Morris S, Lester JN. 1994. Behaviour and fate of polychlorinated biphenyls in a pilot wastewater. Water Res 28(7):1553–1561.
*Morrissey RE, Harris MW, Diliberto JJ, . 1992. Limited PCB antagonism of TCDD-induced malformations in mice. Toxicol Lett 60:19–25.1539179
Morse DC, Brouwer A. 1995. Fetal, neonatal, and long-term alterations in hepatic retinoid levels following maternal polychlorinated biphenyl exposure in rats. Toxicol Appl Pharmacol 131:175–182.7878673
*Morse DC, Plug A, Wesseling W, . 1996b. Persistent alterations in regional brain glial fibrillary acidic protein and synaptophysin levels following pre- and postnatal polychlorinated biphenyl exposure. Toxicol Appl Pharmacol 139:252–261.8806841
*Morse DC, Seegal RF, Borsch KO, . 1996a. Long-term alterations in regional brain serotonin metabolism following maternal polychlorinated biphenyl exposure in the rat. Neurotoxicology 17(3–4):631–638.9086483
*Morse DC, Wehler EK, Wesseling W, . 1996c. Alterations in rat brain thyroid hormone status following pre- and postnatal exposure to polychlorinated biphenyls (Aroclor 1254).
*Morse DC, Wehler EK, van de Pas M, . 1995. Metabolism and biochemical effects of 3,3’,4,4’-tetrachlorobiphenyl in pregnant and fetal rats. Chem Biol Interact 95(1–2):41–56.7697753
*Morselli L, Brocco D, Pirni A. 1985. The presence of polychlorodibenzo-p-dioxins (PCDDs), polychlorodibenzofurans (PCDFs), and polychlorobiphenyls (PCBs) in fly ashes from various municipal incinerators under different technological and working conditions. Ann Chim 75:59–64.
*Morselli L, Zappoli S, Liberti A, . 1989. Evaluation and comparison of organic and inorganic compounds between emission and emission samples from municipal solid waste incinerator. Chemosphere 18:2263–2273.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
*Moslen MT, Reynolds ES, Szabo S. 1977. Enhancement of the metabolism and hepatotoxicity of trichloroethylene and perchloroethylene. Biochem Pharmacol 26:369–375.192239
Moya J, Garrahan KG, Poston TM, . 1998. Effects of cooking on levels of PCBs in the fillets of winter flounder. Bull Environ Contam Toxicol 60:845–851.9606259
*Moysich KB, Ambrosone CB, Vena JE, . 1998. Environmental organochlorine exposure and postmenopausal breast cancer risk. Cancer Epidemiol Biomarkers Prev 7(3):181–188.9521429
*Moysich KB, Shields PG, Freudenheim JL, . 1999. Polychlorinated biphenyls, cytochrome P4501A1 polymorphism, and postmenopausal breast cancer risk. Cancer Epidemiol Biomarkers Prev 8:41–44.9950238
*Moza P, Weisgerber I, Klein W. 1976. Fate of 2,2’-dichlorobiphenyl-^14^C in carrots, sugar beets, and soil under outdoor conditions. J Agric Food Chem 24(4):881–885.821985
*Mühlebach S, Bickel MH. 1981. Pharmacokinetics in rats 2,4,5,2’,4’,5’,-hexachlorobiphenyl, an unmetabolizable lipophilic model compound. Xenobiotica 11(4):249–257.6795836
*Muir DCG, Ford CA, Rosenberg B, . 1996b. Persistent organochlorines in beluga whales (delphinapterus leucas) from the St. Lawrence River estuary-I. Concentrations and patterns of specific PCBs, chlorinated pesticides and polychlorinated dibenzo-p-dioxins and dibenzofurans. Environ Pollut 93(2):219–234.15091361
*Muir DCG, Koczanski K, Rosenberg B, . 1996a. Persistent organochlorines in beluga whales (delphinapterus leucas) from the St. Lawrence River estuary-II. Temporal trends, 1982-1994. Environ Pollut 93(2):235–245.15091362
*Mullin MD, Pochini CM, McCrindle S, . 1984. High-resolution PCB analysis: Synthesis and chromatographic properties of all 209 PCB congeners. Environ Sci Technol 18:468–476.22247951
Mulvad G, Pedersen HS, Hansen JC, . 1996. Exposure of Greenlandic Inuit to organochlorines and heavy metals through the marine food chain: an international study. Sci Total Environ 186(½):137–139.8685705
*Murk AJ, Boudewijn TJ, Meininger PL, . 1996. Effects of polyhalogenated aromatic hydrocarbons and related contaminants on common tern reproduction: Integration of biological, biochemical, and chemical data. Arch Environ Contam Toxicol 31:128–140.8688000
*Murphy MJ, Piper LJ, Fasco MJ, . 1979. Potentiation of fluoroxene (2,2,2-trifluoroethyl vinyl ether) toxicity with polychlorinated biphenyls. Toxicol Appl Pharmacol 48:87–97.36687
*Murphy TJ, Formanski LJ, Brownawell B, . 1985. Polychlorinated biphenyl emissions to the atmosphere in the Great Lakes region. Municipal landfills and incinerators. Environ Sci Technol 19:924–946.
*Murphy TJ, Mullin MD, Meyer JA. 1987. Equilibration of polychlorinated biphenyls and toxaphene with air and water. Environ Sci Technol 21:155–162.
Murray HE, Ray LE, Giam CS. 1981. Phthalic acid esters, total DDTs and polychlorinated biphenyls in marine samples from Galveston Bay, Texas. Bull Environ Contam Toxicol 26:769–774.6789916
*Mussalo-Rauhamaa H, Hasanen E, Pyysalo H, . 1990. Occurrence of beta-hexachlorocyclohexane in breast cancer patients. Cancer 66:2124–2128.1699651
*Nagayama J, Okamura K, Iida T, . 1998a. Postnatal exposure to chlorinated dioxins and related chemicals on thyroid hormone status in Japanese breast fed infants. Chemosphere 37:1789–1793.9828307
Nagayama J, Tsuji H, Iida T, . 1998b. Postnatal exposure to chlorinated dioxins and related chemicals on lymphocyte subsets in Japanese breast-fed infants. Chemosphere 37:1781–1787.9828306
*Nakanishi Y, Shigematsu N, Kurita Y, . 1985. Respiratory involvement and immune status in Yusho patients. Environ Health Perspect 59:31–36.3921360
Napolitano GE, Richmond JE. 1995. Enrichment of biogenic lipids, hydrocarbons and PCBs in stream-surface foams. Environ Toxicol Chem 14(2):197–201.
Narayanan PK, Carter WO, Ganey PE, . 1998. Impairment of human neutrophil oxidative burst by polychlorinated biphenyls: inhibition of superoxide dismutase activity. J Leukoc Biol 63(2):216–224.9468280
*Narbonne JF, Gillet G, Daubeze M. 1978. [Effect of polychlorinated biphenyls in the rat: I. -- relation tissue level dose (author’s transl)]. Toxicological European Research 1(3):145–52.105424
NAS/NRC. 1980. National Academy of Sciences/National Research Council. Drinking water and health. Volume 3. Washington, DC: National Academy Press, 133.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
Nath RG, Randerath E, Randerath K. 1991. Short-term effects of the tumor promoting polychlorinated biphenyl mixture, Aroclor 1254, on I-compounds in liver, kidney and lung DNA of male Sprague-Dawley rats. Toxicology 68:275–289.1896999
NATICH. 1992. National Air Toxics Information Clearinghouse. Report on state, local, and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. December 1992.
Navas JM, Segner H. 1998. Antiestrogenic activity of anthropogenic and natural chemicals. Environ Sci Pollut Res Int 5(2):75–82.19005814
*NCI. 1978. Bioassay of Aroclor 1254 for possible carcinogenicity. NCI-GC-TR-38. Bethesda, MD: National Cancer Institute. NTIS PB279624.
Nebert DW, Adesnik M, Coon MJ, . 1987. The P450 gene superfamily: Recommended nomenclature. DNA 6:1–11.3829886
*Needham LL, Burse VW, Price HA. 1981. Temperature-programmed gas chromatographic determination of polychlorinated and polybrominated biphenyls in serum. J Assoc Off Anal Chem 64:1131–1137.6270054
*Needham LL, Smrek AL, Head SL, . 1980. Column chromatography separation of polychlorinated biphenyls from dichlorodiphenyltrichloroethane and metabolites. Anal Chem 52:2227–2229.
Neely WB. 1977. A material balance study of polychlorinated biphenyls in Lake Michigan. Sci Total Environ 7:117–129.402690
*Nelson ED, McConnell LL, Baker JE. 1998. Diffusive exchange of gaseous polycyclic aromatic hydrocarbons and polychlorinated biphenyls across the air-water interface of the Chesapeake Bay. Environ Sci Technol 32(7):912–919.
*Nelson NN, Hammond PB, Nisbet ICT, . 1972. PCBs - environmental impact. Environ Res 5:249–362.4628373
*Nesaretnam K, Darbre P. 1997. 3,5,3’,5’-Tetrachlorobiphenyl is a weak oestrogen agonist in vitro and in vivo. J Steroid Biochem Mol Biol 62(5–6):409–418.9449244
*Nesaretnam K, Corcoran D, Dils RR, . 1996. 3,4,3’,4’-Tetrachlorobiphenyl acts as an estrogen in vitro and in vivo. Mol Endocrinol 10:923–936.8843409
Ness DK, Schantz SL, Hansen LG. 1994. PCB congeners in the rat brain: Selective accumulation and lack of regionalization. J Toxicol Environ Health 43:453–468.7990170
*Ness DK, Schantz SL, Moshtaghian J, . 1993. Effects of perinatal exposure to specific PCB congeners on thyroid hormone concentrations and thyroid histology in the rat. Toxicol Lett 68:311–323.8516785
*Newman JW, Becker JS, Blondina G, . 1998. Quantitation of Aroclors using congener-specific results. Environ Toxicol Chem 17(11):2159–2167.
*Newman JW, Vedder J, Jarman WM, . 1994. A method for the determination of environmental contaminants in living marine mammals using microscale samples of blubber and blood. Chemosphere 28(10):1795–1805.
*Newsome WH, Ryan JJ. 1999. Toxaphene and other chlorinated compounds in human milk from northern and southern Canada: A comparison. Chemosphere 39(3):519–526.10399849
*Newsome WH, Davies D, Doucet J. 1995. PCB and organochlorine pesticides in Canadian human milk-1992. Chemosphere 30(11):2143–2153.7620848
*NFPA. 1994. National Fire Protection Association. Hazardous chemicals data.
*Nhan DD, Am NM, Hoi NC, . 1998. Organochlorine pesticides and PCBs in the Red River Delta, North Vietnam. Mar Pollut Bull 36(9):742–749.
*Nicholson WJ, Landrigan PJ. 1994. Human health effects of polychlorinated biphenyls. In: Schecter A, ed. Dioxins and health. New York, NY: Plenum Press, 487–524.
Nicola RM, Branchflower R, Pierce D. 1987. Chemical contaminants in bottomfish. J Environ Health 49:342–347.
*Nies L, Vogel TM. 1990. Effects of organic substrates on dechlorination of Aroclor 1242 in anaerobic sediments. Appl Environ Microbiol 56:2612–2617.16348270
*Nies L, Vogel TM. 1991. Identification of the proton source for the microbial reductive dechlorination of 2,3,4,5,6-pentachlorobiphenyl. Appl Environ Microbiol 57(9):2771–2774.16348557
*Nilsson B, Ramel C. 1974. Genetic tests on drosophila melanogaster with polychlorinated biphenyls (PCB). Hereditas 77:319–322.4217330
*Nims RW, Beebe LE, Dragnev KH, . 1992. Induction of hepatic CYP1A in male F344/NCr rats by dietary exposure to Aroclor 1254: Examination of immunochemical, RNA, catalytic, and pharmacokinetic endpoints. Environ Res 59(2):447–466.1281448
Nims RW, Fox SD, Issaq HJ, . 1994. Accumulation and persistence of individual polychlorinated biphenyl congeners in liver, blood, and adipose tissue of rats following dietary exposure to Aroclor® 1254. Arch Environ Contam Toxicol 27:513–520.7811109
*NIOSH. 1977. Criteria for a recommended standard: Occupational exposure to polychlorinated biphenyls (PCBs). Rockville Md: U.S. Department of Health, Education and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. NIOSH publ. 77-225.
*NIOSH. 1984a. NIOSH manual of analytical methods. Vol. 1: Method no. 5503. 3rd ed. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1984b. NIOSH manual of analytical methods. Vol. 1: Method no. 8004. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
NIOSH. 1986. National Institute for Occupational Safety and Health. Mortality of workers exposed to polychlorinated biphenyls: An update. NTIS PB86-206000.
*NIOSH. 1987a. Registry of toxic effects of chemical substances. Vol. 4. 1985-86 ed. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 3687.
NIOSH. 1987b. Health hazard evaluation report: Jacksonville Fire Department, Jacksonville, Florida. Cincinnati, OH: National Institute for Occupational Safety and Health, Hazard Evaluations and Technical Assistance Branch. HETA 84-180-1776.
*NIOSH. 1989. National occupational exposure survey as of 08/29/89. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 134, 142, 184.
*NIOSH. 1990. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health, Cincinnati, OH.
*NIOSH. 1991. Health hazard evaluation report. Westinghouse Electric Corporation, Bloomington, Indiana. Cincinnati, OH: Hazard Evaluations and Technical Assistance Branch, National Institute for Occupational Safety and Health. HETA 89-116-2094.
*NIOSH. 1992. NIOSH recommendations for occupational safety and health compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Division of Standards Development and Technology Transfer. NIOSH 92-100, B92, 162, 536.
*NIOSH. 1997. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute of Occupational Safety and Health.
*NIOSH. 2000. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute of Occupational Safety and Health. Http://www.cdc.gov/niosh/npg/.
*Nisbet ICT, Fry DM, Hatch JJ, . 1996. Feminization of male common tern embryos is not correlated with exposure to specific PCB congeners. Bull Environ Contam Toxicol 57:895–901.8875836
*Nishida N, Farmer JD, Kodavanti PRS, . 1997. Effects of acute and repeated exposures to Aroclor 1254 in adult rats: Motor activity and flavor aversion conditioning. Fundam Appl Toxicol 40:68–74.9398489
*Nishizumi M. 1976. Radioautographic evidence for absorption of polychlorinated biphenyls through the skin. Ind Health 14:41–44.
Nishizumi M. 1980. Reduction of diethylnitrosamine-induced hepatoma in rats exposed to polychlorinated biphenyls through their dams. Gann 71:910–912.6791983
NOAA. 1988. PCB and chlorinated pesticide contamination in U.S. fish and shellfish: A historical assessment report. Seattle, WA: National Oceanic and Atmospheric Administration. NOAA Technical Memorandum NOS OMA 39.
*Norback DH, Weltman RH. 1985. Polychlorinated biphenyl induction of hepatocellular carcinoma in the Sprague-Dawley rat. Environ Health Perspect 60:97–105.3928368
*Norback DH, Seymour JL, Knieriem KM, . 1976. Biliary metabolites of 2,5,2’,5’-tetrachlorobiphenyl in the rat. Res Commun Chem Pathol Pharmacol 14:527–533.822484
*Noren K, Lunden A, Pettersson E, . 1996. Methylsulfonyl metabolites of PCBs and DDE in human milk in Sweden, 1972-1992. Environ Health Perspect 104(7):766–772.8841763
*Noren K, Weistrand C, Karpe F. 1999. Distribution of PCB congeners, DDE, hexachlorobenzene, and methylsulfonyl metabolites of PCB and DDE among various fractions of human blood plasma. Arch Environ Contam Toxicol 37:408–414.10473799
*Norena-Barroso E, Zapata-Perez O, Ceja-Moreno V, . 1998. Hydrocarbon and organochlorine residue concentrations in sediment from Bay of Chetumal, Mexico. Bull Environ Contam Toxicol 61:80–87.9657834
*NRC. 1991. National Research Council. Animals as sentinels of environmental health hazards. Washington, DC: National Academy Press.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
NTP. 1989. National Toxicology Program. Fifth annual report on carcinogens: Summary 1989. Research Triangle Park, NC: U.S. Department of Health and Human Service, Public Health Service, 239–242. NTP 89-239.
NTP. 1995. National Toxicology Program. Management status report. Research Triangle Park, NC: Division of Toxicology Research and Testing, National Institute of Environmental Health and Sciences.
NTP. 1998. National Toxicology Program. Eighth annual report on carcinogens. Summary 1998. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program, 176–178.
*NTP. 2000. National Toxicology Program. Ninth annual report on carcinogens. http://ehis.niehs.nih.gov/roc/toc9.html
Nyhan WL. 1961. Toxicity of drugs in the neonatal period. J Pediatr 59:1–20.13729971
*Oakley GG, Devanaboyina U, Robertson LW, . 1996. Oxidative DNA damage induced by activation of polychlorinated biphenyls (PCBs): Implications for PCB-induced oxidative stress in breast cancer. Chem Res Toxicol 9:1285–1292.8951230
*Oatman L, Roy R. 1986. Surface and indoor air levels of polychlorinated biphenyls in public buildings. Bull Environ Contam Toxicol 37:461–466.3091120
*Ockenden WA, Prest HF, Thomas GO, . 1998. Passive air sampling of PCBs: Field calculation of atmospheric sampling rates by triolein-containing semipermeable membrane devices. Environ Sci Technol 32:1538–1543.
*O’Connor GA, Kiehl D, Eiceman GA, . 1990. Plant uptake of sludge-borne PCBs. J Environ Qual 19:113–118.
*Oda H, Yoshida A. 1994. Effect of feeding xenobiotics on serum high density lipoprotein and apolipoprotein A-I in rats. Biosci Biotechnol Biochem 58:1646–1651.
*Oehme M, Mano S, Mikalsen A. 1987. Formation and presence of polyhalogenated and polycyclic compounds in the emissions of small and large scale municipal waste incinerators. Chemosphere 16:143–153.
*Oesterle D, Deml E. 1983. Promoting effect of polychlorinated biphenyls on development of enzyme-altered islands in livers of weanling and adult rats. J Cancer Res Clin Oncol 105:141–147.6402515
*Oesterle D, Deml E. 1984. Dose-dependent promoting effect of polychlorinated biphenyls on enzyme-altered islands in livers of adult and weanling rats. Carcinogenesis 5:351–355.6142772
*Offenberg JH, Baker JE. 1997. Polychlorinated biphenyls in Chicago precipitation: Enhanced wet deposition to near-shore Lake Michigan. Environ Sci Technol 31(5):1534–1538.
*Offenberg JH, Baker JE. 1999. Influence of Baltimore’s urban atmosphere on organic contaminants over the northern Chesapeake Bay. J Air Waste Manage Assoc 49:959–965.
*Ofjord GD, Puhakka JA, Ferguson JF. 1994. Reductive dechlorination of Aroclor 1254 by marine sediment cultures. Environ Sci Technol 28:2286–2294.22176046
*Ohnishi Y, Kohno T. 1979. Polychlorinated biphenyls poisoning in monkey eye. Invest Ophthalmol Vis Sci 18:981–984.113362
*Ohsaki Y, Matsueda T. 1994. Levels, features and a source of non-ortho coplanar polychlorinated biphenyl in soil. Chemosphere 28(1):47–56.
*Okey AB, Riddick DS, Harper PA. 1994. The Ah receptor: Mediator of the toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and related compounds. Toxicol Lett 70(1):1–22.8310450
*Oliver BG, Bourbonniere RA. 1985. Chlorinated contaminants in surficial sediments of lakes Huron, St. Clair, and Erie: Implications regarding sources along the St. Clair and Detroit rivers. J Great Lakes Res 11:366–372.
*Oliver BG, Niimi AJ. 1985. Bioconcentration factors of some halogenated organics for rainbow trout: Limitations in their use for prediction of environmental residues. Environ Sci Technol 19:842–849.22196610
*Oliver BG, Niimi AJ. 1988. Trophodynamic analysis of polychlorinated biphenyl congeners and other chlorinated hydrocarbons in the Lake Ontario ecosystem. Environ Sci Technol 22:388–397.
*Oliver BG, Charlton MN, Durham RW. 1989. Distribution, redistribution, and geochronology of polychlorinated biphenyl congeners and other chlorinated hydrocarbons in Lake Ontario sediments. Environ Sci Technol 23:200–208.
*Olivero J, Ganey PE. 2000. Role of protein phosphorylation in activation of phospholipase A_2_ by the polychlorinated biphenyl mixture aroclor 1242. Toxicol Appl Pharmacol 163:9–16.10662600
*Oloffs PC, Albright LJ, Szeto SY. 1972. Fate and behavior of five chlorinated hydrocarbons in three natural waters. Can J Microbiol 18:1393–1398.4116057
*Olsen SF, Olsen J, Frische G. 1990. Does fish consumption during pregnancy increase fetal growth? A study of the size of the newborn, placental weight and gestatational age in relation to fish consumption during pregnancy. Int J Epidemiol 19(4):971–977.2084030
*Olsson M, Karlsson B, Ahnland E. 1994. Diseases and environmental contaminants in seals form the Baltic and the Swedish west coast. Sci Total Environ 154:217–227.7973608
*Omara FO, Flipo D, Brochu C, . 1998. Lack of suppressive effects of mixtures containing low levels of methylmercury (MeHg), polychlorinated dibenzo-p-dioxins (PCDDS), polychlorinated dibenzofurans (PCDFS), and aroclor biphenyls (PCBS) on mixed lymphocyte reaction, phagocytic, and natural killer cell activities of rat leukocytes in vitro. J Toxicol Environ Health A54:561–577.
*O’Neill HJ, Pollock TL, Brun GL, . 1992. Toxic chemical survey of municipal drinking water sources in Atlantic Canada 1985-1988. Wat Pollut Res J 27(4):715–732.
*Oremland RS. 1988. Biogeochemistry of methanogenic bacteria. In: Zehnder AJB, ed. Biology of anaerobic microorganisms. New York, NY: John Wiley & Sons, 641–705.
*Orris P, Kominsky JR, Hryhorczyk D, . 1986. Exposure to polychlorinated biphenyls from an overheated transformer. Chemosphere 15:1305–1311.
OSHA. 1974. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910. 1000.
OSHA. 1997a. U.S. Department of Labor. Occupational Safety and Health Administration. Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. 29 CFR 1915.1000.
OSHA. 1997b. U.S. Department of Labor. Occupational Safety and Health Administration. Safety and health regulations for construction. Gases, vapors; fumes, dusts, and mists. Code of Federal Regulations. 29 CFR 1926.55.
*OSHA. 1998a. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1998b. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000.
*OSHA. 1998c. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55.
*Osius N, Karmaus W, Kruse H, . 1999. Exposure to polychlorinated biphenyls and levels of thyroid hormones in children. Environ Health Perspect 107(10):843–849.10504153
*Osowski SL, Brewer LW, Baker OE, . 1995. The decline of mink in Georgia, North Carolina, and South Carolina: The role of contaminants. Arch Environ Contam Toxicol 29(3):418–423.7487161
OSTP. 1985. Office of Science and Technology Policy. Chemical carcinogens; A review of the science and its associated principles, February 1985. Federal Register 50(50):10372–10381.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
*Ouw HK, Simpson GR, Siyali DS. 1976. Use and health effects of Aroclor 1242, a polychlorinated biphenyl, in an electrical industry. Arch Environ Health 31:189–194.821401
*Overmann SR, Kostas J, Wilson LR, . 1987. Neurobehavioral and somatic effects of perinatal PCB exposure in rats. Environ Res 44:56–70.3115773
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Pal D, Weber JB, Overcash MR. 1980. Fate of polychlorinated biphenyls (PCBs) in soil-plant systems. Residue Reviews 74:45–98.6776596
*Paneth N. 1991. Human reproduction after eating PCB-contaminated fish. Health Environ Digest 5:4–6.
Paneth N. 1996. Adopting a public health approach to developmental neurotoxicity. Neurotoxicol Teratol 18(3):233–234.8725630
*Panshin SY, Hites RA. 1994. Atmospheric concentrations of polychlorinated biphenyls at Bloomington, Indiana. Environ Sci Technol 28:2008–2013.22191739
*Pantaleoni G, Fanini D, Sponta AM, . 1988. Effects of maternal exposure to polychlorobiphenyls (PCBs) on F1 generation behavior in the rat. Fundam Appl Toxicol 11:440–449.3146520
*Pappas BA, Murtha SJE, Park GAS, . 1998. Neurobehavioral effects of chronic ingestion of Great Lakes chinook salmon. Regul Toxicol Pharmacol 27:S55–S67.9618334
*Pardue JH, Delaune RD, Patrick WH. 1988. Effect of sediment of pH and oxidation-reduction potential on PCB mineralization. Water Air Soil Pollut 37:439–447.
*Parham FM, Portier CJ. 1998. Using structural information to create physiologically based pharmacokinetic models for all polychlorinated biphenyls. II-Rates of metabolism. Toxicol Appl Pharmacol 151(1):110–116.9705893
*Parham FM, Kohn MC, Matthews HB, . 1997. Using structural information to create physiologically based pharmacokinetic models for all polychlorinated biphenyls. Toxicol Appl Pharmacol 144(2):340–347.9194418
*Paris DF, Steen WC, Baughman GL. 1978. Role of the physico-chemical properties of Aroclors 1016 and 1242 in determining their fate and transport in aquatic environments. Chemosphere 7:319–325.
Parkinson A, Robertson L, Safe L, . 1980. Polychlorinated biphenyls as inducers of hepatic microsomal enzymes: Structure-activity rules. Chem Biol Interact 30:271–285.6769597
Parkinson A, Safe SH, Robertson LW, . 1983. Immunochemical quantitation of cytochrome P-450 isozymes and epoxide hydrolase in liver microsomes from polychlorinated or polybrominated biphenyl-treated rats. J Biol Chem 258:5967–5976.6304102
*Patandin S, Koopman-Esseboom C, De Ridder MAJ, . 1998. Effects of environmental exposure to polychlorinated biphenyls and dioxins on birth size and growth in Dutch children. Pediatr Res 44(4):538–545.9773843
*Patandin S, Lanting CI, Mulder PGH, . 1999. Effects of environmental exposure to polychlorinated biphenyls and dioxins on cognitive abilities in Dutch children at 42 months of age. J Pediatr 134:33–41.9880446
*Patandin S, Weiglas-Kuperus N, de Ridder MAJ, . 1997. Plasma polychlorinated biphenyl levels in Dutch preschool children either breast-fed or formula-fed during infancy. Am J Public Health 87:1711–1714.9357362
*Paterson S, Mackay D, Tam D, . 1990. Uptake of organic chemicals by plants: A review of processes, correlations and models. Chemosphere 21(3):297–331.
*Patnode KA, Curtis LR. 1994. 2,2’,4,4’,5,5’- and 3,3’,4,4’,5,5’-Hexachlorobiphenyl alteration of uterine progesterone and estrogen receptors coincides with embryotoxicity in mink (mustela vison). Fundam Appl Toxicol 127:9–18.
*Patterson DG Jr., Lapeza CR, Barnhart ER, . 1989. Gas chromatographic/mass spectrometric analysis of human serum for non-ortho (coplanar) and ortho substituted polychlorinated biphenyls using isotope-dilution mass spectrometry. Chemosphere 19:127–134.
*Patterson DG Jr., Todd GD, Turner WE, . 1994. Levels of non-ortho-substituted (coplanar), mono- and di-ortho-substituted polychlorinated biphenyls, dibenzo-p-dioxins, and dibenzofurans in human serum and adipose tissue. Environ Health Perspect Suppl 102(1):195–204.
*Pauwels A, Covaci A, Delbeke L, . 1999. The relation between levels of selected PCB congeners in human serum and follicular fluid. Chemosphere 39(14):2433–2441.10581696
*Peakall DB, Lincer JL, Bloom SE. 1972. Embryonic mortality and chromosomal alterations caused by Aroclor 1254 in ring doves. Environ Health Perspect 1:103–104.17539068
*Pearson RF, Hornbuckle KC, Eisenreich SJ, . 1996. PCBs in Lake Michigan water revisited. Environ Sci Technol 30(5):1429–1436.
*Pellettieri MB, Hallenbeck WH, Brenniman GR, . 1996. PCB intake from sport fishing along the northern Illinois shore of Lake Michigan. Bull Environ Contam Toxicol 57(5):766–770.8791552
*Peng J, Singh A, Ireland WP, . 1997. Polychlorinated biphenyl congener 153-induced ultrastructural alterations in rat liver: a quantitative study. Toxicology 120:171–183.9217304
*Pereira MA, Herren SL, Britt AL, . 1982. Promotion by polychlorinated biphenyls of enzyme-altered foci in rat liver. Cancer Lett 15:185–190.6124313
*Pereira WE, Hostettler FD, Cashman JR, . 1994. Occurrence and distribution of organochlorine compounds in sediment and livers of striped bass (morone saxatilis) from the San Francisco Bay-Delta Estuary. Mar Pollut Bull 28(7):434–441.
*Perkins JL, Knight VB. 1989. Risk assessment of dermal exposure to polychlorinated biphenyls permeating a polyvinyl chloride glove. Am Ind Hyg Assoc J 50:A171–A172.2497629
Petersen GI, Kristensen P. 1998. Bioaccumulation of lipophilic substances in fish early life stages. Environ Toxicol Chem 17(7):1385–1395.
*Pham TT, Proulx S. 1997. PCBs and PAHs in the Montreal urban community (Quebec, Canada) wastewater treatment plant and in the effluent plume in the St. Lawrence River. Water Res 31(8):1887–1896.
Phaneuf D, DesGranges JL, Plante N, . 1995. Contamination of local wildlife following a fire at a polychlorinated biphenyls warehouse in St. Basile le Grand, Quebec, Canada. Arch Environ Contam Toxicol 28:145–153.7710287
*Phillips DL, Pirkle JL, Burse VW, . 1989b. Chlorinated hydrocarbon levels in human serum: Effects of fasting and feeding. Arch Environ Contam Toxicol 18:495–500.2505694
*Phillips DL, Smith AB, Burse VW, . 1989a. Half-life of polychlorinated biphenyls in occupationally exposed workers. Arch Environ Health 44:351–354.2514628
*Phillips WEJ, Hatina G, Villeneuve DC, . 1972. Effect of parathion administration in rats following long term feeding with PCB’s. Environ Physiol Biochem 2:165–169.
*Pines A, Cucos S, Ever-Hadani P, . 1987. Some organochlorine insecticide and polychlorinated biphenyl blood residues in infertile males in the general Israeli population of the middle 1980’s. Arch Environ Contam Toxicol 16:587–597.3115197
*Pintar JE. 2000. Normal development of the hypothalamic-pituitary-thyroid axis. In: Braverman LE, Utiger RD, ed. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott-Raven, 7–19.
*Platanow NS, Karstad LH. 1973. Dietary effects of polychlorinated biphenyls on mink. Can J Comp Med 37:391–400.4270810
Pohl H, Holler J. 1995. Halogenated aromatic hydrocarbons and toxicity equivalency factors (TEFs) from the public health assessment perspective. Chemosphere 31(1):2547–2559.7670866
Poland A, Glover E. 1977. Chlorinated biphenyl induction of aryl hydrocarbon hydroxylase activity: A study of the structure-activity relationship. Mol Pharmacol 13:924–938.408602
*Poland A, Knutson JC. 1982. 2,3,7,8-Tetrachlorodibenzo-p-dioxin and related halogenated aromatic hydrocarbons. Examinations of the mechanisms of toxicity. Annu Rev Pharmacol Toxicol 22:57–end 6282189
*Poland A, Glover E, Kende AS. 1976. Stereospecific, high affinity binding of 2,3,7,8-tetrachlorodibenzo-p-dioxin by hepatic cytosol: Evidence that the binding species is receptor for induction of aryl hydrocarbon hydroxylase. J Biol Chem 16:4936–4946.
*Poland A, Knutson J, Glover E, . 1983. Tumor promotion in the skin of hairless mice by halogenated aromatic hydrocarbons. In: Weinstein IB, Vogel HJ, eds. Genes and proteins in oncogenesis. New York, NY: Academic Press, 143–161.
*Polder A, Becher G, Savinova TN, . 1998. Dioxins, PCBs and some chlorinated pesticides in human milk from the Kola Peninsula, Russia. Chemosphere 37(9–12):1795–1806.9828308
*Poole KG, Elkin BT, Bethke RW. 1995. Environmental contaminants in wild mink in the Northwest Territories, Canada. Sci Total Environ 160–161:473–486.
*Poole KG, Elkin BT, Bethke RW. 1998. Organochlorine and heavy metal contaminants in wild mink in western Northwest Territories, Canada. Arch Environ Contam Toxicol 34(4):406–413.9543512
*Poon K-F, Lam PKS, Lam MHW. 1999. Determination of polychlorinated biphenyls in human blood serum by SPME. Chemosphere 39(6):905–912.10448565
*Porte C, Albaiges J. 1993. Bioaccumulation patterns of hydrocarbons and polychlorinated biphenyls in bivalves, crustaceans, and fishes. Arch Environ Contam Toxicol 26(3):273–281.
Porte C, Barcelo D, Albaiges J. 1988. Quantitation of total versus selected polychlorinated biphenyl congeners in marine biota samples. J Chromatogr 442:386–393.3138271
*Porterfield SP, Hendry LB. 1998. Impact of PCBs on thyroid hormone directed brain development. Toxicol Ind Health 14(½):103–120.9460172
*Portier RJ, Fujisaki K. 1988. Enhanced biotransformation and biodegradation of polychlorinated biphenyls in the presence of aminopolysaccharides. In: Adams WJ, Chapman GA, Landis WG eds. Aquatic toxicology and hazard assessment: 10^th^ volume. Philadelphia, PA: ASTM, 517–527.
*Preston BD, Miller JA, Miller EC. 1983. Non-arene oxide aromatic ring hydroxylation of 2,2’,5,5’-tetrachlorobiphenyl as the major metabolic pathway catalyzed by phenobarbital-induced rat liver microsomes. J Biol Chem 258:8304–8311.6408087
*Preston BD, Miller JA, Miller EC. 1984. Reactions of 2,2’,5,5’ -tetrachlorobiphenyl-3,4-oxide with methionine, cysteine and glutathione in relation to the formation of methylthio-metabolites of 2,2’,5,5’ - tetrachlorobiphenyl in the rat and mouse. Chem-Biol Ineract 50:289–312.
*Preston BD, Miller EC, Miller JA. 1985. The activities of 2,2’,5,5’-tetrachlorobiphenyl, its 3,4-oxide metabolite, and 2,2’,4,4’-tetrachlorobiphenyl in tumor induction and promotion assays. Carcinogenesis 6(3):451–453.2858273
*Preston BD, Van Miller JP, Moore RW, . 1981. Promoting effects of polychlorinated biphenyls (Aroclor 1254) and polychlorinated dibenzofuran-free Aroclor 1254 on diethylnitrosamine-induced tumorigenesis in the rat. J Natl Cancer Inst 66:509–515.6782318
Price HA, Welch RL. 1972. Occurrence of polychlorinated biphenyls in humans. Environ Health Perspect 1:73–78.17539091
*Price NO, Young RW, Dickinson JK. 1972. Pesticide residues and polychlorinated biphenyl levels in diets, urine, and fecal matter of preadolescent girls. Proc Soc Exp Biol Med 139:1280–1283.4623415
*Price SC, Ozalp S, Weaver R, . 1988. Thyroid hyperactivity caused by hypolipodaemic compounds and polychlorinated biphenyls: The effect of coadministration in the liver and thyroid. Arch Toxicol Suppl 12:85–92.
*Provost TL, Juarez De Ku LM, Zender C, . 1999. Dose- and age-dependent alterations in choline acetyltransferase (ChAT) activity, learning and memory, and thyroid hormones in 15- and 30-day old rats exposed to 1.25 or 12.5 ppm polychlorinated biphenyl (PCB) beginning at conception. Prog Neuro-Psychopharmacol Biol Psychiat 23:915–928.
*Pruell RJ, Rubinstein NI, Taplin BK, . 1993. Accumulation of polychlorinated organic contaminants from sediment by three benthic marine species. Arch Environ Contam Toxicol 24(3):290–297.
*Puhvel SM, Sakamoto M, Ertl DC, . 1982. Hairless mice as models for chloracne: A study of cutaneous changes induced by topical application of established chloracnegens. Toxicol Appl Pharmacol 64:492–503.6215744
*Qi M, Anderson M, Meyer S, . 1997. Contamination of PCB congeners in Bear Lake fish tissues, livers, and brains. Toxicol Environ Chem 61(1–4):147–161.
*Quazi S, Takahata M, Horio F, 1984. Hepatic 3-hydroxy-3-methylglutaryl coenzyme A reductase and cholesterol 7-α-hydroxylase activities in rats fed PCB. Nutr Rep Int 30(3):617627.
*Que Hee S, Ward JA, Tabor MW, . 1983. Screening method for Aroclor 1254 in whole blood. Anal Chem 55:157–160.6402952
*Quenson JF III, Boyd SA, Tiedje JM. 1990. Dechlorination of four commercial polychlorinated biphenyl mixtures (Aroclor) by anaerobic microoganisms from sediments. Appl Environ Microbiol 56(8):2360–2369.16348249
*Quensen JF III, Mousa MA, Boyd SA, . 1998. Reduction of aryl hydrocarbon receptor-mediated activity of polychlorinated biphenyl mixtures due to anaerobic microbial dechlorination. Environ Toxicol Chem 17(5):806–813.
*Quensen JF III, Tiedje JM, Boyd SA. 1988. Reductive dechlorination of polychlorinated biphenyls by anaerobic microorganisms from sediments. Science 242:752–754.17751997
Ramamoorthy K, Vyhlidal C, Wang F, . 1997. Additive estrogenic activities of a binary mixture of 2’,4’,6’-trichloro- and 2’,3’,4’,5’-tetrachloro-4-biphenylol. Toxicol Appl Pharmacol 147(1):93–100.9356311
Ramos L, Hernandez LM, Gonzalez MJ. 1997. Variation of PCB congener levels during lactation period and relationship to their molecular structure. Arch Environ Contam Toxicol 33(1):97–103.9216877
*Ramos L, Torre M, Laborda F, . 1998. Determination of polychlorinated biphenyls in soybean infant formulas by gas chromatography. J Chromatogr 823:365–372.
Rao CV, Banerji AS. 1988. Induction of liver tumors in male Wistar rats by feeding polychlorinated biphenyls (Aroclor 1260). Cancer Lett 39:59–67.3125961
*Rao CV, Banerji SA. 1993. Effect of polychlorinated biphenyls (Aroclor 1260) on histology of adrenal of rats. J Environ Biol 14:1–6.
*Rappe C, Buser HR. 1981. Occupational exposure to polychlorinated dioxins and dibenzofurans. ACS Symp Ser 149:319–342.
*Rappe C, Buser HR. 1989. Chemical and physical properties, analytical methods, sources and environmental levels of halogenated dibenzodioxins and dibenzofurans. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 71–102.
*Rappe C, Buser HR, Bosshardt HP. 1979. Dioxins, dibenzofurans, and other polyhalogenated aromatics: Production, use, formation, and destruction. Ann NY Acad Sci 320:1–18.287392
*Rathke DE, McRae G. 1989. 1987 report on Great Lakes water quality: Appendix B: Great Lakes water surveillance. Great Lakes Water Quality Board report to the International Joint Commission, Windsor, Ontario.
*Ray LE, Murray HE, Giam CS. 1983. Organic pollutants in marine samples from Portland, Maine. Chemosphere 12:1031–1038.
Ray S, Bailey M, Paterson G, . 1998. Comparative levels of organochlorine compounds in flounders from the northeast coast of Newfoundland and an offshore site. Chemosphere 36(10):2201–2210.9566296
*Reich S, Jimenez B, Marsili L, . 1999. Congener specific determination and enantiomeric ratios of chiral polychlorinated biphenyls in striped dolphins (stenella coeruleoalba) from the Mediterranean sea. Environ Sci Technol 33:1787–1793.
*Reid D, Fox JM. 1982. Polychlorinated biphenyl report: Old Forge, Lackawanna County. Pennsylvania Department of Health, Division of Environmental Health.
Requejo AG, West RH, Hatcher PG, . 1979. Polychlorinated biphenyls and chlorinated pesticides in soils of the Everglades national park and adjacent agricultural areas. Environ Sci Technol 13:931–935.
*Restum JC, Bursian SJ, Giesy JP, . 1998. Multigenerational study of the effects of consumption of PCB-contaminated carp from Saginaw Bay, Lake Huron, on mink. 1. Effects on mink reproduction, kit growth and survival, and selected biological parameters. J Toxicol Environ Health 54:343–375.
*Reynolds ES, Moslen MT, Szabo S, . 1975. Hepatotoxicity of vinyl chloride and 1,1-dichloroethylene. Am J Pathol 81:219–236.241261
*Rhee G-Y, Bush B, Bethoney CM, . 1993a. Reductive dechlorination of Aroclor 1242 in anaerobic sediments: Pattern, rate, and concentration dependence. Environ Toxicol Chem 12(6):1025–1032.
*Rhee GY, Bush B, Brown MP, . 1989. Anaerobic biodegradation of polychlorinated biphenyls in Hudson River sediments and dredged sediments in clay encapsulation. Water Res 23:957–964.
*Rhee G-Y, Sokol RC, Bush B, . 1993b. Long-term study of the anaerobic dechlorination of Aroclor 1254 with and without biphenyl enrichment. Environ Sci Technol 27(4):714–719.
*Rice DC. 1996. PCBs and behavioral impairment: Are there lessons we can learn from lead? Neurotoxicol Teratol 18(3):229–232.8725629
*Rice DC. 1997. Effect of postnatal exposure to a PCB mixture in monkeys on multiple fixed interval-fixed ratio performance. Neurotoxicol Teratol 19(6):429–434.9392778
*Rice DC. 1998. Effects of postnatal exposure of monkeys to a PCB mixture on spatial discrimination reversal and DRL performance. Neurotoxicol Teratol 20(4):391–400.9697965
Rice DC. 1999b. Behavioral impairment produced by low-level postnatal PCB exposure in monkeys. Environ Res 80:S113–S121.10092425
*Rice DC. 1999a. Effect of exposure to 3,3’,4,4’,5-pentachlorobiphenyl (PCB 126) throughout gestation and lactation on development and spatial delayed alternation performance in rats. Neurotoxicol Teratol 21(1):59–69.10023802
*Rice DC. 2000. Parallels between attention deficit hyperactivity disorder and behavioral deficits produced by neurotoxic exposure in monkeys. Environ Health Perspect Suppl 108(3):405–408.
*Rice DC, Hayward S. 1997. Effects of postnatal exposure to a PCB mixture in monkeys on nonspatial discrimination reversal and delayed alternation performance. Neurotoxicology 18(2):479–494.9291496
*Rice DC, Hayward S. 1998. Lack of effect of 3,3’,4,4,5-pentachlorobiphenyl (PCB 126) throughout gestation and lactation on multiple fixed interval-fixed ration and DRL performance in rats. Neurotoxicol Teratol 20(6):645–650.9831126
*Rice DC, Hayward S. 1999b. Effects of exposure to 3,3’,4,4’,5-pentachlorobiphenyl (PCB 126) throughout gestation and lactation on behavior (concurrent random interval-random interval and progressive ratio performance) in rats. Neurotoxicol Teratol 21(6):679–687.10560775
*Rice DC, Hayward S. 1999a. Effects of postnatal exposure of monkeys to a PCB mixture on concurrent random interval-random interval and progressive ratio performance. Neurotoxicol Teratol 21(1):47–58.10023801
Rice RH, Cohen DE. 1996. Toxic responses of the skin. In: Klaassen CD, ed. Cassarett and Doull’s toxicology: The basic science of poisons. New York, NY: McGraw-Hill, 529–546.
*Rickenbacher U, McKinney JD, Oatley SJ, . 1986. Structurally specific binding of halogenated biphenyls to thyroxine transport protein. J Med Chem 29:641–648.3009810
*Ridgway S, Reddy M. 1995. Residue levels of several organochlorines in tursiops truncatus milk collected at varied stages of lactation. Mar Poll Bull 30(9):609–614.
*Ringer RK, Aulerich RJ, Bleavins MR. 1981. Biological effects of PCBs and PBBs on mink and ferrets: A review. In: Khan MAQ, ed. Toxicology of halogenated hydrocarbons: Health and ecological effects. Elmsford, NY: Pergamon Press, 329–343.
*Risebrough RW. 1999. ‘Endocrine disruption’ and the ‘wildlife connection’. Human and Ecological Risk Assessment 5(5):869–883.
*Risebrough RW, Anderson DW. 1975. Some effects of DDE and PCB on mallards and their eggs. J Wildl Manage 39(3):508–513.
*Robbiano L, Pino A. 1981. Induction in rats of liver DNA single-strand breaks by the polychlorinated biphenyl Aroclor 1254. Boll Soc Ital Biol Sper 57:407–413.6786308
*Robertson LW, Gupta RC. 2000. Metabolism of polychlorinated biphenyls (PCBs) generates electrophiles and reactive oxygen species that damage DNA. In: Williams GM, Aruoma OI, eds. Molecular drug metabolism and toxicology. OICA International, 1–19.
Robertson LW, Parkinson A, Bandiera S, . 1984. PCBs and PBBs: Biologic and toxic effects on C57BL/6J and DBA/2J inbred mice. Toxicology 31:191–206.6330936
*Robinson GK, Lenn MJ. 1994. The bioremediation of polychlorinated biphenyls (PCBs): Problems and perspectives. Biotechnol Genet Eng Rev 12:139–188.7727027
Rodgers JA Jr. 1997. Pesticide and heavy metal levels of waterbirds in the Everglades agricultural area of South Florida. Florida Field Naturalist 25(2):33–41.
*Rodgers PW, Swain WR. 1983. Analysis of polychlorinated biphenyl (PCB) loading trends in Lake Michigan. J Great Lakes Res 9:548–558.
*Rodriguez J, Kholkute SD, Dukelow WR. 1997. Reproductive toxicology of 3,3’,4,4’-tetrachlorobiphenyl in mice. Bull Environ Contam Toxicol 58:999–1005.9136666
*Rogan WJ. 1989. Yu-Cheng. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 401–415.
*Rogan WJ, Gladen BC. 1991. PCBs, DDE, and child development at 18 and 24 months. Ann Epidemiol 1(5):407–413.1669521
*Rogan WJ, Gladen BC. 1992. Neurotoxicology of PCBs and related compounds. Neurotoxicology 13:27–36.1508429
*Rogan WJ, Gladen BC, Guo Y-LL, . 1999. Sex ratio after exposure to dioxin-like chemicals in Taiwan. Lancet 353:206–207.
*Rogan WJ, Gladen BC, Hung K-L, . 1988. Congenital poisoning by polychlorinated biphenyls and their contaminants in Taiwan. Science 241:334–336.3133768
*Rogan WJ, Gladen BC, McKinney JD, . 1986a. Neonatal effects of transplacental exposure to PCBs and DDE. J Pediatr 109:335–341.3090217
*Rogan WJ, Gladen BC, McKinney JD, . 1986b. Polychlorinated biphenyls (PCBs) and dichlorophenyl dichloroethene (DDE) in human milk: Effects of maternal factors and previous lactation. Am J Public Health 76:172–177.3080910
*Rogan WJ, Gladen BC, McKinney JD, . 1987. Polychlorinated biphenyls (PCBs) and dichlorodiphenyl dichloroethane (DDE) in human milk: Effects on growth, morbidity, and duration of lactation. Am J Public Health 77:1294–1297.3115123
*Roose P, Cooreman K, Vyncke W. 1998. PCBs in cod (gadus morhua), flounder (platichthys flesus), blue mussel (mytilus edulis) and brown shrimp (crangon crangon) from the Belgian continental shelf: Relation to biological parameters and trend analysis. Chemosphere 37(9–12):2199–2210.9828337
*Rose N, Laib RJ, Brunn H, . 1985. Biotransformation and toxicity of polychlorinated biphenyls (PCB’s): Investigation of initiating and promoting activities of 2,2’,4,5’-tetra- and 2,2’,4,4’,5,5’-hexachlorobiphenyl. Naunyn-Schmiedebergs Arch Pharmacol 330(Suppl):R21.
*Rosenshield ML, Jofre MB, Karasov WH. 1999. Effects of polychlorinated biphenyl 126 on green frog (rana clamitans) and leopard frog (rana pipiens) hatching success, development, and metamorphosis. Environ Toxicol Chem 18(11):2478–2486.
*Rosin DL, Martin BR. 1981. Neurochemical and behavioral effects of polychlorinated biphenyls in mice. Neurotoxicology 2:749–764.6123098
*Rothman N, Cantor KP, Blair A, . 1997. A nested case-control study of non-Hodgkin lymphoma and serum organochlorine residues. Lancet 350(9073):240–244.9242800
Rumsby PC, Evans JG, Phillimore HE, . 1992. Search for Ha-ras codon 61 mutations in liver tumours caused by hexachlorobenzene and Aroclor 1254 in C57BL/10ScSn mice with iron overload. Carcinogenesis 13(10):1917–1920.1423854
*Ruokojarvi P, Ruuskanen J, Ettala M, . 1995. Formation of polyaromatic hydrocarbons and polychlorinated organic compounds in municipal waste landfill fires. Chemosphere 31(8):3899–3908.
Rushmore TH, Pickett CB. 1990. Transcriptional regulation of the rat glutathione S-transferase Ya subunit gene. J Biol Chem 265:14648–14653.2387873
*Ryan JJ, Dewailly E, Gilman A, . 1997. Dioxin-like compounds in fishing people from the lower north shore of the St. Lawrence River, Quebec, Canada. Arch Environ Health 52(4):309–316.9210733
*Ryan JJ, Gasiewicz TA, Brown JF. 1990. Human body burden of polychlorinated dibenzofurans associated with toxicity based on the Yusho and Yucheng incidents. Fundam Appl Toxicol 15:722–731.2128284
Ryan JJ, Lau PY, Pilon JC, . 1984. Incidence and levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin in Lake Ontario commercial fish. Environ Sci Technol 18:719–721.
*Ryan JJ, Levesque D, Panopio LG, . 1993. Elimination of polychlorinated dibenzofurans (PCDFs) and polychlorinated biphenyls (PCBs) from human blood in the Yusho and Yu-Cheng rice oil poisonings. Arch Environ Contam Toxicol 24:504–512.8507107
Rybitski MJ, Hale RC, Musick JA. 1995. Distribution of organochlorine pollutants in Atlantic sea turtles. Copeia 1995(2):379–390.
*Rylander L and Hagmar L. 1995. Mortality and cancer incidence among women with a high consumption of fatty fish contaminated with persistent organochlorine compounds. Scand J Work Environ Health 21(6):419–426.8824747
*Rylander L, Stromberg U, Dyremark E, . 1998b. Polychlorinated biphenyls in blood plasma among Swedish female fish consumers in relation to low birth weight. Am J Epidemiol 147:493–502.9525537
*Rylander L, Stromberg U, Hagmar L. 1995. Decreased birthweight among infants born to women with a high dietary intake of fish contaminated with persistent organochlorine compounds. Scand J Work Environ Health 21:368–375.8571093
Rylander L, Stromberg U, Hagmar L. 1998a. Agreement between reported fish consumption obtained by two interviews and its impact on the results in a reproduction study. Eur J Epidemiol 14(1):93–97.9517879
*Sabata S, Friesova A, Rericha R, . 1993. Limits to the use of KOH/PEG method for destruction of PCB liquids of Czechoslovak production. Chemosphere 27(7):1201–1210.
*Sabljic A, Güsten H. 1989. Predicting Henry’s law constants for polychlorinated biphenyls. Chemosphere 19:1503–1511.
*Sabljic A, Güsten H, Hermens J, . 1993. Modeling octanol/water partition coefficients by molecular topology: Chlorinated benzenes and biphenyls. Environ Sci Technol 27(7):1394–1402.
*Saçan MT, Balcio™lu IA. 1996. Prediction of the soil sorption coefficient of organic pollutants by the characteristic root index model. Chemosphere 32(10):1993–2001.
*Saeed A, Hansen LG. 1997. Morphometric changes in the prepubertal female rat thyroid gland following acute exposure to 2,2’,4,4’-tetrachlorobiphenyl and Aroclor 1242. J Toxicol Environ Health 51(5):503–513.9233383
Safe S. 1976. Overview of analytical identification and spectroscopic properties. In: Proceedings of the National Conference on Polychlorinated Biphenyls, Chicago, 1975. Washington, DC: U.S. Environmental Protection Agency. EPA 560/6-75-004.
*Safe S. 1980. Metabolism, uptake, storage and bioaccumulation of halogenated aromatic pollutants. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 81–107.
*Safe S. 1984. Polychlorinated biphenyls (PCBs) and polybrominated biphenyls (PBBs): Biochemistry, toxicology and mechanism of action. CRC Crit Rev Toxicol 13:319–395.
*Safe S. 1989a. Polyhalogenated aromatics: uptake, disposition and metabolism. In: Kimbrough R, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam, The Netherlands: Elsevier Science Publishers, 131–159.
*Safe S. 1989b. Polychlorinated biphenyls (PCBs): mutagenicity and carcinogenicity. Mutat Res 220:31–47.2492077
*Safe S. 1990. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), dibenzofurans (PCDFs), and related compounds: Environmental and mechanistic considerations which support the development of toxic equivalency factors (TEFs). Crit Rev Toxicol 21:51–88.2124811
*Safe S. 1993. Development of bioassays and approaches for the risk assessment of 2,3,7,8-tetrachlorodibenzo-p-dioxin and related compounds. Environ Health Perspect Suppl 101(3):317–325.
*Safe S. 1994. Polychlorinated biphenyls (PCBs): Environmental impact, biochemical and toxic responses, and implications for risk assessment. Crit Rev Toxicol 24(2):87–149.8037844
*Safe SH. 1995. Environmental and dietary estrogens and human health: Is there a problem? Environ Health Perspect 103:356–351.
*Safe S. 1998a. Limitations of the toxic equivalency factor approach for the risk assessment of TCDD and related compounds. Teratogen Carcinogen Mutagen 17:285–304.
*Safe S. 1998b. Development validation and problems with the toxic equivalency factor approach for risk assessment of dioxins and related compounds. J Anim Sci 76(1):134–141.9464894
*Safe S. 1998c. Interactions between hormones and chemicals in breast cancer. Annu Rev Pharmacol Toxicol 38:121–158.9597151
*Safe SH. 1999. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) and related environmental antiestrogens: Characterization and mechanism of action. In: Naz RK, ed. Endocrine disruptors: effects on male and female reproductive systems. Boca Raton, FL: CRC Press, 187–221.
*Safe SH, Zacharewski T. 1997. Organochlorine exposure and risk for breast cancer. In: Aldaz CM, Gould MN, McLachlan J, ., ed. Etiology of breast and gynecological cancers. New York, NY: John Wiley & Sons, Inc., 133–145.
*Safe S, Bandiera S, Sawyer T, . 1985a. PCBs: Structure-function relationships and mechanism of action. Environ Health Perspect 60:47–56.2992927
*Safe S, Bannister R, Davis D, . 1989. Aroclor 1254 as a 2,3,7,8-tetrachlorobenzo-p-dioxin antagonist in mice. Chemosphere 18:709–714.
*Safe S, Connor K, Ramamoorthy K, . 1997. Human exposure to endocrine-active chemicals: Hazard assessment problems. Reg Toxicol Pharmacol 26(1 Part 1):52–58.
*Safe SH, Connor K, Raamamorthy K, . 1998. Estrogenic activity of hydroxylated polychlorinated biphenyls (PCBs) and their interactions. In: Eisenbrand G, ed. Hormonally active agents in food: Symposium. Weinheim, FRG: Wiley-VCH, 200–207.
*Safe S, Hutzinger O, Jones D. 1975. The mechanism of chlorobiphenyl metabolism. J Agric Food Chem 23:851–853.1159182
Safe S, Rodriguez LV, Goldstein LS. 1995. Toxic equivalency factor approach for risk assessment of combustion by-products. Toxicol Environ Chem 49(3):181–191.
*Safe S, Safe L, Mullin M. 1985b. Polychlorinated biphenyls: Congener-specific analysis of a commercial mixture and a human milk extract. J Agric Food Chem 33:24–29.
*Sager DB. 1983. Effect of postnatal exposure to polychlorinated biphenyls on adult male reproductive function. Environ Res 31:76–94.6406218
*Sager DB, Girard DM. 1994. Long-term effects on reproductive parameters in female rats after translactational exposure to PCBs. Environ Res 66(1):52–76.8013438
*Sager D, Girard D, Nelson D. 1991. Early postnatal exposure to PCBs: Sperm function in rats. Environ Toxicol Chem 10:737–746.
*Sager DB, Shih-Schroeder W, Girard D. 1987. Effect of early postnatal exposure to polychlorinated biphenyls (PCBs) on fertility in male rats. Bull Environ Contam Toxicol 38:946–953.3107640
*Saghir SA, Hansen LG. 1999. Toxicity and tissue distribution of 2,2’,4,4’- and 3,3’,4,4’-tetrachlorobiphenyls in houseflies. Ecotoxicol Environ Safety 42:177–184.10051368
*Saghir SA, Koritz GD, Hansen LG. 1994. Toxicokinetics of 2,2’,4,4’-and 3,3’,4.4’-tetrachlorobiphenyl in house files following topical administration. Pestic Biochem Physiol 49:94–113.
*Sahl JD, Crocker TT, Gordon RJ, . 1985a. Polychlorinated biphenyl concentrations in the blood plasma of a selected sample of non-occupationally exposed southern California working adults. Sci Total Environ 46:9–18.3936176
*Sahl JD, Crocker TT, Gordon RJ, . 1985b. Polychlorinated biphenyls in the blood of personnel from an electric utility. J Occup Med 27:639–643.3930667
*Sakai S, Hiraoka M, Takeda N, . 1993. Coplanar PCBs and PCDDs/PCDFs in municipal waste incineration. Chemosphere 27(1–3):233–240.
Salama AA, Mohamed MAM, Duval B, . 1998. Polychlorinated biphenyl concentrations in raw and cooked North Atlantic bluefish (pomatomus saltatrix) fillets. J Agric Food Chem 46(4):1359–1362.
*Salata GG, Wade TL, Sericano JL, . 1995. Analysis of Gulf of Mexico bottlenose dolphins for organochlorine pesticides and PCBs. Environ Pollut 88(2):167–175.15091557
*Sanders G, Hamilton-Taylor J, Jones KC. 1996. PCB and PAH dynamics in a small rural lake. Environ Sci Technol 30:2958–2966.
*Sanders OT, Zepp RL, Kirkpatrick RL. 1974. Effect of PCB ingestion on sleeping times, organ weights, food consumption, serum corticosterone and survival of albino mice. Bull Environ Contam Toxicol 12:394–399.4215520
*SANSS. 1990. Structure and Nomenclature Search System. Chemical Information System (CIS) computer database.
*Sargent L, Dragan YP, Erickson C, . 1991. Study of the separate and combined effects of the non-planar 2,5,2’,5’- and the planar 3,4,3’,4’-tetrachlorobiphenyl in liver and lymphocytes in vivo. Carcinogenesis 12:793–800.1827616
*Sargent L, Roloff B, Meisner L. 1989. In vitro chromosome damage due to PCB interactions. Mutat Res 224:79–88.2505070
Sargent LM, Sattler GL, Roloff B, . 1992. Ploidy and specific karyotypic changes during promotion with phenobarbital, 2,5,2’,5’-tetrachlorobiphenyl, and/or 3,4,3’,4-tetrachlorobiphenyl in rat liver. Cancer Res 52:955–962.1737357
*Sawhney BL, Hankin L. 1985. Polychlorinated biphenyls in food: A review. J Food Protect 48:442–448.
Sawyer T, Safe S. 1982. PCB isomers and congeners: Induction of aryl hydrocarbon hydroxylase and ethoxyresorufin-o-deethylase enzyme activities in rat hepatoma cells. Toxicol Lett 13:87–94.6817473
*Schade G, Heinzow B. 1998. Organochlorine pesticides and polychlorinated biphenyls in human milk of mothers living in northern Germany: Current extent of contamination, time trend from 1986 to 1997 and factors that influence the levels of contamination. Sci Total Environ 215:31–39.9599454
*Schaeffer E, Greim H, Goessner W. 1984. Pathology of chronic polychlorinated biphenyl (PCB) feeding in rats. Toxicol Appl Pharmacol 75:278–288.6433511
*Schantz MM, Koster BJ, Wise SA, . 1993. Determination of PCBs and chlorinated hydrocarbons in marine mammal tissues. Sci Total Environ 139/140:323–345.8272838
*Schantz MM, Parris RM, Kurz J, . 1993a. Comparison of methods for the gas-chromatographic determination of PCB congeners and chlorinated pesticides in marine reference materials. Fresenius J Anal Chem 346(6–9):766–778.
*Schantz MM, Parris RM, Wise SA. 1993b. NIST standard reference materials (SRMs) for polychlorinated biphenyl (PCB) determinations and their applicability to toxaphene measurements. Chemosphere 27(10):1915–1922.
Schantz SL. 1996. Developmental neurotoxicity of PCBs in humans: What do we know and where do we go from here? Neurotoxicol Teratol 18(3):217–227.8725628
*Schantz SL, Gardiner JC, Gasior DM, . 1999. Motor function in aging Great Lakes fisheaters. Environ Res 80(2):S46–S56.10092419
*Schantz SL, Jacobson JL, Humphrey HEB, . 1994. Determinants of polychlorinated biphenyls (PCBs) in the sera of mothers and children from Michigan farms with PCB-contaminated silos. Arch Environ Health 49(6):452–458.7818287
Schantz SL, Levin ED, Bowman RE. 1991. Long-term neurobehavioral effects of perinatal polychlorinated biphenyl (PCB) exposure in monkeys. Environ Toxicol Chem 10:747–756.
*Schantz SL, Levin ED, Bowman RE, . 1989. Effects of perinatal PCB exposure on discrimination-reversal learning in monkeys. Neurotoxicol Teratol 11:243–250.2502707
*Schantz SL, Moshtaghian J, Ness DK. 1995. Spatial learning deficits in adult rats exposed to ortho-substituted PCB congeners during gestation and lactation. Fundam Appl Toxicol 26:117–126.7657055
*Schantz SL, Seo BW, Wong PW, . 1997. Long-term effects of developmental exposure to 2,2’,3,5’,6-pentachlorobiphenyl (PCB 95) on locomotor activity, spatial learning and memory and brain ryanodine binding. Neurotoxicology 18(2):457–67.9291494
*Schantz SL, Seo B-W, Moshtaghian J, . 1996b. Effects of gestational and lactational exposure to TCDD or coplanar PCBs on spatial learning. Neurotoxicol Teratol 18:305–313.8725643
*Schantz SL, Sweeney AM, Gardiner JC, . 1996a. Neuropsychological assessment of an aging population of Great Lakes fisheaters. Toxicol Ind Health 12(3–4):403–417.8843557
*Schecter AJ. 1983. Contamination of an office building in Binghamton, New York by PCBs, dioxins, furans and biphenylenes after an electrical panel and electrical transformer incident. Chemosphere 12:669–680.
*Schecter AJ. 1986. The Binghamton state office building PCB, dioxin and dibenzofuran electrical transformer incident: 1981-1986. Chemosphere 15:1273–1280.
*Schecter AJ. 1987. The Binghamton state office building PCB transformer incident: 1981-1987. Chemosphere 16:2155–2160.
*Schecter AJ. 1991. Dioxins and related chemicals in humans and in the environment. In: Banbury report 35: Biological basis for risk assessment of dioxins and related compounds. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory Press, 169–214.
Schecter AJ. 1992. Written communication (September 24) to Agency for Toxic Substances and Disease Control in peer review comments on draft toxicological profile for polychlorinated biphenyls. SUNY Health Science Center, Binghamton, NY.
*Schecter AJ, Charles K. 1991. The Binghamton state office building transformer incident after one decade. Chemosphere 23:1307–1321.
Schecter A, Li L. 1997. Dioxins, dibenzofurans, dioxin-like PCBs, and DDE in U.S. fast food, 1995. Chemosphere 34(5–7):1449–1457.9134678
*Schecter A, Cramer P, Boggess K, . 1997. Levels of dioxins, dibenzofurans, PCB and DDE congeners in pooled food samples collected in 1995 at supermarkets across the United States. Chemosphere 34(5–7):1437–1447.9134677
*Schecter AJ, Furst P, Furst C, . 1991. Dioxins, dibenzofurans and selected chlorinated organic compounds in human milk and blood from Cambodia, Germany, Thailand, the U.S.A., the U.S.S.R., and Vietnam. Chemosphere 23:1903–1912.
Schecter A, Kassis I, Papke O. 1998. Partitioning of dioxins, dibenzofurans, and coplanar PCBs in blood, milk, adipose tissue, placenta and cord blood from five American women. Chemosphere 37:1817–1823.9828310
*Schecter A, McGee H, Stanley J, . 1993. Chlorinated dioxin, dibenzofuran, coplanar, mono-ortho, and di-ortho substituted PCB congener levels in blood and semen of Michigan Vietnam veterans compared with levels in Vietnamese exposed to Agent Orange. Chemosphere 27(1–3):241–252.
*Schecter A, Mes J, Davies D. 1989. Polychlorinated biphenyl (PCB), DDT, DDE and hexachlorobenzene (HCB) and PCDD/F isomer levels in various organs in autopsy tissue from North American patients. Chemosphere 18:811–818.
*Schecter AJ, Schaffner F, Tiernan TO, . 1985b. Biological markers after exposure to polychlorinated dibenzo-p-dioxins, dibenzofurans, biphenyls, and related chemicals. Part II: Ultrastructural characterization of human liver biopsies. In: Keith L, Rappe C, Choudhry G, eds., Chlorinated dioxins and dibenzofurans in the total environment, II. Boston, MA: Butterworth Publishers, 247–264.
*Schecter A, Stanley J, Boggess K, . 1994. Polychlorinated biphenyl levels in the tissues of exposed and nonexposed humans. Environ Health Perspect Suppl 102(1):149–158.
*Schecter A, Tiernan T. 1985. Occupational exposure to polychlorinated dioxins, polychlorinated furans, polychlorinated biphenyls, and biphenylenes after an electrical panel and transformer accident in an office building in Binghamton, New York. Environ Health Perspect 60:305–313.3928358
*Schecter A, Tiernan T, Schaffner F, . 1985a. Patient fat biopsies for chemical analysis and liver biopsies for ultrastructural characterization after exposure to polychlorinated dioxins, furans and PCBs. Environ Health Perspect 60:241–254.3928350
Scheele J, Teufel M, Niessen KH. 1992. Chlorinated hydrocarbons in the bone marrow of children: studies on their association with leukemia. Eur J Pediatr 151(11):802–805.1468452
*Scheele J, Teufel M, Niessen K-H. 1994. A pilot study on polychlorinated biphenyl levels in the bone marrow of healthy individuals and leukemia patients. J Environ Pathol Toxicol Oncol 13:181–185.7722885
*Scheider WA, Cox C, Hayton A, . 1998. Current status and temporal trends in concentrations of persistent toxic substances in sport fish and juvenile forage fish in the Canadian waters of the Great Lakes. Environ Monit Assess 53:57–76.
*Schlummer M, Moser GA, McLachlan MS. 1998. Digestive tract absorption of PCDD/Fs, PCBs, and HCB in humans: Mass balances and mechanistic considerations. Toxicol Appl Pharmacol 152:128–137.9772208
Schell LM, Tarbell AM. 1998. A partnership study of PCBs and the health of Mohawk youth: Lessons from our past and guidelines for our future. Environ Health Perspect Suppl 106(3):833–840.
*Scheutz EG, Wrighton SA, Safe SH, . 1986. Regulation of cytochrome P-450p by phenobarbital and phenobarbital-like inducers in adult rat hepatocytes in primary monolayer culture and in vivo. Biochemistry 25:1124–1133.3083864
*Schlebusch H, Wagner V, van der Ven H, . 1989. Polychlorinated biphenyls: The occurrence of the main congeners in follicular and sperm fluids. J Clin Chem Clin Biochem 27:663–667.2514253
*Schmidt LJ, Hesselberg RJ. 1992. A mass spectroscopic method for analysis of AHH-inducing and other polychlorinated biphenyl congeners and selected pesticides in fish. Arch Environ Contam Toxicol 23(1):37–44.1637197
*Schmitt CJ, Zajicek JL, Peterman PH, . 1990. National contaminant biomonitoring program: Residues of organochlorine chemicals in U.S. freshwater fish, 1976-1984. Arch Environ Contam Toxicol 19:748–781.21318506
*Schmitt CJ, Zajicek JL, Ribick MA. 1985. National pesticide monitoring program: Residues of organochlorine chemicals in freshwater fish, 1980-81. Arch Environ Contam Toxicol 14:225–260.3920980
*Schnellmann RG, Putnam CW, Sipes IG. 1983. Metabolism of 2,2’,3,3’6,6’-hexachlorobiphenyl and 2,2’,4,4’,5,5’-hexachlorobiphenyl by human hepatic microsomes. Biochem Pharmacol 32:3233–3239.6416258
*Schnellmann RG, Volp RF, Putnam CW, . 1984. The hydroxylation, dechlorination, and glucuronidation of 4,4’-dichlorobiphenyl (4-DCB) by human hepatic microsomes. Biochem Pharmacol 33:3503–3509.6437410
*Schoeny RS, Smith CC, Loper JC. 1979. Non-mutagenicity for salmonella of the chlorinated hydrocarbons Aroclor 1254, 1,2,4-trichlorobenzene, mirex and kepone. Mutat Res 68:125–132.92763
*Schönherr J, Riederer M. 1989. Foliar penetration and accumulation of organic chemicals in plant cuticles. Rev Environ Contam Toxicol 108:1–70.
Schreitmueller J, Ballschmiter K. 1994. Levels of polychlorinated biphenyls in the lower troposphere of the North- and South-Atlantic Ocean. Fresenius J Anal Chem 348(3):226–239.
*Schuetz EG, Brimer C, Schuetz JD. 1998. Environmental xenobiotics and the antihormones cyproterone acetate and spirolactone use the nuclear hormone pregnenolone X receptor to activate the CYP3A23 hormone response element. Mol Pharmacol 54:1113–1117.9855641
*Schultz DE, Patrick G, Duinkeyr JC. 1989. Complete characterization of polychlorinated biphenyl congeners in commercial Aroclor and Clophen mixtures by multidimensional gas chromatography-electron capture detection. Environ Sci Technol 23:852–859.
*Schulze-Stack A, Altman-Hamamdzic S, Morris PJ, . 1999. Polychlorinated biphenyl mixtures (Aroclors) inhibit LPS-induced murine splenocyte proliferation in vitro. Toxicology 139:137–154.10614695
*Schuur AG, Cenjin PH, van Toor H, . 1998a. Effect of Aroclor 1254 on thyroid hormone sulfation in fetal rats. In: Johansson N, Bergman A, Broman D, ., ed. Organohalogen compounds. Akademitryck, Edsbruk:, Vol. 37, 249–252.
*Schuur AG, van Leeuwen-Bol I, Jong WMC, . 1998b. In vitro inhibition of thyroid hormone sulfation by polychloribiphenylols: Isozyme specificity and inhibition kinetics. Toxicol Sci 45:188–194.9848125
*Schuur AG, Bergman A, Brouwer A, . 1999. Effects of pentachlorophenol and hydroxylated polychlorinated biphenyls on thyroid hormone conjugation in a rat and a human hepatoma cell line. Toxicol in Vitro 13:417–425.20654499
*Schwartz PM, Jacobson SW, Fein G, . 1983. Lake Michigan fish consumption as a source of polychlorinated biphenyls in human cord serum, maternal serum, and milk. Am J Public Health 73:293–296.6401943
*Schwartz TR, Stalling DL, Rice CL. 1987. Are polychlorinated biphenyls residues adequately described by Aroclor mixture equivalents? Isomer-specific principal components analysis of such residues in fish and turtles. Environ Sci Technol 21:72–76.
*Schwartz TR, Tillitt DE, Feltz KP, . 1993. Determination of mono- and non-O,O’-chlorine substituted polychlorinated biphenyls in Aroclors and environmental samples. Chemosphere 26(8):1443–1460.
*Secor CL, Mills EL, Harshbarger J, . 1993. Bioaccumulation of toxicants, element and nutrient composition, and soft tissue histology of zebra mussels (dreissena polymorpha) from New York State waters. Chemosphere 26(8):1559–1575.
Seegal RF. 1995. Dopaminergic bases of polychlorinated biphenyl-induced neurotoxicity. In: Chang LW, Slikker W Jr, eds. Neurotoxicology: Approaches and methods. San Diego, CA: Academic Press Inc., 347–357.
*Seegal RF. 1996a. Can epidemiological studies discern subtle neurological effects due to perinatal exposure to PCBs? Neurotoxicol Teratol 18(3):251–254.8725635
*Seegal RF. 1996b. Epidemiological and laboratory evidence of PCB-induced neurotoxicity. Crit Rev Toxicol 26(6):709–737.8958469
*Seegal RF. 1998. Neurochemical effects of co-planar and non-coplanar polychlorinated biphenyls. [Abstract]. Neurotoxicol Teratol 20(3):349–350.
Seegal RF, Schantz SL. 1994. Neurochemical and behavioral sequelae of exposure to dioxins and PCBs. In: A. Schecter, ed. Dioxins and health. New York, NY: Plenum Press, 409–447.
Seegal RF, Bemis JC, Okoniewski RJ. 1998. Polychlorinated biphenyls interact with other Great Lakes Fish-borne contaminants to alter dopamine function in vitro. In:Organohalogen Compounds 37:1–4.
*Seegal RF, Brosch KO, Bush B. 1986a. Polychlorinated biphenyls produce regional alterations of dopamine metabolism in rat brain. Toxicol Lett 30:197–202.3085294
*Seegal RF, Brosch KO, Bush B. 1986b. Regional alterations in serotonin metabolism induced by oral exposure of rats to polychlorinated biphenyls. Neurotoxicology 7:155–166.2423934
*Seegal RF, Brosch K, Bush, B . 1989. Effects of Aroclor 1254 on dopamine and norepinephrine concentrations in pheochromocytoma (PC-12) cells. Neurotoxicology 10:757–764.2562550
*Seegal RF, Brosch KO, Okoniewski R. 1988. The degree of PCB chlorination determines whether the rise in urinary homovanillic acid production in rats is peripheral or central in origin. Toxicol Appl Pharmacol 96:560–564.3144778
*Seegal RF, Brosch KO, Okoniewski RJ. 1997. Effects of in utero and lactational exposure of the laboratory rat to 2,4,2’,4’- and 3,4,3’,4’-tetrachlorobiphenyl on dopamine function. Toxicol Appl Pharmacol 146(1):95–103.9299601
*Seegal RF, Bush B, Brosch KO. 1991a. Sub-chronic exposure of the adult rat to Aroclor 1254 yields regionally-specific changes in central dopaminergic function. Neurotoxicology 12:55–66.2014069
*Seegal RF, Bush B, Brosch KO. 1991b. Comparison of effects of Aroclors 1016 and 1260 on non-human primate catecholamine function. Toxicology 66:145–163.2014516
*Seegal RF, Bush B, Brosch KO. 1992. PCBs induce long-term changes in dopaminergic function in the non-human primate. In: Organohalogen compounds, Vol. 10: 12th International Symposium on Dioxins and Related Compounds, August 24-28, Tampere, Finland, 319–322.
*Seegal RF, Bush B, Brosch KO. 1994. Decreases in dopamine concentrations in adult, non-human primate brain persist following removal from polychlorinated biphenyls. Toxicology 86(1–2):71–87.8134924
*Seegal RF, Bush B, Shain W. 1990. Lightly chlorinated ortho-substituted PCB congeners decrease dopamine in nonhuman primate brain and in tissue culture. Toxicol Appl Pharmacol 106:136–144.2123577
*Seegal RF, Pappas BA, Park GAS. 1998a. Neurochemical effects of consumption of Great Lakes salmon by rats. Regul Toxicol Pharmacol 27:S68–S75.9618335
*Seiler P, Fischer B, Lindenau A, . 1994. Effects of persistent chlorinated hydrocarbons on fertility and embryonic development in the rabbit. Human Reprod 9:1920–1926.
*Seo BW, Meserve LA. 1995. Effects of maternal ingestion of Aroclor 1254 (PCB) on the developmental pattern of oxygen consumption and body temperature in neonatal rats. Bull Environ Contam Toxicol 55:22–28.7663088
*Seo BW, Li MH, Hansen LG, . 1995. Effects of gestational and lactational exposure to coplanar polychlorinated biphenyl (PCB) congeners or 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) on thyroid hormone concentrations in weanling rats. Toxicol Lett 78(3):253–262.7624895
*Sericano JL, Wade TL, El-Husseini AM, . 1992. Environmental significance of the uptake and depuration of planar PCB congeners by the American oyster (crassostrea viginica). Mar Pollut Bull 24(11):537–543.
*Sericano JL, Wade TL, Jackson TJ, . 1995. Trace organic contamination in the Americas: An overview of the US national status and trends and the international ‘mussel watch’ programmes. Mar Pollut Bull 31(4/12):214–225.
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
*Shafer TJ, Mundy WR, Tilson HA, . 1996. Disruption of inositol phosphate accumulation in cerebellar granule cells by polychlorinated biphenyls: A consequence of altered Ca^2+^ homeostasis. Toxicol Appl Pharmacol 141:448–455.8975770
*Shain W, Bush B, Seegal R. 1991. Neurotoxicity of polychlorinated biphenyls: Structure-activity relationship of individual congeners. Toxicol Appl Pharmacol 111:33–42.1949034
*Shain W, Overmann SR, Wilson LR, . 1986. A congener analysis of polychlorinated biphenyls accumulating in rat pups after perinatal exposure. Arch Environ Contam Toxicol 15:687–707.3098189
*Shalat SL, True LD, Fleming LE, . 1989. Kidney cancer in utility workers exposed to polychlorinated biphenyls (PCBs). Br J Ind Med 46:823–824.2511925
*Shaw GR, Connell DW. 1982. Factors influencing concentrations of polychlorinated biphenyls in organisms from an estuarine ecosystem. Aust J Mar Freshwater Res 33:1057–1070.
*Shear NM, Schmidt CW, Huntley SL, . 1996. Evaluation of the factors relating combined sewer overflows with sediment contamination of the lower Passaic River. Mar Pollut Bull 32(3):288–304.
*Shen TT, Tofflemire TJ. 1980. Air pollution aspects of land disposal of toxic wastes. Journal of the Environmental Engineering Division 106:211–226.
*Shiarls MP, Sayler GS. 1982. Biotransformation of PCB by natural assemblages of freshwater microorganisms. Environ Sci Technol 16:367–369.
*Shigematsu N, Norimatsu Y, Ishibashi T, . 1971. Clinical and experimental studies on respiratory involvement in chlorobiphenyls poisoning. Fukuoka Ishi 62(1):150–156.
Shimada T. 1987. Lack of correlation between formation of reactive metabolites and thymic atrophy caused by 3,4,3’,4’-tetrachlorobiphenyl in C57BL/6N mice. Arch Toxicol 59:301–306.3107519
*Shimada T, Imai Y, Sato R. 1981. Covalent binding of polychlorinated biphenyls to proteins by reconstituted monooxygenase system containing cytochrome P-450. Chem Biol Interact 38:29–44.6799213
*Shipp EB, Restum JC, Giesy JP, . 1998a. Multigenerational study of the effects of consumption of PCB-contaminated carp from Saginaw Bay, Lake Huron, on mink. 2. Liver PCB concentration and induction of hepatic cytochrome P-450 activity as a potential biomarker for PCB exposure. J Toxicol Environ Health 54:377–401.
*Shipp EB, Restum JC, Bursian SJ, . 1998b. Multigenerational study of the effects of consumption of PCB-contaminated carp from Saginaw Bay, Lake Huron, on mink. 3. Estrogen receptor and progesterone receptor concentrations, and potential correlation with dietary PCB consumption. J Toxicol Environ Health 54:403–420.
*Shirai JH, Kissel JC. 1996. Uncertainty in estimated half-lives of PCBs in humans: impact on exposure assessment. Sci Total Environ 187:199–210.8711465
*Silberhorn EM, Glauert HP, Robertson LW. 1990. Carcinogenicity of polyhalogenated biphenyls: PCBs and PBBs. Crit Rev Toxicol 20:440–496.2165409
*Silkworth JB, Grabstein EM. 1982. Polychlorinated biphenyl immunotoxicity: Dependence on isomer planarity and the Ah gene complex. Toxicol Appl Pharmacol 65:109–115.6815831
*Silkworth JP, Loose LD. 1978. Cell-mediated immunity in mice fed either Aroclor 1016 or hexachlorobenzene. Toxicol Appl Pharmacol 45:326–332.
Silkworth JP, Sutter TR, Kim JH, . 1999. CYP1A1 and CYP1B1 expression in Sprague-Dawley rats fed araclors 1016, 1242, 1254, and 12600 for 6 months. Organohalogen Compounds 42:481–484.
*Simcik MF, Basu I, Sweet CW, . 1999. Temperature dependence and temporal trends of polychlorinated biphenyl congeners in the Great Lakes atmosphere. Environ Sci Technol 33:1991–1995.
*Simcik MF, Franz TP, Zhang H, . 1998. Gas-particle partitioning of PCBs and PAHs in the Chicago urban and adjacent coastal atmosphere: States of equilibrium. Environ Sci Technol 32:251–257.
*Simcik MF, Hoff RM, Strachan WMJ, . 2000. Temporal trends of semivolatile organic contaminants in Great Lakes precipitation. Environ Sci Technol 34:361–367.
*Simcik MF, Zhang H, Eisenreich SJ, . 1997. Urban contamination of the Chicago/coastal Lake Michigan atmosphere by PCBs and PAHs during aeolos. Environ Sci Technol 31(7):2141–2147.
*Sinclair PR, Bement WJ, Bonkovsky HL, . 1986. Uroporphyrin accumulation produced by halogenated biphenyls in chick-embryo hepatocytes. Biochem J 237:63–71.3026315
*Singh A, Chu I, Villeneuve DC. 1996. Subchronic toxicity of 2,4,4’-trichlorobiphenyl in the rat liver: An ultrastructural and biochemical study. Ultrastruct Pathol 20:275–284.8727071
*Singh A, Gilroy C, Chu I, . 1997. Toxicity of PCB 105 in the rat liver: An ultrastructural and biochemical study. Ultrastruct Pathol 21:143–151.9090025
*Sinks T, Steele G, Smith AB, . 1992. Mortality among workers exposed to polychlorinated biphenyls. Am J Epidemiol 136(4):389–398.1415158
*Sipes G, Schnellmann RG. 1987. Biotransformation of PCBs: Metabolic pathways and mechanisms. In: Safe S, ed. Environmental toxic series, Vol. 1. Polychlorinated biphenyls (PCBs): Mammalian and environmental toxicology. Secaucus, NJ: Springer-Verlag, Inc.
*Sipes IJ, Gandolfi AJ. 1986. Biotransformation of toxicants. In: Casarett and Doull’s toxicology: The basic science of poisons. 3rd ed. New York, NY: Macmillan Publishing Co., 66–74.
Siren H, Hyvonen H, Saarinen M, . 1992. Comparison of HPLC and solid phase clean-up methods for identification of PCBs in cod-liver oil by HRGC/MS-SIM technique. Chromatographia 34(5–8):421–430.
Sittig, M. 1994. World-wide limits for toxic and hazardous chemicals in air, water and soil. Park Ridge, NJ: Noyes Publications.
*Skinner LC. 1992. Chemical contaminants in wildlife from the Mohawk nation at Akwesasne and the vicinity of the General Motors Corporation/Central Foundry Division Massena, New York plant. New York State Department of Environmental Conservation, Albany, New York.
*Sklarew DS, Girvin DC. 1987. Attenuation of polychlorinated biphenyls in soils. Rev Environ Contam Toxicol 98:1–41.3107089
*Slim R, Toborek M, Robertson LW, . 1999. Antioxidant protection against PCB-mediated endothelial cell activation. Toxicol Sci 52:232–239.10630576
*Sloan R, Brown M, Brandt R, . 1985. Hudson River PCB relationships between resident fish, water, and sediment. Northeastern Environmental Science 3(3/4):138–151.
*Sloan RJ, Jock K. 1990. Chemical contaminants in fish from the St. Lawrence river drainage on lands of the Mohawk nation at Akwesasne, and near the General Motors Corporation central foundry division Massena, New York Plant. Technical report 90-1 (BEP). Division of Fish and Wildlife.
*Smialowicz RJ, Andrews JE, Riddle MM, . 1989. Evaluation of the immunotoxicity of low level PCB exposure in the rat. Toxicology 56:197–211.2499955
*Smialowicz RJ, DeVito MJ, Riddle MM, . 1997. Opposite effects of 2,2’,4,4’,5,5’-hexachlorobiphenyl and 2,3,7,8-tetrachlorodibenzo-p-dioxin on the antibody response to sheep erythrocytes in mice. Fundam Appl Toxicol 37:141–149.9242587
*Smith AB, Schloemer J, Lowry LK, . 1982. Metabolic and health consequences of occupational exposure to polychlorinated biphenyls. Br J Ind Med 39:361–369.6128023
*Smith AG, Francis JE, Carthew P. 1990a. Iron as a synergist for hepatocellular carcinoma induced by polychlorinated biphenyls in Ah-responsive C57BL/10ScSn mice. Carcinogenesis 11:437–444.2155720
*Smith AG, Francis JE, Green JA, . 1990b. Sex-linked hepatic uroporphyria and the induction of cytochromes P450IA in rats caused by hexachlorobenzene and polyhalogenated biphenyls. Biochem Pharmacol 40(9):2059–2068.2173599
*Smith BJ. 1984. P.C.B. levels in human fluids: Sheboygan case study. University of Wisconsin Sea Grant Institute, Madison, WI. Technical report WIS-SG-83-240.
Smith MA. 1997. Reassessment of the carcinogenicity of polychlorinated biphenyls (PCBs). J Toxicol Environ Health 50(6):567–579.15279030
*Smits-van Prooije AE, Lammers JHCM, Waalkens-Berendsen DH, . 1993. Effects of the PCB 3,4,5,3’,4’,5’-hexachlorobipyenyl on the reproduction capacity of Wistar rats. Chemosphere 27(1–3):395–400.
*Smrek AL, Needham LL. 1982. Simplified cleanup procedures for adipose tissue containing polychlorinated biphenyls, DDT, and DDT metabolites. Bull Environ Contam Toxicol 28:718–722.6809084
*Sodergren A, Larsson P, Knulst J, . 1990. Transport of incinerated organochlorine compounds to air, water, microlayer, and organisms. Marine Pollut Bull 21:18–24.
*Sokol RC, Bethoney CM, Rhee G-Y. 1995. Effect of PCB concentration on reductive dechlorination and dechlorination potential in natural sediments. Water Res 29(1):45–48.
*Sokol RC, Bethoney CM, Rhee G-Y. 1998. Effect of Aroclor 1248 concentration on the rate and extent of polychlorinated biphenyl dechlorination. Environ Toxicol Chem 17(10):1922–1926.
*Sokol RC, Kwon O-S, Behoney M, . 1994. Reductive dechlorination of polychlorinated biphenyls in St. Lawrence River sediments variations in dechlorination characteristics. Environ Sci Technol 28:2054–2064.22191744
*Sondossi M, Sylvestre M, Ahmad D. 1992. Effects of chlorobenzoate transformation on the pseudomonas-testosteroni biphenyl and chlorobiphenyl degradation pathway. Appl Environ Microbiol 58(2):485–495.1610172
*Soog D-K, Ling Y-C. 1997. Reassessment of PCDD/DFs and Co-PCBs toxicity in contaminated rice-bran oil responsible for the disease “Yu-Cheng”. Chemosphere 34:1579–1586.9134689
Soontornchat S, Li M-H, Cooke PS, . 1994. Toxicokinetic and toxicodynamic influences on endocrine disruption by polychlorinated biphenyls. Environ Health Perspect 102(6–7):568–571.9679117
*Spencer F. 1982. An assessment of the reproductive toxic potential of Aroclor 1254 in female Sprague-Dawley rats. Bull Environ Contam Toxicol 28:290–297.6805538
Springer MA. 1980. Pesticide levels, egg and eggshell parameters of great horned owls. Ohio J Sci 80:184–187.
*Stack AS, Altman-Hamamdzic S, Morris PJ, . 1999. Polychlorinated biphenyl mixtures (Aroclors) inhibit LPS-induced murine splenocyte proliferation in vitro. Toxicology 139:137–154.10614695
*Steele G, Stehr-Green P, Welty E. 1986. Estimates of the biologic half-life of polychlorinated biphenyls in human serum. New Engl J Med 314:926–927.3081811
*Steen WC, Paris DF, Baughman GL. 1978. Partitioning of selected polychlorinated biphenyls to natural sediments. Water Res 12:655–657.
*Stehr-Green PA, Burse VW, Welty E. 1988. Human exposure to polychlorinated biphenyls at toxic waste sites: Investigations in the United States. Arch Environ Health 43:420–424.3143317
*Stehr-Green PA, Ross D, Liddle J, . 1986b. A pilot study of serum polychlorinated biphenyl levels in persons at high risk of exposure in residential and occupational environments. Arch Environ Health 4:240–244.
*Stehr-Green PA, Welty E, Steele G, . 1986a. Evaluation of potential health effects associated with serum polychlorinated biphenyl levels. Environ Health Perspect 70:255–259.3104024
Stein VB, Amin TA, Narang RS. 1987. Simplified method for determining polychlorinated biphenyls, phthalates, and hexachlorocyclohexanes in air. J Assoc Off Anal Chem 70:721–723.2442133
*Steinberg KK, Freni-Titulaer LWJ, Rogers TN, . 1986. Effects of polychlorinated biphenyls and lipemia on serum analytes. J Toxicol Environ Health 19:369–381.3021964
*Stellman SD, Djordjevic MV, Muscat JE, . 1998. Relative abundance of organochlorine pesticides and polychlorinated biphenyls in adipose tissue and serum of women in Long Island, New York. Cancer Epidemiol Biomarkers Prev 7:489–496.9641493
*Stern GA, Halsall CJ, Barrie LA, . 1997. Polychlorinated biphenyls in Arctic air. 1. Temporal and spatial trends: 1992-1994. Environ Sci Technol 31(12):3619–3628.
*Stewart P, Darvill T, Lonky E, . 1999. Assessment of prenatal exposure to PCBs from maternal consumption of Great Lakes fish: An analysis of PCB pattern and concentration. Environ Res 80:S87–S96.10092422
*Stewart P, Pagano J, Sargent D, . 2000a. Effects of Great Lakes fish consumption on brain PCB pattern, concentration, and progressive-ratio performance. Environ Res 82:18–32.10677143
*Stewart P, Reihman J, Lonky E, . 2000b. Prenatal PCB exposure and neonatal behavioral assessment scale (NBAS) performance. Neurotoxicol Teratol 22:21–29.10642111
Stone PJ, ed. 1981. Emergency handling of hazardous materials in surface transportation. Washington, DC: Bureau of Explosives, Association of American Railroads, 418.
*Stow CA. 1995a. Factors associated with PCB concentrations in Lake Michigan salmonids. Environ Sci Technol 29(2):522–527.22201401
*Stow CA. 1995b. Great Lakes herring gull egg PCB concentrations indicate approximate steady-state conditions. Environ Sci Technol 29(11):2893–2897.22206540
Stow CA, Carpenter SR, Eby LA, . 1995. Evidence that PCBs are approaching stable concentrations in Lake Michigan fishes. Ecological Applications 5(1):248–260.
*Stow CA, Jackson LJ, Amrhein JF. 1997. An examination of the PCB: lipid relationship among individual fish. Can J Fish Aquat Sci 54(5):1031–1038.
*Strandberg B, Strandberg L, van Bavel B, . 1998. Concentrations and spatial variations of cyclodienes and other organochlorines in herring and perch from the Baltic Sea. Sci Total Environ 215:69–83.9599457
*Strek HJ, Weber JB. 1982a. Behaviour of polychlorinated biphenyls (PCBs) in soils and plants. Environ Pollut 28:291–312.
*Strek HJ, Weber JB. 1982b. Adsorption and reduction in bioactivity of polychlorinated biphenyl (Aroclor 1254) to redroot pigweed by soil organic matter and montmorillonite clay. Soil Sci Am J 46(2):318–322.
*Street JC, Sharma RP. 1975. Alteration of induced cellular and humoral immune responses by pesticides and chemicals of environmental concern: Quantitative studies of immunosuppression by DDT, Aroclor 1254, carbaryl, carbofuran, and methylparathion. Toxicol Appl Pharmacol 32:587–602.50651
*Stripp BR, Lund J, Mango GW, . 1996. Clara cell secretory protein: a determinant of PCB bioaccumulation in mammals. Am J Physiol 271:L656–L664.8897914
*Sugiura K. 1992. Microbial degradation of polychlorinated biphenyls in aquatic environments. Chemosphere 24(7):881–890.
Sundlof SF, Forrester DJ, Thompson NP, . 1986. Residues of chlorinated hydrocarbons in tissues of raptors in Florida. J Wildl Dis 22:71–82.3951065
*Sundstrom G, Hutzinger O, Safe S. 1976a. The metabolism of 2,2’,4,4’,5,5’-hexachlorobiphenyl by rabbits, rats and mice. Chemosphere 4:249–253.
*Sundstrum G, Hutzinger O, Safe S. 1976b. The metabolism of chlorobiphenyls-A review. Chemosphere 5:267–298.
*Suzuki M, Aizawa N, Okano G, . 1977. Translocation of polychlorobiphenyls in soil into plants: A study by a method of culture of soybean sprouts. Arch Environ Contam 5:343–352.
*Suzuki T. 1980. Additive effects of dietary cadmium and PCB in rats. Agric Biol Chem 44:2209–2210.
*Svensson BG, Hallberg T, Nilsson A, . 1994. Parameters of immunological competence in subjects with high consumption of fish contaminated with persistent organochlorine compounds. Int Arch Occup Environ Health 65(6):351–358.8034358
*Svensson B-G, Mikoczy Z, Stromberg U, . 1995a. Mortality and cancer incidence among Swedish fishermen with a high dietary intake of persistent organochlorine compounds. Scand J Work Environ Health 21(2):106–115.7618056
*Svensson B-G, Nilsson A, Jonsson E, . 1995b. Fish consumption and exposure to persistent organochlorine compounds, mercury, selenium and methylamines among Swedish fishermen. Scand J Work Environ Health 21:96–105.7618064
*Swackhamer DL, Armstrong DE. 1986. Estimation of the atmospheric and nonatmospheric contributions and losses of polychlorinated biphenyls for Lake Michigan on the basis of sediment records of remote lakes. Environ Sci Technol 20:879–883.22263819
*Swackhamer DL, Armstrong DE. 1987. Distribution and characterization of PCBs in Lake Michigan water. J Great Lakes Res 13:24–36.
Swanson GM, Ratcliffe HE, Fischer LJ. 1995. Human exposure to polychlorinated biphenyls (PCBs): a critical assessment of the evidence for adverse health effects. Regul Toxicol Pharmacol 21(1):136–50.7784626
Sykes RG, Coate AR. 1995. PCBs in sealants in water distribution reservoirs. Am Water Works Assoc J 87(4):96–100.
*Sylvestre M, Sondossi M. 1994. Selection of enhanced polychlorinated biphenyl-degrading bacterial strains for bioremediation: Consideration of branching pathways. In: Chaudhry GR, ed. Biod Degrad Biorem Toxic Chem. Portland, OR: Dioscorides Press, 47–73.
*Szabo S, Silver EH, Gallagher GT. 1983. Potentiation of duodenal ulcerogenic action of acrylonitrile by PCB or phenobarbital in the rat. Toxicol Appl Pharmacol 71:451–454.6419390
*Takabatake E, Fujita M, Sawa Y. 1980. Combined effects of polychlorinated biphenyls and methylmercury on hepatic microsomal monooxygenases and the hepatic action of bromobenzene. JPharmDyn 3:463–469.
*Takagi Y, Aburada S, Hashimoto K, . 1986. Transfer and distribution of accumulated (^14^C)polychlorinated biphenyls from maternal to fetal and suckling rats. Arch Environ Contam Toxicol 15:709–715.3098190
*Takahashi S, Lee J-S, Tanabe S, . 1998. Contamination and specific accumulation of organochlorine and butyltin compounds in deep-sea organisms collected from Suruga Bay, Japan. Sci Total Environ 214:49–64.
*Takenaka S, Takahashi, K. 1991. Enhancement of fecal excretion of polychlorinated biphenyls by the addition of rice bran fiber to the diet. Chemosphere 22:375–382.
*Taki I, Hisanaga S, Amagase Y. 1969. Report on Yusho (chlorobiphenyls poisoning) pregnant women and their fetutses. Fukuoka Acta Med 60:471–474.
*Talcott PA, Koller LD. 1983. The effect of inorganic lead and/or a polychlorinated biphenyl on the developing immune system of mice. J Toxicol Environ Health 12:337–352.6418890
*Talcott PA, Koller LD, Exon JH. 1985. The effect of lead and polychlorinated biphenyl exposure on rat natural killer cell cytotoxicity. Int J Immunopharmacol 7(2):255–261.3924847
*Tanabe S, Hidaka H, Tatsukawa R. 1983. PCBs and chlorinated hydrocarbon pesticides in Antarctic atmosphere and hydrosphere. Chemosphere 12:277–288.
Tanabe S, Kannan N, Subramanian A, . 1987. Highly toxic coplanar PCBs: Occurrence, source, persistency and toxic implications to wildlife and humans. Environ Pollut 47:147–163.15092716
*Tanabe S, Kannan N, Wakimoto T, . 1989. Isomer-specific determination and toxic evaluation of potentially hazardous coplanar PCBs, dibenzofurans and dioxins in the tissues of “Yusho” PCB poisoning victim and in the causal oil. Toxicol Environ Chem 24:215–231.
*Tanabe S, Nakagawa Y, Tatsukawa R. 1981. Absorption efficiency and biological half-life of individual chlorobiphenyls in rats treated with Kanechlor products. Agric Biol Chem 45:717–726.
*Tanabe S, Tanaka H, Tatsukawa R. 1984. Polychlorobiphenyls, 3 DDT and hexachlorocyclohexane isomers in the western North Pacific ecosystem. Arch Environ Contam Toxicol 13:731–738.
*Taniguchi S, Murakami A, Hosomi M, . 1997. Chemical decontamination of PCB-contaminated soil. Chemosphere 34(5–7):1631–1637.
*Tanimura T, Ema M, Kihara T. 1980. Effects of combined treatment with methylmercury and polychlorinaed biphenyls (PCBs on the development of mouse offspring. In: Persaud TVN, ed. Neural and behavioural teratology. Baltimore: University Park Press, 163–198.
*Tarvis D, Hegmann K, Gerstenberger S, . 1997. Association of mercury and PCB levels with chronic health effects in Native Americans. Health Conference ‘97 Great Lakes and St. Lawrence. Montreal, Quebec, Canada. (As cited in Johnson et al. 1998)
*Tatematsu M, Nakanishi K, Murasaki G, . 1979. Enhancing effect of inducers of liver microsomal enzymes on induction of hyperplastic liver nodules by N-2-fluorenylacetamide in rats. J Natl Cancer Inst 63:1411–1416.117197
*Tavlarides L. 1998a. Multidisciplinary study of PCBs and PCDFs at a waste site elimination of PCBs by supercritical extraction and wet oxidation. Crisp Data Base National Institutes of Health.
Tavlarides L. 1998b. Supercritical fluid technology--remediation of PCB/PAH contaminated soils. Crisp Data Base National Institutes of Health.
*Taylor PR, Lawrence CE. 1992. Polychlorinated biphenyls: estimated serum half lives. Br J Ind Med 49(7):527–528.1637716
*Taylor PR, Lawrence CE, Hwang HL, . 1984. Polychlorinated biphenyls: Influence on birthweight and gestation. Am J Public Health 74:1153–1154.6433730
*Taylor PR, Stelma, Auger I, . 1988. The relation of occupational polychlorinated biphenyl exposure to cancer and total mortality. In: The health effect of polybrominated biphenyls. Doctoral thesis submitted to Harvard School of Public Health, Boston, MA, 86–136. (Unpublished study)
*Taylor PR, Stelma JM, Lawrence CE. 1989. The relation of polychlorinated biphenyls to birth weight and gestational age in the offspring of occupationally exposed mothers. Am J Epidemiol 129:395–406.2492144
*Thomas G, Sweetman AJ, Ockenden WA, . 1998. Air-pasture transfer of PCBs. Environ Sci Technol 32:936–942.
*Thomas DR, Carswell KS, Georgiou G. 1992. Mineralization of biphenyl and PCBs by the white rot fungus phanerochaete chrysosporium. Biotechnol Bioeng 40(11):1395–1402.18601096
*Thomas PT, Hinsdill RD. 1978. Effect of polychlorinated biphenyls on the immune responses of Rhesus monkeys and mice. Toxicol Appl Pharmacol 44:41–51.79241
*Thomas PT, Hinsdill RD. 1980. Perinatal PCB exposure and its effect on the immune system of young rabbits. Drug Chem Toxicol 3:173–184.6785064
*Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York: McGraw-Hill Book Co., 15–16.
*Thomas RL, Frank R. 1981. PCBs in sediment and fluvial suspended solids in the Great Lakes. In: Mackay D, ., eds. Physical behavior of PCBs in the Great Lakes. Ann Arbor, MI: Ann Arbor Science Press, 245–267.
*Tiedje JM, Quensen JF III, Chee-Sanford J, . 1993. Microbial reductive dechlorination of PCBs. Biodegradation 4(4):231–240.7764920
Tiernan TO, Taylor ML, Garrett JG, . 1985. Sources and fate of polychlorinated dibenzodioxins, dibenzofurans and related compounds in human environments. Environ Health Perspect 59:145–158.3921357
*Tiernan TO, Taylor ML, Garret JH, . 1983. Chlorodibenzodioxins, chlorodibenzofurans and related compounds in the effluents from combustion processes. Chemosphere 12:595–606.
*Tilden J, Hanrahan LP, Anderson H, . 1997. Health advisories for consumers of Great Lakes sport fish: Is the message being received? Environ Health Perspect 105(12):1360–1365.9405330
*Tilson HA, Kodavanti PR. 1997. Neurochemical effects of polychlorinated biphenyls: an overview and identification of research needs. Neurotoxicology 18(3):727–743.9339820
*Tilson HA, Kodavanti PR. 1998. The neurotoxicity of polychlorinated biphenyls. Neurotoxicology 19(4–5):517–525.9745906
*Tilson HA, Davis GJ, McLachlan JA, . 1979. The effects of polychlorinated biphenyls given prenatally on the neurobehavioral development of mice. Environ Res 18:466–474.116844
*Tilson HA, Jacobson JL, Rogan WJ. 1990. Polychlorinated biphenyls and the developing nervous system cross-species comparisons. Neurotoxicol Teratol 12:239–248.2115098
*Tilson HA, Kodavanti PRS, Mundy WR, . 1998. Neurotoxicity of environmental chemicals and their mechanism of action. Toxicol Lett 102–103:631–635.
*Timberlake DL, Garbaciak S Jr. 1995. Bench-scale testing of selected remediation alternatives for contaminated sediments. J Air Waste Manage Assoc 45:52–56.
*Tironi A, Pesatori A, Consonni D, . 1996. [Mortality among women workers exposed to PCB.] Epidemiol Prev 20:200–202. (Italian)8766323
*Tithof PK, Contreras ML, Ganey PE. 1995. Aroclor 1242 stimulates the production of inositol phosphates in polymorphonuclear neutrophils. Toxicol Appl Pharmacol 131:136–143.7878669
*Tithof PK, Schiamberg E, Peters-Golden M, . 1996. Phospholipase A_2_ is involved in the mechanism of activation of neutrophils by polychlorinated biphenyls. Environ Health Persp 104(1):105–111.
Toborek M, Barger SW, Mattson MP, . 1995. Exposure to polychlorinated biphenyls causes endothelial cell dysfunction. J Biochem Toxicol 10(4):219–226.8568836
Travis CC, Arms AD. 1988. Bioconcentration of organics in beef, milk, and vegetation. Environ Sci Technol 22:271–274.22288859
Travis CC, Hattemer-Frey HA. 1988. Uptake of organics by aerial plant parts: A call for research. Chemosphere. 17:277–283.
Tremblay NW, Gilman AP. 1995. Human health, the Great Lakes, and environmental pollution: A 1994 perspective. Environ Health Perspect Suppl 103(9):3–5.
*Treon JF, Cleveland FP, Cappel JW, . 1956. The toxicity of the vapours of Aroclor 1242® and Aroclor® 1254. Am Ind Hyg Assoc Q 17:204–213.13326847
TRI88. 1990. Toxics Release Inventory 1988. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
TRI92. 1994. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI93. 1995. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI96. 1998. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI98. 2000. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Troisi GM, Haraguchi K, Simmonds MP, . 1998. Methyl sulphone metabolites of polychlorinated biphenyls (PCBs) in cetaceans from the Irish and the Aegean seas. Arch Environ Contam Toxicol 35:121–128.9601929
*Truelove J, Grant D, Mes J, . 1982. Polychlorinated biphenyl toxicity in the pregnant Cynomolgus monkey: A pilot study. Arch Environ Contam Toxicol 11:583–588.6816151
*Tryphonas H. 1994. Immunotoxicity of polychlorinated biphenyls: Present status and future considerations. Exp Clin Immunogenet 11:149–162.7826664
*Tryphonas H. 1995. Immunotoxicity of PCBs (Aroclors) in relation to Great Lakes. Environ Health Perspect Suppl 103(9):35–46.
*Tryphonas H, Fournier M, Lacroix F, . 1998b. Effects of Great Lakes fish consumption on the immune system of Sprague-Dawley rats investigated during a two-generation reproductive study: II. Quantitative and functional aspects. Regul Toxicol Pharmacol 27:S40–S54.9618333
*Tryphonas H, Hayward S, O’Grady L, . 1989. Immunotoxicity studies of PCB (Aroclor 1254) in the adult Rhesus (macaca mulatta) monkey-Preliminary report. Int J Immunopharmacol 11:199–206.2495254
*Tryphonas H, Luster MI, Schiffman G, . 1991b. Effect of chronic exposure of PCB (Aroclor 1254) on specific and nonspecific immune parameters in the Rhesus (macaca mulatta) monkey. Fundam Appl Toxicol 16:773–786.1884915
*Tryphonas H, Luster MI, White KL Jr, . 1991a. Effects of PCB (Aroclor® 1254) on non-specific immune parameters in Rhesus (macaca mulatta) monkeys. Int J Immmunopharmacol 13:639–648.
*Tryphonas H, McGuire P, Fernie S, . 1998a. Effects of Great Lakes fish consumption on the immune system of Sprague-Dawley rats investigated during a two-generation reproductive study: I. Body and organ weights, food consumption, and hematological parameters. Regul Toxicol Pharmacol 27:S28–S39.9618332
*Tryphonas L, Arnold DL, Zawidzka Z, . 1986b. A pilot study in adult Rhesus monkeys (m. mulatta) treated with Aroclor 1254 for two years. Toxicol Pathol 14:1–10.3086960
*Tryphonas L, Charbonneau S, Tryphonas H, . 1986a. Comparative aspects of Aroclor 1254® toxicity in adult Cynomolgus and Rhesus monkeys: A pilot study. Arch Environ Contam Toxicol 15:159–169.3085600
*Tryphonas L, Truelove J, Zawidzka Z, . 1984. Polychlorinated biphenyl (PCB) toxicity in adult Cynomolgus monkeys (m. fascicularis): A pilot study. Toxicol Pathol 12(1):10–25.6436955
Tsai ML, Webb RC, Loch-Caruso R. 1996. Congener-specific effects of PCBs on contractions of pregnant rat uteri. Reprod Toxicol 10(1):21–28.8998381
*Tuey DB, Matthews HB. 1977. Pharmacokinetics of 3,3’,5,5’-tetrachlorobiphenyl in the male rat. Drug Metab Dispos 5:444–450.20292
*Tuey DB, Matthews HB. 1980. Use of a physiological compartmental model for the rat to describe the pharmacokinetics of several chlorinated biphenyls in the mouse. Drug Metab Dispos 8:397–403.6109607
*Tysklind M, Rappe C. 1991. Photolytic transformation of polychlorinated dioxins and dibenzofurans in fly ash. Chemosphere 23:1365–1375.
*UATW. 1999a. Unified Air Toxics Website. Alabama. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. July 23, 1999. http://www.epa.gov/ttn/uatw/stprogs.html
*UATW. 1999b. Unified Air Toxics Website. Hawaii. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. July 23, 1999. http://www.epa.gov/ttn/uatw/stprogs.html
*UATW. 1999c. Unified Air Toxics Website. Hawaii. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. July 23, 1999. http://www.epa.gov/ttn/uatw/stprogs.html
*UATW. 1999d. Unified Air Toxics Website. Hawaii. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. July 23, 1999. http://www.epa.gov/ttn/uatw/stprogs.html
*UATW. 1999e. Unified Air Toxics Website. Idaho. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. July 23, 1999. http://www.epa.gov/ttn/uatw/stprogs.html
*Unger M, Kiaer H, Blichert-Toft M, . 1984. Organochlorine compounds in human breast fat from deceased with and without breast cancer and in a biopsy material from newly diagnosed patients undergoing breast surgery. Environ Res 34:24–28.6426947
*Unterman R, Brennan MJ, Brooks RE, . 1989. Biodegradation of PCB on contaminated soils. In: Proceedings of the 197th National Meeting of the American Chemical Society, Dallas, Texas, USA, April 9-14. Abstract Paper American Chemical Society, Washington, DC, 197.
USC. 1980. United States Code. Comprehensive Environmental Response, Compensation, and Liability. 42 USC 9601.
*USC. 1998. United States Code. Regulation of hazardous chemical substances and mixtures. 15 USC 2605.
*USC. 1999. United States Code. Hazardous air pollutants. 42 USC 7412.
*U.S. Congress. 1980. Comprehensive environmental response, compensation, and liability act of 1980. Title1-Hazardous substances releases, liability, compensation. Section 121-Cleanup standards. Public Law 96-510.94 Stat. 2767; 42 USC 9601.
*USITC. 1978. Imports of benzenoid chemicals and products 1977. USITC Publ 900. Washington, DC: U.S. International Trade Commission, 26.
*USITC. 1979. Imports of benzenoid chemicals and products 1978. USITC Publ 990. Washington, DC: U.S. International Trade Commission, 26.
*USITC. 1980. Imports of benzenoid chemicals and products 1979. USITC Publ 1083. Washington, DC: U.S. International Trade Commission, 28.
*USITC. 1982. Imports of benzenoid chemicals and products 1981. USITC Publ 1272. Washington, DC: U.S. International Trade Commission, 25.
*Uzawa H, Ito Y, Notomi A, . 1969. [Hyperglyceridemia resulting from intake of rice oil contaminated with chlorinated biphenyls.] Fukuoka Igaku Zasshi 60:449–454. (Japanese)
Uzgiris EE, Edelstein WA, Philipp HR, . 1995. Complex thermal desorption of PCBs from soil. Chemosphere 30(2):377–387.
Vaman Rao C, Banerji SA. 1993. Effect of polychlorinated biphenyls (Aroclor 1260) on histology of adrenal of rats. J Environ Biol 14(1):1–6.
*van Birgelen APJM, Fase KM, van der Kolk J, . 1996a. Synergistic effect of 2,2’,4,4’,5,5’-hexachlorobiphenyl and 2,3,7,8-terachlorodibenzo-p-dioxin on hepatic porphyrin levels in the rat. Environ Health Perspect 104(5):550–557.8743444
*Van Birgelen APJM, Smit EA, Kampen IM, . 1995. Subchronic effects of 2,3,7,8-TCDD or PCBs on thyroid hormone metabolism: use in risk assessment. Eur J Pharmacol 293:77–85.7672011
Van Birgelen APJM, Ross DG, Devito MJ. 1996b. Interactive effects between 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,2’,4,4’,5,5’-hexachlorobiphenyl in female B6C3FL mice: Tissue distribution and tissue-specific enzyme induction. Fundam Appl Toxicol 34(1):118–131.8937899
*van Birgelen APJM, van der Kolk J, van den Berg M, . 1992. Interactive effects of 2,2’,4,4’,5,5’-hexachlorobiphenyl and 2,3,7,8-tetrachlorodibenzo-p-dioxin on thyroid hormone, vitamin A, and vitamin K metabolism in the rat. Chemosphere 25:1239–1244.
*Van Birgelen APJM, Van der Kolk J, Fase KM, . 1994a. Toxic potency of 2,3,3’4,4’5-hexachlorobiphenyl relative to and in combination with 2,3,7,8-tetrachlorodibenzo-p-dioxin in a subchronic feeding study in the rat. Toxicol Appl Pharmacol 126:202–213.8209374
*Van Birgelen APJM, Van der Kolk J, Fase KM, . 1994b. Toxic potency of 3,3’,4,4’,5,5’-pentachlorobiphenyl relative to and in combination with 2,3,7,8-tetrachlorodibenzo-p-dioxin in a subchronic feeding study in the rat. Toxicol Appl Pharmacol 127:209–221.8048064
*Van den Berg KJ, Van Raaij J, Bragt P, . 1991. Interactions of halogenated industrial chemicals with transthyretin and effects on thyroid hormone levels in vivo. Arch Toxicol 65:15–19.2043046
*Van den Berg M, Birnbaum L, Bosveld ATC, . 1998. Toxic equivalency factors (TEFs) for PCBs, PCDDs, PCDFs for humans and wildlife. Environ Health Perspect 106(12):775–792.9831538
*Van den Berg M, Olic K, Hutzinger O. 1985. Polychlorinated dibenzofurans (PCDFs): Environmental occurrence and physical, chemical and biological properties. Toxicol Environ Chem Rev 9:171–217.
*van der Burght ASAM, Clijsters PJ, Horbach GJ, . 1999. Structure-dependent induction of CYP1A by polychlorinated biphenyls in hepatocytes of Cynomolgus monkeys (Macaca fascicularis). Toxicol Appl Pharmacol 155:13–23.10036214
*van der Kolk J, van Birgelen APJM, Poiger H, . 1992. Interactions of 2,2’,4,4’,5,5’hexachlorobiphenyl and 2,3,7,8-tetrachlorodibenzo-p-dioxin in a subchronic feeding study in the rat. Chemosphere 25(12):2023–2027.
Van der Plas SA, de Jongh J, Faassen-Peters M, . 1998. Toxicokinetics of an environmentally relevant-mixture of dioxin-like PHAHs with or without a non-dioxin-like PCB in a semi-chronic exposure study in female Sprague Dawley rats. Chemosphere 37:1941–1955.9828321
*van der Plas SA, Haag-Gronlund M, Scheu G, . 1999. Induction of altered hepatic foci by a mixture of dioxin-like compounds with and without 2,2’,4,4’,5,5’-hexachlorobiphenyl in female Sprague-Dawley rats. Toxicol Appl Pharmacol 156:30–39.10101096
*van der Schalie WH, Gardner HS, Bantle JA, . 1999. Animals as sentinels of human health hazards of environmental chemicals. Environ Health Perspect 107(4):309–315.
*Van der Velde EG, Marsman JA, De Jong AP, . 1994. Analysis and occurrence of toxic planar PCBs, PCDDs and PCDFs in milk by use of carbosphere activated carbon. Chemosphere 28(4):693–702.
*Van Dort HM, Bedard DL. 1991. Reductive ortho and meta-dechlorination of a polychlorinated biphenyl congener by anaerobic microorganisms. Appl Environ Microbiol 57:1576–1578 16348498
Van Duuren BL. 1981. Cocarcinogens and tumor promoters and their environmental importance. J Environ Pathol Toxicol 4:959–969.
*Vanier C, Sylvestre M, Planas D. 1996. Persistence and fate of PCBs in sediments of the Saint Lawrence River. Sci Total Environ 192(3):229–244.
*Van Metre PC, Wilson JT, Callender E, . 1998. Similar rates of decrease of persistent, hydrophobic and particle-reactive contaminants in riverine systems. Environ Sci Technol 32:3312–3317.
Varanasi U, Stein JE, Tilbury KL, . 1994. Chemical contaminants in gray whales (eschrichtius robutus) stranded along the west coast of North America. Sci Total Environ 145:29–53.8016628
*Vartiainen T, Jaakkola JJK, Saarikoski S, . 1998. Birth weight and sex of children and the correlation to the body burden of PCDDs/PCDFs and PCBs of the mother. Environ Health Perspect 106(2):61–66.9432971
Vater ST, Velazquez SF, Cogliano VJ. 1995. A case study of cancer data set combinations for PCBs. Regul Toxicol Pharmacol 22(1):2–10.7494898
Veith GD, Kosian P. 1983. Estimating bioconcentration potential from octanol/water partition coefficients: In: Mackay D, ., eds. Physical behavior of PCBs in the Great Lakes. Ann Arbor, MI: Ann Arbor Science Press, 269–282.
Vena JE, Buck GM, Kostyniak P, . 1996. The New York angler cohort study: Exposure characterization and reproductive and developmental health. Toxicol Ind Health 12 (3–4):327–334.8843550
*Verbrugge DA, Giesy JP, Mora MA, . 1995. Concentrations of dissolved and particulate polychlorinated biphenyls in water from the Saginaw River, Michigan. J Great Lakes Res 21(2):219–233.
*Vernon AA. 1981. High levels of polychlorinated biphenyls in serum specimens, Kansas. Internal report ELI-80-23-2. Centers for Disease Control, Atlanta, GA.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Villeneuve DC, Grant DL, Khera K, . 1971. The fetotoxicity of a polychlorinated biphenyl mixture (Aroclor® 1254) in the rabbit and in the rat. Environ Physiol 1:67–71.
*Villeneuve DC, Grant DL, Phillips WEJ. 1972. Modification of pentobarbital sleeping times in rats following chronic PCB ingestion. Bull Environ Contam Toxicol 7:264–269.4626083
Vinierm PM, Crain DA, McLachlan JA, . 1996. Interactions of environmental chemicals with the estrogen and progesterone receptors from the oviduct of the American alligator. Environ Health Perspect 104(12):1318–1322.9118873
*Vorhees DJ, Cullen AC, Altshul LM. 1997. Exposure to polychlorinated biphenyls in residential indoor air and outdoor air near a Superfund site. Environ Sci Technol 31(12):3612–3618.
*Vorhees DJ, Cullen AC, Altshul LM. 1999. Polychlorinated biphenyls in house dust and yard soil near a Superfund site. Environ Sci Technol 33:2151–2156.
*Vos JG, Beems RB. 1971. Dermal toxicity studies of technical polychlorinated biphenyls and fractions thereof in rabbits. Toxicol Appl Pharmacol 19:617–633.5132032
*Vos JG, de Roij T. 1972. Immunosuppressive activity of a polychlorinated biphenyl preparation on the humoral immune response in guinea pigs. Toxicol Appl Pharmacol 21:549–555.4114810
*Vos JG, Notenboom-Ram E. 1972. Comparative toxicity study of 2,4,5,2’,4’,5’-hexachlorobiphenyl and a polychlorinated biphenyl mixture in rabbits. Toxicol Appl Pharmacol 23:563–578.4630164
*Vos JG, Van Dreil-Grootenhuis D. 1972. PCB-induced suppression of the humoral and cell-mediated immunity in guinea pigs. Sci Total Environ 1:289–302.4633048
Vrecl M, Pogacnik A, Sek S, . 1995. Quantitative alterations in the liver and adrenal gland in pregnant rats induced by Pyralene 3000. Bull Environ Contam Toxicol 54(6):900–906.7647507
*Wade TL, Chambers L, Gardinali PR, . 1997. Toxaphene, PCB, DDT, and chlordane analyses of beluga whale blubber. Chemosphere 34(5–7):1351–1357.9134674
*Wallace JC, Basu I, Hites RA. 1996. Sampling and analysis artifacts caused by elevated indoor air polychlorinated biphenyl concentrations. Environ Sci Technol 30(9):2730–2734.
Waller CL, Minor DL, McKinney JD. 1995. Using three-dimensional quantitative structure-activity relationships to examine estrogen receptor binding affinities of polychlorinated hydroxybiphenyls. Environ Health Perspect 103(7–8):33–38.
Waller DP, Presperin C, Drum ML, . 1996. Great Lakes fish as a source of maternal and fetal exposure to chlorinated hydrocarbons. Toxicol Ind Health 12(3/4):335–345.8843551
*Wallnöfer PR, Kowiger M, Engelhardt G. 1975. [No title available]. Z. Plauz Pflanzeuschutz. 82:91.
Wang JS, Chou HN, Fan J-J, . 1998. Uptake and transfer of high PCB concentrations from phytoplankton to aquatic biota. Chemosphere 36(6):1201–1210.
*Wania F, Mackay D. 1993. Global fractionation and cold condensation of low volatility organochlorine compounds in polar regions. Ambio 22(1):10–18.
*Wania F, Mackay D. 1996. Tracking the distribution of persistent organic pollutants. Environ Sci Technol 30:390A–396A.
*Wania F, Hoff JT, Jia CQ, . 1998. The effects of snow and ice on the environmental behaviour of hydrophobic organic chemicals. Environ Pollut 102:25–41.
*Wania F, Mackay D, Hoff JT. 1999. The importance of snow scavenging of polychlorinated biphenyl and polycyclic aromatic hydrocarbon vapors. Environ Sci Technol 33(1):195–197.
Ward EM, Burnett CA, Ruder A, . 1997. Industries and cancer. Cancer Causes Control 8(3):356–370.9498899
*Ward JM. 1985. Proliferative lesions of the glandular stomach and liver in F344 rats fed diets containing Aroclor 1254. Environ Health Perspect 60:89–95.3928367
Warngard L, Haag-Gronlund M, Bager Y. 1998. Assessment of animal tumour promotion data for the human situation. Arch Toxicol Suppl 20:311–319.9442304
*Warshaw R, Fischbein A, Thornton J, . 1979. Decrease in vital capacity in PCB-exposed workers in a capacitor manufacturing facility. Ann NY Acad Sci 320:277–283.110195
*Wassermann D, Wassermann M, Cucos S, . 1973. Function of adrenal gland-zona fasciculata in rats receiving polychlorinated biphenyls. Environ Res 6:334–338.4200975
*Wassermann M, Bercovici B, Cucos S, . 1980. Storage of some organochlorine compounds in toxemia of pregnancy. Environ Res 22:404–411.6773756
*Wassermann M, Nogueira DP, Tomatis L, . 1976. Organochlorine compounds in neoplastic and adjacent apparently normal breast tissue. Bull Environ Contam Toxicol 15(4):478–484.816406
*Wassermann M, Ron M, Bercovici G, . 1982. Premature delivery and organochlorine compounds: Polychlorinated biphenyls and some organochlorine insecticides. Environ Res 28:106–112.6179776
*Webber MD, Peitz RI, Granato TC, . 1994. Organic chemicals in the environment: Plant uptake of PCBs and other organic contaminants from sludge-treated coal refuse. J Environ Qual 23:1019–1026.34872209
*Weinand-Harer A, Lilienthal H, Bucholski K-A, . 1997. Behavioral effects of maternal exposure to an ortho-chlorinated or a coplanar PCB congener in rats. Environ Toxicol Pharmacol 3(2):97–103.21781766
*Weisglas-Kuperus N. 2000. Immunologic effects of polychlorinated biphenyl (PCB) and dixoin exposure in Dutch toddlers. Toxicologist 54(1):300.
*Weisglas-Kuperus N, Patandin S, Berbers G, . 1999. Immunological effects of background exposure to polychlorinated biphenyls and dioxins in Dutch toddlers. Organohalogen Compounds 44:425.
*Weisglas-Kuperus N, Sas TCJ, Koopman-Esseboom C, . 1995. Immunologic effects of background prenatal and postnatal exposure to dioxins and polychlorinated biphenyls in Dutch infants. Pediatr Res 38(3):404–10.7494667
*Weistrand C, Noren K. 1997. Methylsulfonyl metabolites of PCBs and DDE in human tissues. Environ Health Perspect 105(6):644–649.9288499
*Weistrand C, Noren K. 1998. Polychlorinated naphthalenes and other organochlorine contaminants in human adipose and liver tissue. J Toxicol Environ Health 53:293–311.
*Welling L, Paukku R, Mantykoski K. 1992. PCB in recycled paper products. Chemosphere 25(3):293–295.
Wells DE, Echarri I. 1994. Determination of chlorobiphenyls, with the separation of non-ortho, mono-ortho and di-ortho chloro congeners in fish and sea mammals. Anal Chim Acta 286(3):431–449.
Welp EA, Weiderpass E, Boffetta P, . 1998. Environmental risk factors of breast cancer. Scand J Work Environ Health 24(1):3–7.
*Welsch F. 1985. Effects of acute or chronic polychlorinated biphenyl ingestion on maternal metabolic homeostasis and on the manifestations of embryotoxicity caused by cyclophosphamide in mice. Arch Toxicol 57:104–113.3927875
*Welsh MS. 1995. Extraction and gas chromatography/electron capture analysis of polychlorinated biphenyls in railcar paint scrapings. Appl Occup Environ Hyg 10(3):175–181.
*Welty ER. 1983. Personal communication, August 8, 1983. (As cited in Kreiss 1985).
*Wenning RJ, Bonnevie NL, Huntley SL. 1994. Accumulation of metals, polychlorinated biphenyls, and polycyclic aromatic hydrocarbons in sediments from the lower Passaic River, New Jersey. Arch Environ Contam Toxicol 27(1):64–81.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Wester RC, Bucks DAW, Maibach HI, . 1983. Polychlorinated biphenyls (PCBs): Dermal absorption, systemic elimination, and dermal wash efficiency. J Toxicol Environ Health 12:511–519.6422047
*Wester RC, Maibach HI, Bucks DW, . 1990. Percutaneous absorption and skin decontamination of PCBs: In vitro studies with human skin and in vivo studies in the Rhesus monkey. J Toxicol Environ Health 31:235–246.2254950
*Wester RC, Maibach HI, Sedik L, . 1993. Percutaneous absorption of PCBs from soil: In vivo rhesus monkey, in vitro human skin, and binding to powdered human stratum corneum. J Toxicol Environ Health 39(3):375–382.8350383
*Whalen MM, Loganathan BG, Warren T, . 1998. Effect of in vitro exposure to individual and mixtures of PCBs and tributylin on human naltural (NK) cell function. In:Organohalogen Compounds 37:209–212.
Whitlock JP. 1987. The regulation of gene expression of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Pharmacol Rev 39:147–161.3303065
*WHO. 1993. Polychlorinated biphenyls and terphenyls. Environmental Health Criteria, 140. Geneva, Switzerland: World Health Organization, 48–52, 444–479.
*Whysner J, Montandon F, McClain RM, . 1998. Absence of DNA adduct formation by phenobarbital, polychlorinated biphenyls, and chlordane in mouse liver using the 32p-postlabeling assay. Toxicol Appl Pharmacol 148(1):14–23.9465259
*Wickizer TM, Brilliant LB, Copeland R, . 1981. Polychlorinated biphenyl contamination of nursing mothers’ milk in Michigan. Am J Public Health 71:132–137.6779648
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise, Volume II - The elements Part A. New York, NY: Academic Press.
Wierda D, Irons RD, Greenlee WF. 1981. Immunotoxicity in C57BL/6 mice exposed to benzene and Aroclor 1254. Toxicol Appl Pharmacol 60:410–417.6794184
*Wiegel J, Wu Q. 2000. Microbial reductive dehalogenation of polychlorinated biphenyls. FEMS Microbiol Ecol 32:1–15.10779614
*Williams WA. 1994. Microbial reductive dechlorination of trichlorobiphenyls in anaerobic sediment slurries. Environ Sci Technol 28:630–635.22196545
*Williams WA, May RJ. 1997. Low-temperature microbial aerobic degradation of polychlorinated biphenyls in sediment. Environ Sci Technol 31(12):3491–3496.
*Willman EJ, Manchester-Neesvig JB, Agrell C, . 1999. Influence of ortho-substitution homolog group on polychlorinated bioaccumulation factors and fugacity ratios in plankton and zebra mussels (dreissena polymorpha). Environ Toxicol Chem 18(7):1380–1389.
*Willman EJ, Manchester-Neesvig JB, Armstrong DE. 1997. Influence of ortho-substitution on patterns of PCB accumulation in sediment, plankton, and fish in a freshwater estuary. Environ Sci Technol 31:3712–3718.
*Wilson N, Shear N, Paustenbach D, . 1998. The effect of cooking practices on the concentration of DDT and PCB compounds in the edible tissue of fish. J Expo Anal Environ Epidemiol 8:423–440.9679221
*Wilson R, Allen-Gill S, Griffin D, . 1995. Organochlorine contaminants in fish from the Arctic Lake in Alaska, USA. Sci Total Environ 160/161:511–519.7892581
Winneke G. 1995. Endpoints of developmental neurotoxicity in environmentally exposed children. Toxicol Lett 77(1–3):127–136.7618126
*Winneke G, Bucholski A, Heinzow B, . 1998a. Neurobehavioral development and TSH-levels in human infants: associations with PCBs in the neonatal period. In: Gies A, Wenzel A, Gahr M, ed. Workshop: Effects of endocrine disruptors in the environment on neuronal development and behaviour-current knowledge, assessment, gaps. Berlin, Germany: Firma Werbung and Vertrieb, Vol. 50, 49–55.
*Winneke G, Bucholski A, Heinzow B, . 1998b. Developmental neurotoxicity of polychlorinated biphenyls (PCBs): cognitive and psychomotor functions in 7-month old children. Toxicol Lett 102–103:423–428.
*Winter S, Streit B. 1992. Organochlorine compounds in a three-step terrestrial food chain. Chemosphere 24(12):1765–1774.
*Wirth EF, Chandler GT, Dipinto LM, . 1994. Assay of polychlorinated biphenyl bioaccumulation from sediments by marine benthic copepods using a novel microextraction technique. Environ Sci Technol 28:1609–1614.22176362
*Wolfe RJ, Walker RJ. 1987. Subsistence economies in Alaska: Productivity, geography, and development impacts. Arctic Anthropology 24(2):56–81.
*Wolff MS. 1985. Occupational exposure to polychlorinated biphenyls (PCBs). Environ Health Perspect 60:133–138.3928344
*Wolff MS, Schecter A. 1991. Accidental exposure of children to polychlorinated biphenyls. Arch Environ Contam Toxicol 20:449–453.1906267
*Wolff MS, Toniolo PG. 1995. Environmental organochlorine exposure as a potential etiologic factor in breast cancer. Environ Health Perspect Suppl 103(7):141–145.
*Wolff MS, Camann D, Gammon M, . 1997. Proposed PCB congener groupings for epidemiological studies. Environ Health Perspect 105(1):13.9074863
Wolff MS, Fischbein A, Rosenman KD, . 1986. Pattern designation of PCBs in human samples. Chemosphere 15:301–307.
*Wolff MS, Fischbein A, Selikoff IJ. 1992. Changes in PCB serum concentrations among capacitor manufacturing workers. Environ Res 59(1):202–216.1425510
*Wolff MS, Fischbein A, Thornton J, . 1982a. Body burden of polychlorinated biphenyls among persons employed in capacitor manufacturing. Int Arch Occup Environ Health 49:199–208.6802767
*Wolff MS, Thornton J, Fischbein A, . 1982b. Disposition of polychlorinated biphenyl congeners in occupationally exposed persons. Toxicol Appl Pharmacol 62:294–306.6800066
*Wolff MS, Toniolo PG, Lee EW, . 1993. Blood levels of organochlorine residues and risk of breast cancer. J Natl Cancer Inst 85(8):648–652.8468722
*Wolff MS, Zeleniuch-Jacquotte A, Dubin N, . 2000. Risk of breast cancer and organochlorine exposure. Cancer Epidemiol Biomarkers Prev 9:271–277.10750665
Wolfle D. 1998. Interactions between 2,3,7,8-TCDD and PCBs as tumor promoters: Limitations of TEFs. Teratogenesis Carcinog Mutagen 17:217–224.
*Wong O. 1995. Pancreatic cancer in workers at a transformer manufacturing plant. Am J Ind Med 27(6):905–910.7645583
*Wong PTS, Kaiser KLE. 1975. Bacterial degradation of polychlorinated biphenyls II. Rate studies. Bull Environ Contam Toxicol 38:249–255.
*Wong PW, Pessah IN. 1996. Ortho-substituted polychlorinated biphenyls alter calcium regulation by a ryanodine receptor-medicated mechanism: Structural specificity toward skeletal- and cardiac-type microsomal calcium release channels. Mol Pharmacol 49:740–751.8609904
*Wong PW, Pessah IN. 1997. Noncoplanar PCB 95 alters microsomal calcium transport by an immunophilin FKBP 12-dependent mechanism. Mol Pharmacol 51:693–702.9145907
*Wong PW, Brackney WR, Pessah IN. 1997. Ortho-Substituted polychlorinated biphenyls alter microsomal calcium transport by direct interaction with ryanodine receptors of mammalian brain. J Biol Chem 272(24):15145–15153.9182535
Wormworth J. 1995. Toxins and tradition: The impact of food-chain contamination on the Inuit of northern Quebec. Can Med Assoc J 152(8):1237–1240.7736374
*Wren CD, Hunter DB, Leatherland JF, . 1987a. The effects of polychlorinated biphenyls and methylmercury, singly and in combination, on mink. I: Uptake and toxic responses. Arch Environ Contam Toxicol 16:441–447.3111390
*Wren CD, Hunter DB, Leatherland JF, . 1987b. The effects of polychlorinated biphenyls and methylmercury, singly and in combination on mink. II: Reproductive and kit development. Arch Environ Contam Toxicol 16:449–454.3111391
*Wu Q, Bedard DL, Wiegel J. 1996. Influence of incubation temperature on the microbial reductive dechlorination of 2,3,4,6-tetrachlorobiphenyl in two freshwater sediments. Appl Environ Microbiol 62(11):4174–4179.16535443
*Wu Q, Bedard DL, Wiegel J. 1997. Temperature determines the pattern of anaerobic microbial dechlorination of Aroclor 1260 primed by 2,3,4,6-tetrachlorobiphenyl in Woods Pond sediment. Appl Environ Microbiol 63(12):4818–4825.9406401
*Wu Q, Sowers KR, May HD. 1998. Microbial reductive dechlorination of Aroclor 1260 in anaerobic slurries of estuarine sediments. Appl Environ Microbiol 64(3):1052–1058.16349512
Wyndham C, Safe S. 1978. In vitro metabolism of 4-chlorobiphenyl by control and induced rat liver microsomes. Biochemistry 17:208–215.619985
*Wyss PA, Muhlebach S, Bickel MH. 1986. Long-term pharmacokinetics of 2,2’,4,4’,5,5’-hexachloro-biphenyl (6-CB) in rats with constant adipose tissue mass. Drug Metab Dispos 14:361–365.2872039
Yaffe BA, Reeder BA. 1989. An epidemiologic assessment of exposure of children to polychlorinated biphenyls (PCBs) in a Toronto community. Can J Public Health 80:325–329.2509058
*Yakushiji T, Watanabe I, Kuwabara K, . 1978. Long-term studies of the excretion of polychlorinated biphenyls (PCBs) through the mother’s milk of an occupationally exposed worker. Arch Environ Contam Toxicol 7:493–504.755447
*Yakushiji T, Watanabe I, Kuwabara K, . 1984. Postnatal transfer of PCBs from exposed mothers to their babies: Influence of breast-feeding. Arch Environ Health 39:368–375.6439130
*Yamaguchi A, Yoshimura T, Kuratsune M. 1971. Investigation concerning babies born from women who consumed oil contaminated with chlorobiphenyl. Fukuoka Igaku Zasshi 62:117–22.
*Yassi A, Tate R, Fish D. 1994. Cancer mortality in workers employed at a transformer manufacturing plant. Am J Ind Med 25(3):425–437.8160660
*Ye D, Quensen III JF, Tiedje JM, . 1992a. Anaerobic dechlorination of polychlorobiphenyls (Aroclor 1242) by pasteurized and ethanol-treated microorganisms from sediments. Appl Environ Microbiol 58:1110–1114.1599235
*Ye D, Quensen JFIII, Tiedje JM, . 1999. 2-Bromoethanesulfonate, sulfate, molybdate, and ethanesulfonate inhibit anaerobic dechlorination of polychlorobiphenyls by pasteurized microorganisms. Appl Environ Microbiol 65(1):327–329.9872802
*Ye Q, Puri RK, Kapila S, . 1992b. Studies on the transport and transformation of PCBs in plants. Chemosphere 25(7–10):1475–1479.
*Ylitalo GM, Buzitis J, Krahn MM. 1999. Analyses of tissues of eight marine species from Atlantic and Pacific coasts for dioxin-like chlorobiphenyls (Cbs) and total Cbs. Arch Environ Contam Toxicol 37:205–219.10398771
*Yoshimura H, Yamamoto HA. 1975. A novel route of excretion of 2,4,3’,4’-tetrachlorobiphenyl in rats. Bull Environ Contam Toxicol 13:681–688.806316
Yoshimura H, Yonemoto Y, Yamada H, . 1987. Metabolism in vivo of 3,4,3’,4’-tetrachlorobiphenyl and toxicological assessment of the metabolites in rats. Xenobiotica 17:897–910.3118581
*Yoshimura H, Yoshihara S, Ozawa N, . 1979. Possible correlation between induction modes of hepatic enzymes by PCBs and their toxicity in rats. Ann NY Acad Sci 320:179–192.110191
*Yoshimura T. 1974. [Epidemiological study on Yusho babies born to mothers who had consumed oil contaminated by PCB.] Fukuoka Igaku Zasshi 65:74–80. (Japanese)
*Yoshimura T, Ikeda M. 1978. Growth of school children with polychlorinated biphenyl poisoning or Yusho. Environ Res 17:416–425.122586
*Young D, Becerra M, Kopec D, . 1998. GC/MS analysis of PCB congeners in blood of the harbor seal phoca vitulina from San Francisco Bay. Chemosphere 37(4):711–733.9693840
Young SS. 1985. Letter to the editor. Toxicol Appl Pharmacol 78:321–322.3929428
*Yu M-L, Hsin J-W, Hsu C-C, . 1998. The immunologic evaluation of the Yucheng children. Chemosphere 37(9–12):1855–1865.9828314
Zabik ME, Booren A, Zabik MJ, . 1996. Pesticide residues, PCBs and PAH in baked, charbroiled, salt boiled and smoked Great Lakes lake trout. Food Chemistry 55(3):231–239.
Zabik ME, Zabik MJ, Booren AM, . 1995. Pesticides and total polychlorinated biphenyls residues in raw and cooked walleye and white bass harvested from the Great Lakes. Bull Environ Contam Toxicol 54(3):396–402.7749272
*Zhang H, Eisenreich SJ, Franz TR, . 1999. Evidence for increased gaseous PCB fluxes to Lake Michigan from Chicago. Environ Sci Technol 33(13):2129–2137.
*Zhang P-C, Scrudato RJ, Pagano JJ, . 1993. Photodecomposition of PCBs in aqueous systems using TiO_2_ as catalyst. Chemosphere 26(6):1213–1223.
*Zhang S, Rusling JF. 1995. Dechlorination of polychlorinated biphenyls on soils and clay by electrolysis in a bicontinuous microemulsion. Environ Sci Technol 29(5):1195–1199.22192011
*Zhang Y, Rott B, Freitag D. 1983. Accumulation and elimination of ^14^C-PCBs by daphnia magna straus 1820. Chemosphere 12:1645–1651.
*Zhao F, Mayura K, Harper N, . 1997b. Inhibition of 3,3’,4,4’,5-pentachlorobiphenyl-induced fetal cleft palate and immunotoxicity in C57BL/6 mice by 2,2’,4,4’,5,5’-hexachlorobiphenyl. Chemosphere 34(5–7):1605–1613.9134691
*Zhao F, Mayura K, Kocurek N, . 1997a. Inhibition of 3,3’,4,4’,5-pentachlorobiphenyl-induced chicken embryotoxicity by 2,2’,4,4’, 5,5’-hexachlorobiphenyl. Fundam Appl Toxicol 35(1):1–8.9024668
*Zheng T, Holford TR, Mayne ST, . 2000. Risk of female breast cancer associated with serum polychlorinated biphenyls and 1,1-dichloro-2,2’-bis(p-chlorophenyl)ethylene. Cancer Epidemiol Biomarkers Prev 9:167–174.10698477
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zoeller RT, Dowling ALS, Vas AA. 2000. Developmental exposure to polychlorinated biphenyls exerts thyroid hormone-like effects on the expression of RC3/neurogranin and myelin basic protein messenger ribonucleic acids in the developing rat brain. Endocrinology 141(1):181–189.10614638
*Zupancic-Kralj L, Jan J, Marsel J. 1992. Assessment of polychlorobiphenyls in human/poultry fat and in hair/plumage from a contaminated area. Chemosphere 25(12):1861–1867.
*Zwiernik MJ, Quensen JF III, Boyd SA. 1998. FeSO4 amendments stimulate extensive anaerobic PCB dechlorination. Environ Sci Technol 32:3360–3365.