# ERRATA

## Errata

The following errors in the Tox Profile PDF were corrected when it was converted to XML:

- PDF page 277: Section 3.2.9.2.2 was changed to Section 3.2.8.2.2
- PDF page 370: Section 2.5.2 was changed to Section 3.5.2
- PDF page 434: Section 5.7 was changed to Section 6.7
- PDF page 612: "Sections 3.3.1, 3.3.2, and 3.3.3" was changed to "Sections 3.4.1 and 3.4.2"