# APPENDIX C ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienists
ADI: Acceptable Daily Intake
ADME: Absorption, Distribution, Metabolism, and Excretion
AFID: alkali flame ionization detector
AFOSH: Air Force Office of Safety and Health
AML: acute myeloid leukemia
AOAC: Association of Official Analytical Chemists
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
AWQC: Ambient Water Quality Criteria
BAT: Best Available Technology
BCF: bioconcentration factor
BEI: Biological Exposure Index
BSC: Board of Scientific Counselors
C: Centigrade
CAA: Clean Air Act
CAG: Cancer Assessment Group of the U.S. Environmental Protection Agency
CAS: Chemical Abstract Services
CDC: Centers for Disease Control and Prevention
CEL: Cancer Effect Level
CELDS: Computer-Environmental Legislative Data System
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
Ci: curie
CL: ceiling limit value
CLP: Contract Laboratory Program
cm: centimeter
CML: chronic myeloid leukemia
CNS: central nervous system
CPSC: Consumer Products Safety Commission
CWA: Clean Water Act
d: day
Derm: dermal
DHEW: Department of Health, Education, and Welfare
DHHS: Department of Health and Human Services
DNA: deoxyribonucleic acid
DOD: Department of Defense
DOE: Department of Energy
DOL: Department of Labor
DOT: Department of Transportation
DOT/UN/: Department of Transportation/United Nations/
NA/IMCO: North America/International Maritime Dangerous Goods Code
DWEL: Drinking Water Exposure Level
ECD: electron capture detection
ECG/EKG: electrocardiogram
EEG: electroencephalogram
EEGL: Emergency Exposure Guidance Level
EPA: Environmental Protection Agency
F: Fahrenheit
F_1_: first-filial generation
FAO: Food and Agricultural Organization of the United Nations
FDA: Food and Drug Administration
FEMA: Federal Emergency Management Agency
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
FPD: flame photometric detection
fpm: feet per minute
ft: foot
FR: Federal Register
g: gram
GC: gas chromatography
Gd: gestational day
gen: generation
GLC: gas liquid chromatography
GPC: gel permeation chromatography
HPLC: high-performance liquid chromatography
hr: hour
HRGC: high resolution gas chromatography
HSDB: Hazardous Substance Data Bank
IDLH: Immediately Dangerous to Life and Health
IARC: International Agency for Research on Cancer
ILO: International Labor Organization
in: inch
IRIS: Integrated Risk Information System
Kd: adsorption ratio
kg: kilogram
kkg: metric ton
K_oc_: organic carbon partition coefficient
K_ow_: octanol-water partition coefficient
L: liter
LC: liquid chromatography
LC_Lo_: lethal concentration, low
LC_50_: lethal concentration, 50% kill
LD_Lo_: lethal dose, low
LD_50_: lethal dose, 50% kill
LT_50_: lethal time, 50% kill
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
m: meter
MA: trans,trans-muconic acid
MAL: Maximum Allowable Level
mCi: millicurie
MCL: Maximum Contaminant Level
MCLG: Maximum Contaminant Level Goal
mg: milligram
min: minute
mL: milliliter
mm: millimeter
mm Hg: millimeters of mercury
mmol: millimole
mo: month
mppcf: millions of particles per cubic foot
MRL: Minimal Risk Level
MS: mass spectrometry
NAAQS: National Ambient Air Quality Standard
NAS: National Academy of Science
NATICH: National Air Toxics Information Clearinghouse
NATO: North Atlantic Treaty Organization
NCE: normochromatic erythrocytes
NCI: National Cancer Institute
NIEHS: National Institute of Environmental Health Sciences
NIOSH: National Institute for Occupational Safety and Health
NIOSHTIC: NIOSH’s Computerized Information Retrieval System
NFPA: National Fire Protection Association
ng: nanogram
NLM: National Library of Medicine
nm: nanometer
NHANES: National Health and Nutrition Examination Survey
nmol: nanomole
NOAEL: no-observed-adverse-effect level
NOES: National Occupational Exposure Survey
NOHS: National Occupational Hazard Survey
NPD: nitrogen phosphorus detection
NPDES: National Pollutant Discharge Elimination System
NPL: National Priorities List
NR: not reported
NRC: National Research Council
NS: not specified
NSPS: New Source Performance Standards
NTIS: National Technical Information Service
NTP: National Toxicology Program
ODW: Office of Drinking Water, EPA
OERR: Office of Emergency and Remedial Response, EPA
OHM/TADS: Oil and Hazardous Materials/Technical Assistance Data System
OPP: Office of Pesticide Programs, EPA
OPPTS: Office of Prevention, Pesticides and Toxic Substances, EPA
OPPT: Office of Pollution Prevention and Toxics, EPA
OSHA: Occupational Safety and Health Administration
OSW: Office of Solid Waste, EPA
OTS: Office of Toxic Substances
OW: Office of Water
OWRS: Office of Water Regulations and Standards, EPA
PAH: Polycyclic Aromatic Hydrocarbon
PBPD: Physiologically Based Pharmacodynamic
PBPK: Physiologically Based Pharmacokinetic
PCE: polychromatic erythrocytes
PEL: permissible exposure limit
PID: photo ionization detector
pg: picogram
pmol: picomole
PHS: Public Health Service
PMR: proportionate mortality ratio
PPb: parts per billion
ppm: parts per million
ppt: parts per trillion
PSNS: Pretreatment Standards for New Sources
REL: recommended exposure level/limit
RfC: Reference Concentration
RfD: Reference Dose
RNA: ribonucleic acid
RTECS: Registry of Toxic Effects of Chemical Substances
RQ: Reportable Quantity
SARA: Superfund Amendments and Reauthorization Act
SCE: sister chromatid exchange
sec: second
SIC: Standard Industrial Classification
SIM: selected ion monitoring
SMCL: Secondary Maximum Contaminant Level
SMR: standard mortality ratio
SNARL: Suggested No Adverse Response Level
SPEGL: Short-Term Public Emergency Guidance Level
STEL: short-term exposure limit
STORET: Storage and Retrieval
TD_50_: toxic dose, 50% specific toxic effect
TLV: threshold limit value
TOC: Total Organic Compound
TPQ: Threshold Planning Quantity
TRI: Toxics Release Inventory
TSCA: Toxic Substances Control Act
TRI: Toxics Release Inventory
TWA: time-weighted average
U.S.: United States
UF: uncertainty factor
VOC: Volatile Organic Compound
yr: year
WHO: World Health Organization
wk: week

>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to
%: percent
α: alpha
β: beta
γ: gamma
δ: delta
μm: micrometer
μg: microgram
q_1_*: cancer slope factor
−: negative
+: positive
(+): weakly positive result
(−): weakly negative result