# APPENDIX A ATSDR MINIMAL RISK LEVEL AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | PCBs
CAS Number: | 11097-69-1
Date: | September 2000
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ X] Intermediate [ ] Chronic
Key to Figure: | 87k
Species: | Monkey

[underlined: Minimal Risk Level]: 0.03 [X] µg/kg/day [ ] ppm

[underlined: Reference]: Rice 1997, 1998, 1999b; Rice and Hayward 1997, 1999a

[underlined: Experimental design:] A series of studies were conducted that investigated effects of postnatal exposure to a PCB congener mixture, representing 80% of the congeners present in breast milk in Canadian women, on learning in monkeys. Groups of five and eight male monkeys were orally administered doses of 0 or 0.0075 mg/kg/day, respectively, from birth to 20 weeks of age. The daily dose was divided into thirds and administered prior to the first three daily feedings via syringe to the back of the mouth. The dose level represents the approximate daily intake of a nursing human infant whose mother’s milk contained 50 ppb PCBs (the Health Canada guideline for maximum concentration in breast milk). At the end of the dosing period (i.e., at 20 weeks of age), the levels of PCBs in fat and blood in the treated monkeys were 1.7–3.5 ppm and 1.84–2.84 ppb, respectively. Corresponding values in the control monkeys were 0.05–0.20 ppm and 0.30–0.37 ppb. Beginning at 3 years of age, the monkeys were tested on a series of nonspatial discrimination reversal problems followed by a spatial delayed alternation task. Additional testing was done at 4.5 and 5 years of age.

[underlined: Effects noted in study and corresponding doses]: Treated monkeys showed decreased median response latencies and variable increases in mean response latencies across three tasks of nonspatial discrimination reversal. There was no difference in overall accuracy of the tests or correlation between performance and tissue levels of PCBs. Treated monkeys also displayed retarded acquisition of a delayed alternation task and increased errors at short delay task responses. These findings were interpreted as a learning/performance decrement rather than an effect on memory per se. In a separate portion of this study (Rice 1997), treated monkeys displayed shorter mean interresponse times when compared with controls. The increase in pause time for fixed-interval performance emerged more slowly across 48 sessions in treated monkeys. For fixed-ratio performance tasks, the control monkeys decreased their mean pause time across 10 sessions, whereas the treated monkeys did not. Rice (1997) interpreted these results as suggesting learning deficit, perseveration, and/or inability to inhibit inappropriate responding as a result of postnatal PCB exposure. Testing of these monkeys at 4.5–5 years of age showed that treated animals performed in a less efficient manner than controls under a differential reinforcement of low rate (DRL) schedule of reinforcement (Rice 1998). There were no differences between groups on the accuracy of performance on a series of spatial discrimination reversal tasks, although some treated monkeys made more errors than others on certain parts of the experiment. Further tests conducted at about 5 years of age did not find treatment-related effects on a series of concurrent RI-RI (random interval) schedules of reinforcement (Rice and Hayward 1999a). This schedule was designed to study behavior in transition (learning) as well as at steady state. However, there was a difference between treated and control monkeys on performance on a progressive ratio (PR) schedule. Rice and Hayward (1999a) stated that this finding may be indicative of retarded acquisition of the steady-state PR performance in treated monkeys.

[underlined: Dose and end point used for MRL derivation]: The tested dose level, 0.0075 mg/kg/day, is a less serious LOAEL for neurobehavioral toxicity. This LOAEL is a particularly appropriate basis for MRL derivation due to the human relevance of the tested PCB mixture (a congener mixture analogous to that in human breast milk), dose level (approximate daily intake of a nursing human infant whose mother’s milk contained 50 ppb PCBs), and resulting PCB tissue and blood levels (near background concentrations found in the general human population). Support for the LOAEL is provided by the occurrence of minimal immunological alterations in the same monkeys at 0.0075 mg/kg/day (Arnold et al. 1999), as well as clinical signs of toxicity (ocular and dermal changes) and decreased antibody responses in offspring of monkeys that were exposed to a similar dose level of Aroclor 1254 (0.005 mg/kg/day) for approximately 46 weeks during gestation and nursing (Arnold et al. 1995); these studies are summarized below in the other pertinent information section.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NA

[underlined: Was a conversion used from intermittent to continuous exposure?]

No

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

The monkeys that were evaluated for neurodevelopmental toxicity by Rice and coworkers were also tested for other kinds of effects earlier in life (Arnold et al. 1999). Following exposure to 0.0075 mg/kg/day of the simulated human milk congener mixture during the first 20 weeks of life, the monkeys were periodically examined for the following endpoints for at least the following 46 weeks: bone development (at birth); general health status; formula intake; food and water consumption; body weight; tooth eruption; somatic measurements; and hematology, serum biochemistry, and immunology indices. Immunological assessment of the infants was started at 22 weeks of age and included IgM and IgG antibody production following immunization with SRBC, lymphoproliferative activity of peripheral leucocytes in response to mitogens (PHA, ConA, and PWM), numbers of peripheral leucocytes and their subsets, and NK cell activity. Few statistically significant changes were observed in any of the monitored parameters. Anti-SRBC titers were reduced in the treated monkeys but not significantly different from controls. Absolute mean numbers of B lymphocytes were significantly lower in treated monkeys (no change in mean percent), but the effect was transient because it was not observed when re-evaluated in the monkeys at 1 year of age. The investigators concluded that, overall, the effects on the infant immune system were mild and of unclear biological significance due to large inter-animal variability related to small numbers of animals.

In another study (Arnold et al. 1995), oral exposure of adult female monkeys for approximately 44 months (total exposure; pre-conception, gestation, and lactation) to a similarly low dose (0.005 mg/kg/day) of an Aroclor PCB mixture resulted in immunological and dermal/ocular effects in their offspring. Groups of 16 female Rhesus monkeys self-ingested capsules containing Aroclor 1254 in a glycerol/corn oil mixture (1:1) in doses of 0, 0.005, 0.02, 0.04, or 0.08 mg/kg/day. After 25 months of exposure, approximately 90% of the animals had attained an apparent pharmacokinetic steady state with respect to adipose concentrations of PCBs. After 37 months of exposure, the females were mated with untreated males, and dosing was continued throughout breeding and gestation and into the first part of the lactation period. Maternal treatment was discontinued when the infants were 7 weeks old (to preclude ingestion of the mother’s dosing capsule) and resumed after the infants were weaned at age 22 weeks. Mothers were dosed with PCBs for 37 months prior to mating, and infants born to these mothers were exposed for a duration of approximately 46 weeks (average 24 weeks gestation plus 22 weeks nursing). Study end points included numbers of impregnations, live infants, postpartum deaths, abortions, suspected resorptions, stillbirths, and gestation length. On the day of parturition all infants were x-rayed to ascertain osseus development. Body weight, clinical health, hematology, and serum biochemistry were periodically evaluated in the infants and maternal animals during the lactation period, and subsequently in the dams until the infants were 78 weeks old and in the infants until they were 122 weeks old. The offspring were also evaluated for changes in tooth eruption and anthropometric measurements throughout the study, and immunological changes when they were 20 and 60 weeks old. Four immunological tests were performed: IgM and IgG antibodies to SRBC; lymphocyte proliferation response to PHA, ConA, and PWM mitogens; mixed lymphocyte culture assay (one-way); and natural killer cell activity. Most of the control and all treated offspring were autopsied at 122 weeks of age.

PCB-related effects were induced in the adult monkeys and their offspring (Arnold et al. 1995). Conception rate was significantly reduced at 0.02 mg/kg/day and higher doses. Because this effect occurred in the adult animals that were mated after 37 months of exposure, 0.02 mg/kg/day is a serious LOAEL for reproductive toxicity for chronic-duration exposure. Exposure during gestation and lactation resulted in both fetal toxicity and postnatal effects in the offspring. Fetal mortality was increased at 0.02 mg/kg/day and higher doses. Incidence rates for fetal mortality (combined abortions, suspected resorptions, and stillbirths) were 2/11, 5/10, 3/4, 2/6, and 4/5 in impregnated monkeys in the 0, 0.005, 0.02, 0.04, and 0.08 mg/kg/day groups, respectively, and displayed a significant increasing dose-related trend (p=0.040). Statistical comparison of the treated and control groups showed that the fetal mortality incidence rates were increased at 0.02 mg/kg/day (p=0.077) and significantly increased at 0.08 mg/kg/day (p=0.036). The precision of this statistical comparison is limited by the small numbers of animals, which obscures the high response rate in the 0.02 mg/kg/day group (i.e., that there were 3 fetal deaths in 4 impregnated animals, and that the combined incidence of fetal and neonatal deaths was 4/4). Evaluation of the offspring, limited by the small numbers of surviving animals, showed mild clinical manifestations of PCB exposure and some immunological test differences at 0.005 and 0.04 mg/kg/day (no infants survived beyond postpartum week 2 in the other dose groups). The major clinical signs in the surviving exposed offspring were inflammation and/or enlargement of the tarsal (Meibomian) gland, nail lesions, and gum recession. For example, in the control, 0.005, and 0.04 mg/kg/day dose groups, incidences of tarsal gland inflammation and/or enlargement were 1/9, 4/4, and 3/3; incidences of nail bed prominence were 0/9, 3/4, and 3/3; incidences of elevated nails were 0/9, 2/4, and 2/3; incidences of nails folding on themselves were 0/9, 1/4, and 3/3; and incidences of gum recession were 0/9, 1/4, and 2/3. Immunological alterations in the exposed offspring mainly included suppressed antibody responses to SRBC. IgM antibody levels to SRBCs were significantly reduced in comparison to controls at 0.005 and 0.04 mg/kg/day at week 22 (p=0.056 and 0.023, respectively) and week 23 (p=0.043 and 0.029, respectively), and at 0.005 mg/kg/day at weeks 61, 62, and 63 (p=0.028, 0.043, and 0.056, respectively). IgM titers were also suppressed at 0.04 mg/kg/day during weeks 61, 62, and 63, but statistical significance was precluded by the small number of infants (n=2) in this group. Other immunological changes included significantly reduced mitogen (ConA)-induced lymphocyte proliferation compared to controls at 0.04 mg/kg/day at weeks 28 and 60 (p=0.036 and 0.053, respectively). Although evaluation of the offspring data is complicated by the small number of animals, it is highly relevant that the clinical and immunological effects in the infants are similar to those observed in their chronically exposed dams at the same dose levels as low as 0.005 mg/kg/day (Arnold et al. 1993a, 1993b; Tryphonas et al. 1989, 1991a, 1991b). The effects on the dams are detailed in the in the worksheet for the chronic oral MRL.

Evidence that the 0.0075 mg/kg/day less serious LOAEL is an appropriate dose level for intermediate-duration MRL derivation is provided by the observation that the next highest tested dose level in monkeys (or any other species) is 0.02 mg/kg/day (Arnold et al. 1995), which is a serious LOAEL for fetal mortality as indicated above.

[underlined: Agency Contact (Chemical Manager):] Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | PCBs
CAS Number: | 11097-69-1
Date: | September 2000
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Key to Figure: | 148k
Species: | Monkey

[underlined: Minimal Risk Level]: 0.02 [X] µg/kg/day [ ] ppm

[underlined: Reference]: Tryphonas et al. 1989, 1991a

[underlined: Experimental design:] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details):

Groups of 16 female Rhesus monkeys self-ingested capsules containing Aroclor 1254 in a glycerol/corn oil mixture (1:1) in doses of 0, 0.005, 0.02, 0.04, or 0.08 mg/kg/day. The monkeys were challenged with injected sheep red blood cells (SRBC) at 23 months of exposure and received a secondary challenge with SRBC at 55 months. The animals had achieved an apparent pharmacokinetic steady state at 23 months based on PCB concentrations in blood and fat. End points examined at 23 months (Tryphonas et al. 1989) included: antibody titers (IgG and IgM) to SRBC, lymphocyte transformation in response to two mitogens (PHA and ConA), quantitation of T- and B-lymphocytes, total serum immunoglobulin levels (IgG, IgM, and IgA), serum proteins, and serum hydrocortisone level. End points examined at 55 months (Tryphonas et al. 1991a, 1991b) included: body weights, IgM and IgG titers in response to secondary immunization with SRBC, lymphocyte proliferation in response to three mitogens (PHA, ConA, and PWM), mix lymphocyte culture assay, phagocytic activity of peripheral blood monocytes following stimulation with phorbol myristate acetate (PMA) or Zymosan, interleukin 1 production in response to E. coli, lymphocyte subpopulation analysis, antibody response to pneumococcus antigens, serum hydrocortisone level, serum complement activity, natural killer cell activity, levels of serum thymosins, interferon production by Con A-stimulated leukocytes, and tumor necrosis factor production. As indicated below in the other pertinent information section, clinical health findings (Arnold et al. 1993a) and reproduction and offspring findings (Arnold et al. 1995) were also reported for the monkeys that were tested for immunotoxicity.

[underlined: Effects noted in study and corresponding doses]:

IgM (all doses except 0.02 mg/kg/day) and IgG (all doses) antibody levels to SRBC were significantly reduced compared to controls after 23 months, although no clear dose-response relationships were observed (Tryphonas et al. 1989). Secondary challenge with SRBC after 55 months showed decreasing dose-related trends in the IgM and IgG anamnestic responses, although only IgM was significantly lower than controls at all dose levels (Tryphonas et al. 1991a). Other immunologic changes included alterations in lymphocyte T-cell subsets characterized by a significantly decreased ratio of T-inducer/helper (CD4) cells to T-cytotoxic/suppressor (CD8) cells, due to reduced CD4 and increased CD8 cells, at 0.08 mg/kg/day (not tested at lower doses) after 23 months. No effects on total lymphocytes or B-cells were found, indicating that T-cells were preferentially affected by the PCBs, although there were no exposure-related changes in T-cell subsets after 55 months suggesting that adaptation had occurred. Statistically significant dose-related trends, but no significant differences between exposed and control groups, were observed after 55 months for decreasing lymphocyte proliferation in response to mitogens (PHA and ConA, but not PWM), increasing NK cell activity, increasing levels of serum thymosin alpha-1, decreasing phagocytic activity of peripheral blood monocytes following activation with PMA, and increasing total serum complement activity.

[underlined: Dose and end point used for MRL derivation]: The lowest dose level tested, 0.005 mg/kg/day, is a LOAEL for decreased antibody response. Interpretation of the adversity of this effect is complicated by a lack of data on immunocompetence and the essentially inconclusive findings in the other tested end points; however, support for the 0.005 mg/kg/day LOAEL is provided by mild clinical manifestations of toxicity at the same dose. As indicated below in the other pertinent information section, eyelid and toe/finger nail changes were observed in some monkeys at doses as low as 0.005 mg/kg/day (Arnold et al. 1993a).

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?]

No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

NA

[underlined: Was a conversion used from intermittent to continuous exposure?]

No

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

No other studies investigated immunological effects of chronic exposure to PCBs. Intermediate-duration studies, however, have conclusively shown that oral exposure to commercial PCB mixtures can induce morphological and functional alterations in the immune system of rats, mice, guinea pigs, and monkeys. Effects in the non-primate species occurred at relatively high doses (generally $4 mg/kg/day) and included decreased thymus and spleen weights in rats, mice, and guinea pigs exposed to Aroclors 1260, 1254, or 1248 (Allen and Abrahamson 1973; Bonnyns and Bastomsky 1976; Smialowicz et al. 1989; Street and Sharma 1975; Vos and Van Driel-Grootenhuis 1972); reduced antibody responses to tetanus toxoid in guinea pigs exposed to Clopen A-60, keyhole limpet hemocyanin in rats exposed to Aroclor 1254, and SRBC in mice exposed to Aroclor 1242 (Exon et al. 1985; Loose et al. 1977, 1978a, 1978b, 1979; Vos and Van Driel-Grootenhuis 1972); increased susceptibility to infection by Moloney leukemia virus in mice exposed to Aroclor 1254 or 1242, herpes simplex virus in mice exposed to Kanechlor 500, and bacterial endotoxin and malarial parasite in mice exposed to Aroclor 1242 (Imanishi et al. 1980; Koller 1977; Loose et al. 1979); reduced skin reactivity to tuberculin in guinea pigs exposed to Clopen A-60 (Vos and Van Driel-Grootenhuis 1972); and reduced NK cell activity in rats exposed to Aroclor 1254 (Smialowicz et al. 1989; Talcott et al. 1985).

Intermediate-duration oral studies of Aroclors in monkeys confirm the observations of PCB immunotoxicity in rats, mice, and guinea pigs, indicate that non-human primates are more sensitive than the other species, and support the findings of the chronic immunotoxicity study in monkeys (Tryphonas et al. 1989, 1991a, 1991b) used as the basis of the chronic oral MRL. Results of intermediate-duration studies in monkeys included decreased antibody responses to SRBC, increased susceptibility to bacterial infections, and/or histopathological changes in the thymus, spleen, and lymph nodes in adult monkeys and their offspring at 0.1–0.2 mg/kg/day doses of Aroclor 1254 and 1248 (Abrahamson and Allen 1973; Allen and Barsotti 1976; Allen et al. 1980; Barsotti et al. 1976; Thomas and Hinsdill 1978; Truelove et al. 1982; Tryphonas et al. 1986a). Additionally, results of studies in infant monkeys are consistent with the data in adults showing immunosuppressive effects of Aroclor 1254 at doses as low as 0.005 mg/kg/day. Evaluation of in utero and lactationally exposed offspring from the monkeys in the Tryphonas et al. (1989, 1991a, 1991b) studies indicated exposure-related reductions in IgM antibody levels to SRBC and mitogen-induced lymphocyte transformation that paralleled the findings in the maternal animals (Arnold et al. 1995).

Support for the chronic LOAEL of 0.005 mg/kg/day is provided by clinical observations on the same monkeys that were immunologically evaluated by Tryphonas et al. (1989, 1991a, 1991b). Examinations of the monkeys exposed to 0.005–0.08 mg/kg/day Aroclor 1254 during the first 37 months of the study showed characteristic dose-related ocular and dermal effects, including eye exudate, inflammation and/or prominence of the tarsal (Meibomian) glands, and various finger and toe nail changes (Arnold et al. 1993a). Statistical analyses found significant increasing dose-related trends in incidence rates, total frequency of observed occurrences and/or onset times for these effects, with some treated and control group comparisons showing significant differences at doses as low as 0.005 mg/kg/day. Effects that were significantly increased in the 0.005 mg/kg/day group included increased total frequencies of inflamed and/or prominent tarsal glands, toenail separations, and elevated toenails. Additionally, monkeys from this study that were mated after 37 months of exposure and continued to be exposed to $0.005 mg/kg/day Aroclor 1254 through gestation and lactation had offspring with clear clinical signs of PCB intoxication, manifested as inflammation and/or enlargement of the tarsal glands, nail lesions, and gum recession (Arnold et al. 1995). Further, the next highest dose level in this study (0.02 mg/kg/day) is a chronic serious LOAEL for reproductive toxicity (reduced conception rate) (Arnold et al. 1995). Conception rate, adjusted for the total number of matings, was significantly lower than controls at 0.02, 0.04, and 0.08 mg/kg/day (p=0.009, 0.039, and 0.005, respectively), but not at 0.005 mg/kg/day (p=0.085). Similar results were noted after adjustment for the number of matings with positive sires. There was a significant (p=0.017) decrease in conception rate with increasing dose with both types of mating adjustments. Percentages of impregnations (number impregnated/number available) in the 0, 0.005, 0.02, 0.04, and 0.08 mg/kg/day groups were 69, 63, 27, 43, and 33%, respectively. The $0.02 mg/kg/day doses in this study are also serious effect levels for developmental toxicity (fetal mortality), as discussed in the worksheet for the intermediate-duration oral MRL.

[underlined: Agency Contact (Chemical Manager):] Obaid Faroon

Table A-1 PCB Concentrations in Blood and Breast Milk in Epidemiology Studies

Study | Mean PCB concentrations | | Basis of analysis | Health effects
Study | Blood (wet basis) | Breast milk (lipid basis) | Basis of analysis | Health effects
Michigan Mother-Child Study; (Fein et al. 1984a, 1984b; Jacobson and Jacobson 1996a, 1997; Jacobson et al. 1984a, 1985, 1990a, 1990b, 1992) | maternal serum:; 6.1 ppb (fisheaters); 4.1 ppb (nonfisheaters); cord serum:; 2.0 ppb | 866 ppb (fisheaters); 622 ppb (nonfisheaters) | total PCBs | Exposure from consumption of contaminated sportfish (Lake Michigan). Reduced birth weight, head circumference and gestational age in newborns, neurobehavioral alterations in newborn and older children^a^.
Oswego Newborn and Infant Development Project; (Lonky et al. 1996; Stewart et al. 1999, 2000a) | cord blood:; 0.8 ppb (fisheaters)^b^; 1.03 ppb (nonfisheaters) | NR^c^ | total PCBs (68 congeners) | Exposure from consumption of contaminated sportfish (Lake Ontario). Neurobehavioral alterations in newborn children^d^.
Wives of Swedish Fisherman Cohort Study; (Rylander et al. 1995, 1998b) | maternal serum:; 1.0 ppb (median, fisheaters); 0.92 ppb (median, nonfisheaters) | NR | PCB 153 | Exposure from consumption of fatty fish (Baltic Sea). Increased risk of low birth weight was associated with increasing maternal serum levels of PCB 153 (300-400 ppb).
Lake Michigan Aging Population Study; (Schantz et al. 1996a, 1999) | adult serum:; 16.0 ppb (fisheaters); 6.2 ppb (nonfisheaters) | NR | total PCBs | Exposure from consumption of contaminated sportfish (Lake Michigan). No significant effects on visual-motor coordination and hand steadiness tests in adults.
New York State Angler Cohort Study; (Buck et al. 1997, 1999, 2000; Kostyniak et al. 1999; Mendola et al. 1995a, 1997) | NR^e^ | NR | NA | Exposure from consumption of contaminated sportfish (Lake Ontario). Assessments of female and male reproductive endpoints found indications of fish consumption-related reductions in menstrual cycle length and female fecundability.
Michigan Anglers Cohort Study; (Courval et al. 1999) | NR^e^ | NR | NA | Exposure from consumption of contaminated sportfish (Lake Erie, Lake Huron, or Lake Michigan). Associations between conception delay and fish consumption were found in exposed men but not their wives.
Inuit Infant Study; (Dewailly et al. 2000) | NR | 621 ppb | E 3 non-dioxin-like congeners (PCBs 138, 153, and 180) | Exposure from consumption of arctic sea mammal fat and other marine foods. Some immunologic alterations were associated with exposure to PCBs as well as other organochlorine compounds^f^.
North Carolina Breast Milk and Formula Project; (Gladen et al. 1988; Longnecker et al. 2000; Rogan and Gladen 1991, 1992; Rogan et al. 1986a, 1986b, 1987) | maternal serum:; 9.06 ppb (median); cord serum:; <4.27 ppb (median) | 1.8 ppm^g^ | total PCBs | General population exposure. Neurobehavioral alterations in infants^h^. No associations between PCBs and birth weight, head circumference, or thyroid hormones.
Dutch Mother-Child Study; (Huisman et al. 1995a, 1995b; Koopman-Esseboom et al. 1994a, 1994b, 1996; Lanting et al. 1998c; Patandin et al. 1999; Weisglas-Kuperus et al. 1995) | NR | 620 ppb | total PCBs (26 congeners including 118, 138, 153, and 180) | General population exposure. Reduced birth weight. Reduced growth (weight, length, and head circumference) during first 3 months in formula-fed, but not breast-fed, children. Neurobehavioral alterations and changes in T-lymphocyte subpopulations and thyroid hormone levels in infants^i^.
Dutch Mother-Child Study; (Huisman et al. 1995a, 1995b; Koopman-Esseboom et al. 1994a, 1994b, 1996; Lanting et al. 1998c; Patandin et al. 1999; Weisglas-Kuperus et al. 1995) | maternal plasma:; 2.2 ppb; cord plasma:; 0.45 ppb; child plasma:; 0.75 ppb (median, breast-fed at 42 months); 0.21 ppb (median, formula-fed at 42 months) | 430 ppb | Σ 4 non-dioxin-like congeners (PCBs 118, 138, 153, and 180)
Dutch Mother-Child Study; (Huisman et al. 1995a, 1995b; Koopman-Esseboom et al. 1994a, 1994b, 1996; Lanting et al. 1998c; Patandin et al. 1999; Weisglas-Kuperus et al. 1995) | maternal plasma:; 2.2 ppb; cord plasma:; 0.45 ppb; child plasma:; 0.75 ppb (median, breast-fed at 42 months); 0.21 ppb (median, formula-fed at 42 months) | 25.6 ppb; 0.16 ppb TEQ | Σ 3 dioxin-like congeners (PCBs 77, 126, and 169)
Dutch Mother-Child Study; (Huisman et al. 1995a, 1995b; Koopman-Esseboom et al. 1994a, 1994b, 1996; Lanting et al. 1998c; Patandin et al. 1999; Weisglas-Kuperus et al. 1995) | maternal plasma:; 2.2 ppb; cord plasma:; 0.45 ppb; child plasma:; 0.75 ppb (median, breast-fed at 42 months); 0.21 ppb (median, formula-fed at 42 months) | 0.046 ppb TEQ | Σ 3 dioxin-like congeners and 17 PCDD and PCDF 2,3,7,8-substituted congeners
European Background PCB Study — German Sample; (Winneke et al. 1998b) | cord plasma: 0.55 ppb | 427 ppb | Σ 3 non-dioxin-like congeners (PCBs 138, 153, and 180) | General population exposure. Neurodevelopmental and thyroid hormone alterations in infants^i^.

a Newborn children from mothers who ate contaminated fish were more likely to exhibit hypoactive reflexes, more motor immaturity, poorer lability of states, and greater amount of startle. Testing at 4 years of age found that prenatal exposure was associated with poorer performance on the Verbal and the Memory scales of the McCarthy Scales of Children’s Abilities, as well as less efficient visual discrimination processing and more errors in short-term memory scanning. Evaluation of the children at 11 years of age showed that prenatal exposure was significantly associated with lower full-scale and verbal IQ scores and poorer reading word comprehension.

b Although the concentration of total PCBs did not differ between fisheaters and controls, both the proportion (mol %) and absolute concentration (ppb) of the most heavily chlorinated PCB congeners (C17-C19) were markedly elevated in the cord blood of the fisheaters compared to the controls. PCB congeners of light (C11-C13) or moderate (C14-C16) chlorination were unrelated to fish consumption. The most heavily chlorinated congeners in cord blood were also the only congeners that correlated with breast milk levels.

c Actual values of PCBs in milk were not reported. The C17-C19 congeners in breast milk and cord blood were correlated while no correlation was found for the lightly (C11-C13) or moderately (C14-C16) chlorinated congeners.

d Children born to mothers with high consumption of contaminated fish had a greater number of abnormal reflexes and less mature autonomic responses than newborns from low-fisheaters or nonfisheaters. Heavily chlorinated congeners (C17-C19) were associated with poorer Habituation and Autonomic scores.

e Exposure was assessed using an index developed to estimate cumulative lifetime PCB exposure through fish consumption.

f Associations between increasing levels of organochlorine compounds in breast milk and risk of acute otitis media during the first year of life were found, although the data are insufficient for identifying whether the effect may be due to PCBs, hexachlorobenzene, p,p’-DDE, or other chemicals. No statistically significant changes in immunological indices were observed, although there were indications of reduced total serum IgA levels and altered T-lymphocyte subpopulations in breast-fed Inuit infants at 7 and 12 months of age.

g Average PCB levels in milk at birth. In lactating women, the levels declined about 20% over 6 months and about 40% over 18 months.

h Higher PCB levels were associated with less muscle tone and activity and hyporeflexia. Prenatal exposure to PCBs (levels in milk at birth) was associated with a significant decrease in PDI scores at the ages of 6 and 12 months.

i Prenatal exposure to PCBs (cord blood) was not significantly associated with either PDI or MDI scores at 7 months of age. Postnatal exposure was significantly associated with lower PDI scores, but not MDI scores. Cognitive abilities evaluated in these children at 42 months of age using the KABC showed a significant decreased performance associated with prenatal exposure to PCBs. PCB and CDD TEQs in maternal plasma during pregnancy were compared with thyroid T_3,_ T_4_, and TSH concentrations in cord plasma at delivery and in the venous plasma of infants at ages 2 weeks and 3 months. Hormone levels were negatively correlated with CDD TEQs, PCB TEQs, and combined CDD and PCB TEQs, at all ages.

j Prenatal exposure was not significantly associated with MDI or PDI scores at 7 months of age. Postnatal exposure was significantly associated with lower MDI scores, but not with PDI scores. A positive correlation was found between serum concentrations of thyroid TSH and total PCBs in infants.

Table A-2 Summary of Epidemiological Information Concerning Human PCB Exposures: Retrospective Analysis of Cohort Mortality from Cancer or Cohort Cancer Incidence

End points | Comparison groups | Number exposed | Study period | Exposure period | Measure of effect | Outcome | Comments | Reference
Total cancer mortality | Capacitor workers exposed ≥3 months versus. U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 93 (no CI) | Latency <10 year | Brown and Jones 1981
Total cancer mortality | Capacitor workers exposed ≥3 months versus. U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 108 (no CI) | Latency 10<20 year | Brown and Jones 1981
Total cancer mortality | Capacitor workers exposed ≥3 months versus. U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 60 (no CI) | Latency >20 year | Brown and Jones 1981
Total cancer mortality | Capacitor workers exposed ≥3 months versus. U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 89 (95% CI= 63-122) | Overall SMR; further analysis revealed that risk was not related to employment duration. Analyses of mortality from cancers at various specific sites did not show statistically significantly increased risk^a^. | Brown and Jones 1981
Total cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1983 | 1940-1976 | SMR | 78 (no CI) | Overall SMR; update of Brown and Jones (1981) study; seven additional years’ follow-up. Analyses of mortality from cancers at various specific sites did not show statistically significantly increased risk^b^. | Brown 1987b
Total cancer mortality | Capacitor manufacturing plant workers in New York State exposed ≥90 days versus U.S. and regional (surrounding counties) populations | 7,075 | 1946-1993 | 1946-1977 | SMR | No statistically significantly elevated SMRs | Analyses for mortality from all cancers combined were stratified in the following ways: (1) hourly versus salaried compensation schedule, and gender of worker (analyses were also conducted for various cancer sites^c^); (2) gender, employment duration, and latency. Only “limited” exposure to other chemicals was reported. | Kimbrough et al. 1999a
Total cancer mortality | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 142 | 1965-1982 | 1965-1978 (mean exposure 6.5 years) | RR | 1.30 (95% CI= 0.52-2.67) | Median latency time =13 years | Gustavsson et al. 1986
Total cancer mortality | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 242 | 1965-1991 | 1965-1978 | SMR | No statistically significantly elevated SMRs | Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses for mortality by all cancers combined were conducted for the entire cohort or stratified by exposure status (low versus high exposure). SMR=133 (95% CI=76-216) for the entire cohort. Analyses of mortality from cancers at various sites did not show statistically significantly increased risk^d^. | Gustavsson and Hogstedt 1997
Total cancer mortality | Italian capacitor manufacturing workers employed ≥1 week versus national mortality rates | 2,110 (544 males and 1,556 females) | 1946-1982 | 1946-1978 | SMR | Males: 253 (95% CI= 144-415); Females: 156 (no CI; not statistically significant) | In a follow-up study that considered nine additional years of latency (Tironi et al. 1996), mortality from all cancers was not statistically significantly increased in males (SMR=109; CI=67-168) or females (SMR=118; CI=71-184). | Bertazzi et al. 1987
Total cancer mortality | Italian capacitor manufacturing workers employed ≥1 week versus local mortality rates | 2,110 (544 males and 1,556 females) | 1946-1982 | 1946-1978 | SMR | Males: 183 (95% CI= 104-300); Females: 226 (95% CI= 123-385) | NC | Bertazzi et al. 1987
Total cancer mortality | Japanese Yusho food PCB contamination registrants versus national death rates | 887 males | 1968-1983 | 1968 (poisoning incident) | SMR | 2.13 (no CI; p<0.01) | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. SMR was not statistically significant in an evaluation of 874 females. Average follow-up was approximately 11 years. Analyses of mortality from cancers at various sites did not show statistically significantly increased risk^e^. | Kuratsune et al. 1987
Total cancer mortality | Taiwanese Yu-Cheng food PCB contamination victims versus national mortality rates | 1,940 (929 males, 1,011 females) | 1979-1991 | 1979 (poisoning incident) | SMR | Males: SMR=0.69 (95% CI= 0.3-1.36); Females: SMR=0.4 (95% CI= 0.08-1.18); Total: SMR=0.58 (95% CI= 0.29-1.04) | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. Similarly statistically non-significant findings were obtained in comparisons against local reference populations. Analyses of mortality from cancers at various specific sites did not show statistically significantly increased risk^f^. | Hsieh et al. 1996
Total cancer mortality | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 men and 858 women) | 1957-1986 | 1957-1977 | SMR | 0.8 (95% CI= 0.6-1.1) | Analyses of mortality from cancers at various specific sites did not show statistically significantly increased risk^g^. | Sinks et al. 1992
Total cancer mortality | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SMR | 0.84 (95% CI= 0.68-1.03) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. Analyses of mortality from cancers at various specific sites also did not show statistically significantly increased risk^h^. | Svensson et al. 1995a
Total cancer mortality | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SMR | 3.05 (95% CI= 0.99-7.13) | Statistically significant SMR was for squamous cell carcinomas; a statistically non-significant SMR was obtained for melanomas. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Total cancer mortality | U.S. male utility workers employed full time for ≥6 months versus U.S. general population mortality rates (adjusted for age, calendar year, and race) | 138,905 | 1950-1988 | 1950-1986 | SMR | 0.86 (95% CI= 0.84-0.89) | Analyses of mortality from cancers at various specific sites also did not show statistically significant increased risk^i^. Possible confounding factors include co-exposures to solvents, wood preservatives, sunlight, and magnetic fields (which was associated with mortality from brain cancer in this cohort). | Loomis et al. 1997
Total cancer mortality | Canadian transformer manufacturing plant male workers employed for a 1 month versus Canadian general male population 4 | 2,222 | 1947-1989 | 1947-1975 | SMR | 1.21 (95% CI= 0.90-1.60) | Analysis combined deaths from “definite”, “probable”, and “possible” cancer link. Analysis of “definite” cancer mortality cases yielded an SMR of 0.81 (95% CI=0.57-1.13). Statistically non-significant SMRs were also obtained in all workers employed ≥6 months (n=812) and in transformer assembly workers employed for 2;6 months (n=308). The authors noted that “considerably more exposure” to mineral oils occurred than exposure to PCB-containing askarol transformer fluids. | Yassi et al. 1994
Total cancer incidence | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 142 | 1965-1982 | 1965-1978 (mean exposure 6.5 years) | RR | 0.92 (95% CI= 0.37-1.90) | Median latency time =13 years | Gustavsson et al. 1986
Total cancer incidence | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SIR | 1.02 (95% CI= 0.88-1.17) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. Analyses of cancer incidence at various specific sites also did not show statistically significant increased risk^j^. | Svensson et al. 1995a
Total cancer incidence | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SIR | 0.95 (95% CI= 0.89-1.01) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Total cancer incidence | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 242 | 1965-1991 | 1965-1978 | SIR | No statistically significantly elevated SIRs | Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses for all cancers were conducted for the entire cohort, for the subgroup with time since first exposure >10 years, and for the high exposure group. Analysis of cancer incidence at various specific sites also did not show statistically significant increases^k^. | Gustavsson and Hogstedt 1997
Liver-related cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 667 (no CI) | Latency <10 years | Brown and Jones 1981
Liver-related cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 233 (no CI) | Latency 10-20 years | Brown and Jones 1981
Liver-related cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | no deaths | Latency >20 years | Brown and Jones 1981
Liver-related cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 280 (95% CI= 58-820) | Overall value; further analysis revealed that risk not related to employment duration | Brown and Jones 1981
Liver-related cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1983 | 1940-1976 | SMR | 263 (no CI, p<0.05) | Overall value; update of Brown and Jones (1981) study; seven additional years’ follow-up; no increase in risk with increasing duration of latency or employment. Five cases observed versus 1.9 expected. One liver cancer was metastatic, not primary; when exclude that case, SMR=210 (p≥0.05) (Nicholson and Landrigan 1994). | Brown 1987b
Liver-related cancer mortality | Capacitor manufacturing plant workers in New York State exposed ≥90 days versus U.S. and regional (surrounding counties) populations | 7,075 | 1946-1993 | 1946-1977 | SMR | No statistically significantly increased SMRs | Analysis stratified by gender and hourly versus salaried compensation. Male hourly (80; CI=10-289; two deaths); female hourly (89; CI=11-321; two deaths); male salaried (79; CI=2-439; one death); female salaried (no deaths). | Kimbrough et al. 1999a
Liver-related cancer mortality | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 242 | 1965-1991 | 1965-1978 | SMR | No statistically significantly elevated SMRs | Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses for mortality by liver cancer were conducted for the entire cohort or stratified by exposure status (low versus high exposure). Only one death due to liver cancer was reported, in the high exposure group. SMRs were 667 (CI=16-3,710) and 196 (01=5—1,090) for the high exposure group and entire cohort, respectively. | Gustavsson and Hogstedt 1997
Liver-related cancer mortality | Japanese Yusho food PCB contamination registrants versus national and local death rates | 887 males | 1968-1983 | 1968 (poisoning incident) | SMR | 5.59 (no CI; p<0.01) | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. Average follow-up was approximately 11 years. An SMR of 3.85 for males was also statistically significantly elevated (p<0.01; no CI); compared to a local reference population that had an underlying high incidence of liver cancer mortality. Evaluating only those liver cancers in males that were observed after 9 years of latency compared to the local reference population resulted in an SMR of 3.85 (p<0.05); no CI;. SMRs were not statistically significant in evaluations of 874 females. | Kuratsune et al. 1987
Liver-related cancer mortality | Taiwanese Yu-Cheng food PCB contamination victims versus national mortality rates | 1,940 (929 males, 1,011 females) | 1979-1991 | 1979 (poisoning incident) | SMR | Males: 0.29 (95% CI= 0.01-1.62);; Females: 1.08 (95% CI= 0.03-6.02) | Heated PCB-contaminated rice oil aiso contained PCDFs and other contaminants. One male death and one female death observed. The analysis considered deaths from liver and intrahepatic bile duct cancers combined. Similarly statistically non-significant findings were reported in males and females using a local reference population. | Hsieh et al. 1996
Liver-related cancer mortality | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 males, 858 females) | 1957-1986 | 1957-1977 | SMR | 1.1 (95% CI= 0.0-6.4) | NC | Sinks et al. 1992
Liver-related cancer mortality | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SMR | 0.48 (95% CI= 0.01-2.65) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Liver-related cancer mortality | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SMR | 0.9 (95% CI= 0.41-1.7) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Liver-related cancer incidence | U.S. male utility workers employed full time for ≥6 months versus U.S. general population mortality rates (adjusted for age, calendar year, and race). | 138,905 | 1950-1988 | 1950-1986 | SMR | 0.73 (95% CI= 0.57-0.93) | The analysis included combined mortalities from cancers of the liver, biliary passages, and gall bladder. An additional analysis of liver (not specified) cancer mortality yielded an SMR of 0.79 (95% CI=0.55-1.1) | Loomis et al. 1997
Liver-related cancer incidence | Swedish capacitor manufacturing male.workers employed ≥6 months versus Swedish national rates % | 242 | 1965-1991 | 1965-1978 | SIR | No statistically significantly elevated SIRs | Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses for incidence of liver and bile duct cancer were conducted for the entire cohort or stratified by exposure status (low versus high exposure) or time since first exposure (>10 or >20 years). SIR=256 (95% 01=31-926) for the entire cohort. One each of cholangiocellular cancer and adenocarcinoma were reported. | Gustavsson and Hogstedt 1997
Rectal cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | No deaths | Latency <10 years | Brown and Jones 1981
Rectal cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 417 (no CI) | Latency 10-20 years | Brown and Jones 1981
Rectal cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 556 (no CI) | Latency >20 years | Brown and Jones 1981
Rectal cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 335 (95% CI= 92-860) | Overall value; an analysis stratified by employment location and sex of worker revealed that observed mortality (3) statistically significantly greater (p<0.05) than expected (0.5) for females in one of two locations (Plant 2) resulting in an SMR of 600 (no CI; 3 observed deaths, 0.5 expected). An SMR of 323 (no CI; 1 observed death, 0.31 expected) was reported in males from plant 1. No deaths from rectum cancer were observed in females in plant 1 or males in plant 2. Analysis by employment duration revealed statistically significantly increased SMR only in the group exposed for 10-14 years (not for longer or shorter durations) in one or both locations, although the number of deaths was small. | Brown and Jones 1981
Rectal cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1983 | 1940-1976 | SMR | 211 (no CI; p>0.05) | Overall value; update of Brown and Jones (1981) study; seven additional years’ follow-up. Four observed deaths versus 1.9 expected. For females in plant 2 (previously statistically significant in Brown and Jones, 1981) the observed/expected mortality ratio was 3/0.8 (p≥0.05). | Brown 1987b
Rectal cancer mortality | Capacitor manufacturing plant workers in New York State exposed ≥90 days vs. U.S. and regional (surrounding counties) populations | 7,075 | 1946-1993 | 1946-1977 | SMR | No statistically significantly increased SMRs | Analysis stratified by gender and hourly vs. salaried compensation. A statistically non-significant SMR of 169 (95% CI=46-434; 4 observed deaths, 2.3 expected) was reported in female hourly workers. | Kimbrough et al. 1999a
Rectal cancer mortality | Japanese Yusho food PCB contamination registrants versus national death rates | 1,761 (887 males, 874 females) | 1968-1983 | 1968 (poisoning incident) | SMR | Males: 1.60 (no CI; p>0.05); Females: no deaths | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. The analysis combined cancers of the rectum, sigmoid colon, and anus. One observed death. Average follow-up was approximately 11 years. | Kuratsune et al. 1987
Rectal cancer mortality | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 male, 858 female) | 1957-1986 | 1957-1977 | SMR | 0.8 (95% CI= 0.0-4.5) | NC | Sinks et al. 1992
Rectal cancer mortality | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SMR | 0.73 (95% CI= 0.2-1.86) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Rectal cancer mortality | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SMR | 1.02 (95% CI= 0.7-1.46) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Rectal cancer mortality | U.S. male utility workers employed full time for ≥6 months versus U.S. general population mortality rates (adjusted for age, calendar year, and race). | 138,905 | 1950-1988 | 1950-1986 | SMR | 0.79 (95% CI= 0.65-0.95) | NIC | Loomis et al. 1997
Respiratory-related cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 88 (95% CI= 35-181) | Overall SMR value | Brown and Jones 1981
Respiratory-related cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1983 | 1940-1976 | SMR | 59 (no CI) | Overall SMR value; update of Brown and Jones (1981) study; seven additional years’ follow-up | Brown 1987b
Respiratory-related cancer mortality | Japanese Yusho food PCB contamination registrants versus national death rates | 887 males | 1968-1983 | 1968 (poisoning incident) | SMR | 3.26 (no CI; p<0.01) | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. The analysis combined cancers of the lung, trachea, and bronchus. SMR was not statistically significant in an evaluation of 874 females. Average follow-up was approximately 11 years. | Kuratsune et al. 1987
Respiratory-related cancer mortality | Taiwanese Yu-Cheng food PCB contamination victims versus Taiwan national mortality rates | 1,940 (929 males, 1,011 females) | 1979-1991 | 1979 (poisoning incident) | SMR | Males: 0.85 (95% CI= 0.10-3.07);; Females: 0.88 (95%CI= 0.02-4.91) | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. The analysis considered deaths from trachea, bronchus, and lung cancers combined. One death in males and one death in females observed. Similarly statistically non-significant findings were reported in males and females using a local reference population. | Hsieh et al. 1996
Respiratory-related cancer mortality | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 males, 858 women) | 1957-1986 | 1957-1977 | SMR | 0.7 (95% CI= 0.4-1.2) | NC | Sinks et al. 1992
Respiratory-related cancer mortality | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SMR | 0.78 (95% CI= 0.46-1.28) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Respiratory-related cancer mortality | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SMR | 0.86 (95% CI= 0.68-1.07) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Respiratory-related cancer mortality | U.S. male utility workers employed full time for ≥6 months versus U.S. general population mortality rates (adjusted for age, calendar year, and race). | 138,905 | 1950-1988 | 1950-1986 | SMR | 0.91 (95% CI= 0.87-0.95) | The analysis included combined mortalities from cancers of the trachea, bronchus, and lung. | Loomis et al. 1997
Respiratory-related cancer mortality | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 242 | 1965-1991 | 1965-1978 | SMR | No statistically significantly elevated SMRs | The analysis focused on mortality from lung cancer. Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses were conducted for the entire cohort or stratified by exposure status (low versus high exposure). SMRs were 152 (CI=31-444), 222 (27-803), and 173 (CI=56-406) for the low and high exposure groups and entire cohort, respectively. A total of five lung cancer mortalities were observed. | Gustavsson and Hogstedt 1997
Respiratory-related cancer mortality | Canadian transformer manufacturing plant male workers employed for ≥6 months versus Canadian general male population | 819 | 1947-1989 | 1947-1975 | SMR | 0.79 (95% CI= 0.26-1.85) | A statistically non-significant SMR was also obtained in transformer assembly workers employed for ≥6 months (n=308). The authors noted that “considerably more exposure” to mineral oils occurred than exposure to PCB-containing askarol transformer fluids. | Yassi et al. 1994
Pancreatic cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 53 (no CI) | One death observed; overall SMR value. | Brown and Jones 1981
Pancreatic cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white popujation | 2,567 | 1940-1983 | 1940-1976 | SMR | 54 (no CI) | Overall SMR value; update of Brown and Jones (1981) study; seven additional years’ follow-up. | Brown 1987b
Pancreatic cancer mortality | Canadian transformer manufacturing plant male workers employed for ≥6 months versus Canadian general male population 4 | 2,222 | 1947-1989 | 1947-1975 | SMR | 5.01 (95% CI= 2.50-8.96; 11 observed deaths) | Analysis was for all workers in the transformer plant, with “definite”, “probable”, or “possible” link between death and pancreatic cancer. The “definite” pancreatic cancer mortality cases yielded an SMR of 2.92 (95% CI=1.17-6.01). Among all workers employed for ≥6 months (n=812) an SMR of 7.64 (3.29-15.06) was obtained, and among workers employed for ≥6 months in the transformer assembly department (n=308), an SMR of 12.9 (2.59-37.7) was calculated. The authors noted that “considerably more exposure” to mineral oils occurred than exposure to PCB-containing askarol transformer fluids. Wong (1995) identified other concerns about the positive pancreatic findings, including inclusion of cases that had neither sufficient duration of exposure nor sufficient latency to be related to PCB exposure at the plant. | Yassi et al. 1994
Pancreatic cancer mortality | Capacitor manufacturing plant workers in New York State exposed ≥90 days versus U.S. and regional (surrounding counties) populations | 7,075 | 1946-1993 | 1946-1977 | SMR | No statistically significantly increased SMRs | Analysis stratified by gender and hourly versus salaried compensation. | Kimbrough et al. 1999a
Pancreatic cancer mortality | Japanese Yusho food PCB contamination registrants versus national death rates | 1,761 (887 males, 874 females) | 1968-1983 | 1968 (poisoning incident) | SMR | Males: 1.41 (no CI; p>0.05); Females: 2.18 (no CI; p>0.05) | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. Average follow-up was approximately 11 years. One death in males and one death in females observed | Kuratsune et al. 1987
Pancreatic cancer mortality | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 males, 858 females) | 1957-1986 | 1957-1977 | SMR | 0.7 (95% CI= 0.1-2.5) | NC | Sinks et al. 1992
Pancreatic cancer mortality | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SMR | 0.66 (95% CI= 0.22-1.55) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Stomach cancer mortality | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations * | 8,477 | 1968-1988 | 1968-1988 | SMR | 0.84 (95% CI= 0.58-1.18) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Pancreatic cancer mortality | U.S. male utility workers employed full time for ≥6 months versus U.S. general population mortality rates (adjusted for age, calendar year, and race). | 138,905 | 1950-1988 | 1950-1986 | SMR | 0.84 (95% CI= 0.74-0.95) | NC | Loomis et al. 1997
Stomach cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 60 (no CI) | Overall SMR value; one death observed. One observed death, 1.66 expected). | Brown and Jones 1981
Stomach cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1983 | 1940-1976 | SMR | 36 (no CI) | Overall SMR value; one death observed, update of Brown and Jones (1981) study; seven additional years’ follow-up. One observed death, 2.8 expected). | Brown 1987b
Stomach cancer mortality | Capacitor manufacturing plant workers in New York State exposed ≥90 days versus U.S. and regional (surrounding counties) populations | 7,075 | 1946-1993 | 1946-1977 | SMR | No statistically significantly increased SMRs | Analysis stratified by gender and hourly versus salaried compensation. | Kimbrough et al. 1999a
Stomach cancer mortality | Japanese Yusho food PCB contamination registrants versus national death rates | 1,761 (887 males, 874 females) | 1968-1983 | 1968 (poisoning incident) | SMR | Males: 1.40 (no CI; p>0.05); Females: no deaths | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. Average follow-up was approximately 11 years. | Kuratsune et al. 1987
Stomach cancer mortality | Taiwanese Yu-Cheng food PCB contamination victims versus Taiwan national and local reference mortality rates | 1,940 (929 males, 1,011 females) | 1979-1991 | 1979 (poisoning incident) | SMR | National reference: 0.63 (95% CI= 0.02-3.53) Local reference: 0.65 (95% CI= 0.02-3.59 | Heated PCB-contaminated rice oil also contained PCDFs and other contaminants. The analysis focused on deaths from cancer of the stomach in males. One observed death. No parallel analysis was reported in females. | Hsieh et al. 1996
Stomach cancer incidence | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations V | 2,896 | 1968-1988 | 1968-1988 | SMR | 1.37 (95% CI= 0.82-2.23) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Intestinal cancer mortality | Taiwanese Yu-Cheng food PCB contamination victims versus Taiwan national and local reference mortality rates | 1,940 (929 males, 1,011 females) | 1979-1991 | 1979 (poisoning incident) | SMR | National: 19.76 (95% CI= 0.5-110.3) Local: 26.46 (95% CI= 0.67-147.4) | Heated PCB-contaminated rice oil also contained PCDFs and other contaminated. The analysis focused on deaths from cancer of the small intestine in males; one observed death. No parallel analysis was reported in females. | Hsieh et al. 1996
Intestinal cancer mortality | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 99 (95% CI= 27-254) | Overall SMR value. | Brown and Jones 1981
Intestinal cancer mortality | Capacitor workers exposed a 3 months versus U.S. white population | 2,567 | 1940-1983 | 1940-1976 | SMR | 104 (no CI) | Overall SMR value; update of Brown and Jones (1981) study; seven additional years’ follow-up. | Brown 1987b
Intestinal cancer mortality | U.S. male utility workers employed full time for months versus U.S. general population mortality rates (adjusted for age, calendar year, and race). | 138,905 | 1950-1988 | 1950-1986 | SMR | 0.93 (95% CI= 0.85-1.02) | NC | Loomis et al. 1997
“Digestive tract” cancer mortality | Italian capacitor manufacturing male workers employed ≥1 week versus national mortality rates | 544 males | 1946-1982 | 1946-1978 | SMR | 346 (95% CI= 141-721) | For this analysis, cancers of the stomach (2), pancreas (2), liver (1), and biliary tract (1) were included by the authors in the “digestive tract" group. A SMR of 274 (95% CI=112-572) was also obtained in males in a comparison against a local reference group. No statistically significant digestive tract SMR was obtained for female workers compared to either national or local reference groups, or in a follow-up evaluation with an additional 9 years of latency (Tironi et al. 1996). | Bertazzi et al. 1987
“Digestive organs" cancer mortality | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 males, 858 females) | 1957-1986 | 1957-1977 | SMR | 0.6 (95% CI= 0.2-1.1) | NC | Sinks et al. 1992
“Digestive cancer” mortality | Canadian transformer manufacturing plant male workers employed for ≥1 month versus Canadian general male population | 2,222 | 1947-1989 | 1947-1975 | SMR | 1.45 (95% CI= 0.85-2.33) | Analysis combined deaths from “definite”, “probable", and “possible” cancer link. Analysis of “definite” digestive cancer mortality cases yielded an SMR of 0.85 (95% CI=0.43-1.53; 11 observed deaths). Statistically non-significant SMRs were also obtained in all workers employed ≥6 months (n=812) and in transformer assembly workers employed for ≥6 months (n=308). The authors noted that “considerably more exposure” to mineral oils occurred than exposure to PCB-containing askarol transformer fluids. | Yassi et al. 1994
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Italian capacitor manufacturing female workers employed a 1 week versus local mortality rates | 1,556 females | 1946-1982 | 1946-1978 | SMR | 377 (95% CI= 115-877) | A SMR of 266 (not statistically significant; CI not reported; 4 observed, 1.5 expected) was also obtained in females in a comparison against a national reference group. No statistically significantly elevated hematological cancer SMR was obtained for male workers compared to either local (SMR=263; no CI; 3 observed, 1.1 expected) or national (SMR=375; no CI; 3 observed, 0.8 expected) reference groups. | Bertazzi et al. 1987
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Japanese Yusho food PCB contamination registrants versus national death rates | 1,761 (887 males, 874 females). | 1968-1983 | 1968 (poisoning incident) | SMR | Males: 2.23 (no CI; p>0.05); Females: no deaths | Heated PCB-contaminated rice oil also contained PCDFS and other contaminants; one observed death in males. The analysis focused on leukemia. Average follow-up was approximately 11 years. | Kuratsune et al. 1987
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Taiwanese Yu-Cheng food PCB contamination victims versus Taiwan national and local mortality rates | 1,940 (929 males, 1,011 females) | 1979-1991 | 1979 (poisoning incident) | SMR | National: 61.17 (95% CI= 1.55-340.7) Local: 86.45 (95% CI= 2.19-481.5) | Heated PCB-contaminated rice oil also contained PCDFS and other contaminants. The analysis focused on Hodgkin’s disease in males; no comparable analysis in females was reported. One observed death in males. | Hsieh et al. 1996
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Taiwanese Yu-Cheng food PCB contamination victims versus Taiwan national and local mortality rates | 1,940 (929 males, 1,011 females) | 1979-1991 | 1979 (poisoning incident) | SMR | National: 7.69 (95% CI= 0.19-42.84) Local: 8.42 (95% CI= 0.21-46.89) | Heated PCB-contaminated rice oil also contained PCDFS and other contaminants. The analysis focused on unspecified leukemia disease in males; comparable analysis in females was not reported. One observed death in males. | Hsieh et al. 1996
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Capacitor workers exposed ≥3 months versus U.S. white population | 2,567 | 1940-1976 | 1940-1976 | SMR | 46 (no CI) | Lymphatic and hematopoietic cancer mortality; only two deaths; overall SMR value | Brown and Jones 1981
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Capacitor workers exposed months versus U.S. white population | 2,567 | 1940-1983 | 1940-1976 | SMR | 68 (no CI) | Lymphatic and hematopoietic cancer mortality; overall SMR value; update of Brown and Jones (1981) study; seven additional years’ follow-up | Brown 1987b
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SMR | 3.08 (95% CI= 1.24-6.35) | The statistically significant SMR was for multiple myeloma. Statistically non-significant SMRs were obtained for Hodgkins and non-Hodgkins lymphoma and for leukemia. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SMR | No statistically significantly increased SMRs | Statistically non-significant SMRs were obtained for Hodgkins and non-Hodgkins lymphomas, multiple myeloma, and leukemia. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | U.S. male utility workers employed full time for ≥6 months versus U.S. general population mortality rates (adjusted for age, calendar year, and race). | 138,905 | 1950-1988 | 1950-1986 | SMR | No statistically significant SMRs | Statistically non-significant SMRs were obtained for mortalities from the following hematologic-related cancers: combined neoplasms of the lymphatic and hematopoietic tissues, lymphosarcoma and reticulosarcoma, Hodgkins disease, leukemia and aleukemia, other lymphatic neoplasms. | Loomis et al. 1997
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 242 | 1965-1991 | 1965-1978 | SMR | No statistically significant SMRs | Statistically non-significant SMRs were obtained for mortalities from the following hematologic-related cancers: combined hematopoietic and lymphatic malignancies, and malignant lymphomas. Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses were conducted for the entire cohort or stratified by exposure status (low vs. high exposure). | Gustavsson and Hogstedt 1997
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Canadian transformer manufacturing plant male workers employed for ≥6 months versus Canadian general male population | 819 | 1947-1989 | 1947-1975 | SMR | No statistically significant SMRs | Statistically non-significant SMRs were obtained in separate analyses for non-Hodgkins lymphomas and leukemias in all workers employed for ^6 months (n=812) and in transformer assembly workers employed for i6 months (n=308). The authors noted that “considerably more exposure” to mineral oils occurred than exposure to PCB-containing askarol transformer fluids. | Yassi et al. 1994
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 142 | 1965-1982 | 1965-1978 (mean exposure 6.5 yrs) | Observed versus expected | 1 observed case | The report identified one case of malignant lymphoma, expected number of cases was not reported, but the numbers of deaths from cancers was reported to “correspond well with those expected." Median latency time=13 years. | Gustavsson et al. 1986
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Capacitor manufacturing plant workers in New York State exposed ≥90 days versus U.S. and regional (surrounding counties) populations | 7,075 | 1946-1993 | 1946-1977 | SMR | No statistically significantly increased SMRs | Analysis stratified by gender and hourly versus salaried compensation. Three separate analyses were conducted for lymphosarcoma, leukemia and aleukemia, and other lymphatic and hematopoietic cancers. | Kimbrough et al. 1999a
Hematologic cancer mortality (including lymphatic and hematopoietic cancers) | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 males, 858 females) | 1957-1986 | 1957-1977 | SMR | 1.0 (95% CI= 0.4-2.0) | NC | Sinks et al. 1992
Hematologic cancer incidence | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SIR | No statistically significant SIRs | Statistically non-significant SIRs were obtained for Hodgkins and non-Hodgkins lymphoma, multiple myeloma, lymphatic leukemia, myeloic leukemia, and acute leukemia. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Hematologic cancer incidence | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations * | 8,477 | 1968-1988 | 1968-1988 | SIR | 1.86 (95% CI= 0.96-3.25 | The nearly statistically significant SIR was for acute leukemia. Statistically non-significant SIRs were obtained for Hodgkins and non-Hodgkins lymphoma, multiple myeloma, lymphatic leukemia, and myeloic leukemia. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Hematologic cancer incidence | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 242 | 1965-1991 | 1965-1978 | SIR | No statistically significantly elevated SIRs | Statistically non-significant SIRs were obtained for occurrence of the following hematologic-related cancers: combined hematopoietic and lymphatic malignancies, and non-Hodgkins lymphoma. Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses for all cancers were conducted for the entire cohort, for the subgroup with time since first exposure >10 yrs, and for the high exposure group. | Gustavsson and Hogstedt 1997
Skin cancer mortality | Capacitor manufacturing facility workers versus U.S. mortality rates for whites | 3,588 (2,785 males, 858 females) | 1957-1986 | 1957-1977 | SMR | 4.1 (95% CI= 1.8-8.0 | All observed skin cancer deaths (8) were from malignant melanoma, while the expected number of deaths was calculated using mortality rates for basal cell carcinoma, squamous cell carcinoma, and malignant melanoma combined. However, a nested proportional hazards analysis comparing indices of PCB exposure between skin cancer cases and a comparison group showed no relationship between risk of melanoma and cumulative PCB exposure. | Sinks et al. 1992
Skin cancer mortality | Capacitor manufacturing plant workers in New York State exposed ^90 days versus U.S. and regional (surrounding counties) populations % | 7,075 | 1946-1993 | 1946-1977 | SMR | No statistically significantly elevated SMRs | The analysis focused on mortality from melanomas. Analyses were stratified by hourly versus’salaried compensation schedule, and gender of worker. Only “limited” exposure to other chemicals was reported. There were statistically non-significant increases in melanoma mortality in hourly male workers (SMR=130; 95% CI=42-303; 5 observed deaths, 3.8 expected), hourly female workers (SMR=144; 95% CI=30-421; 3 observed deaths, 2 expected), and salaried male workers (SMR=210; 95% CI=57-538; 4 observed deaths, 1.9 exp). | Kimbrough et al. 1999a
Skin cancer mortality | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SMR | 3.05 (95% CI= 0.99-7.13) | Statistically significant SMR was for squamous cell carcinomas (five cases observed versus 1.6 expected); a statistically non-significant SMR was obtained for melanomas. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Skin cancer mortality | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SMR | No deaths observed | Analysis focused on squamous cell skin cancer and melanoma. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Skin cancer mortality | U.S. male utility workers employed full time for ≥6 months versus U.S. general population mortality rates (adjusted for age, calendar year, and race) | 138,905 | 1950-1988 | 1950-1986 | SMR | 1.04 (95% CI= 0.86-1.24) | The overall analysis showed no increases in skin cancers. However, an analysis stratified by latency (“lag”) and total career exposure showed a positive relationship between adjusted mortality rate ratios (RRs) and cumulative exposure within the group with a lag time of 20 years: 0-2,000 hrs total exposure (RR=1.29 [95% 01=0.76-2.17]), 2,000-10,000 hours (RR=2.56 [95% 01=1.09-5.97]), >10,000 hours [RR=4.81 (95% 01=1.49-15.1]). | Loomis et al. 1997
Skin cancer Incidence | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SIR | 2.28 (95% CI= 1.45-3.5 | The statistically significant SIR was for squamous cell cancer of the skin. A statistically non-significant SIR was obtained for melanomas. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a
Skin cancer Incidence | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SIR | Non-statistically significant SIRs | Statistically non-significant SIRs were obtained for squamous cell cancers and melanomas. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Skin cancer Incidence | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus west coast fishermen | 2,896 (east) 8,477 (west) | 1965-1988 | 1968-1988 | IRR | 1.88 (95% CI= 1.15-3.09) | Exposure duration was not clearly identified. East coast fishermen had higher blood levels of PCBs than the west coast population, but they also had higher levels of dioxins and furans (Svensson et al. 1995b). | Svensson et al. 1995a
Skin cancer Incidence | Swedish capacitor manufacturing male workers employed ≥6 months versus Swedish national rates | 242 | 1965-1991 | 1965-1978 | SIR | No observed cases | The analysis focused on malignant melanomas. Update of Gustavsson et al. (1986) study; nine additional years of follow-up. Analyses were conducted for the entire cohort, the high exposure group, and the group with time since first exposure (TSFE) >10 years. | Gustavsson and Hogstedt 1997
Skin cancer Incidence | U.S. male petrochemical plant workers versus National Cancer Survey incidence rates | 31 | 9-year period until late 1950s | 9-year period until late 1950s | NR | 2 cases observed versus 0.4 expected (p=0.001) | The analysis focused on malignant melanoma. The report was an editorial letter to the journal, indicating that the men were “heavily” exposed to Aroclor 1254. A follow-up letter (Bahn et al. 1977) indicated that the men were R&D workers who were exposed to other chemicals, but another group of 20 R&D workers with less PCB exposure had no cases of malignant melanoma. A letter from Lawrence (1977) indicated that an epoxide scavenger additive to PCBs was found to have a “pronounced carcinogenic effect in a skin painting study in animals, and that the skin cancer may not be from the PCBs, per se. | Bahn et al. (1976)
Lip cancer incidence | Swedish west coast fishermen consuming fish with PCBs versus regional reference populations | 8,477 | 1968-1988 | 1968-1988 | SIR | 1.92 (95% CI= 1.29-2.8) | Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. Mercury and selenium were also higher in fishermen than in referents (Svensson et al. 1995b). | Svensson et al. 1995a
Lip cancer incidence | Swedish east coast (Baltic Sea) fishermen consuming fish with PCBs versus regional reference populations | 2,896 | 1968-1988 | 1968-1988 | SIR | 2.6 (95% CI= 1.05-5.36) | Analysis focused on squamous cell skin cancer and melanoma. Exposure duration was not clearly identified, although fishermen were reported to consume fish at twice the rate of the reference population. East coast fishermen had higher blood levels of PCBs than the reference populations, but they also had higher levels of dioxins and furans (Svensson et al. 1995b); mercury and selenium were also higher in fishermen than in referents. | Svensson et al. 1995a

a No statistically significant increase in SMR was obtained in the Brown and Jones (1981) overall analysis for the following cancer sites: stomach, intestine (except rectum), rectum, liver/biliary passages, pancreas, respiratory system, breast, lymphatic/hematopoietic systems, and other cancer.

b No statistically significant increase in SMR was obtained in the Brown (1987b) update analysis that was stratified by employment location and gender for the following cancer sites: stomach, intestine (except rectum), pancreas, respiratory, urinary, lymphatic/hematopoietic, breast, female genital organs, and other cancers.

c No statistically significant increase in SMR was obtained in the Kimbrough et al. (1999a) analysis that was stratified by gender of worker and hourly versus salaried compensation for the following cancer sites: tongue, buccal cavity, pharynx, esophagus, stomach, intestine, rectum, biliary passages and liver, pancreas, larynx, trachea-bronchus-lung, breast, cervix uteri, uterus, ovary-tube-broad ligament, prostate, kidney, bladder and urinary tract, skin, brain and nervous system, connective tissue, other unspecified cancer, lymphosarcoma, leukemia and aleukemia, other lymphatic and hematopoietic cancer.

d No statistically significant increase in SMR was obtained in the Gustavsson and Hogstedt (1997) analysis that was stratified by exposure status for the following cancer sites: esophageal, liver, lung, prostate, bladder, kidney, hematopoietic and lymphatic malignancies, and malignant lymphomas.

e No statistically significant increase in SMR was obtained in the Kuratsune et al. (1987) analysis that was stratified by gender for the following cancer sites: esophagus, stomach, rectum-sigmoid colon-anus, pancreas, breast, uterus, and leukemia.

f No statistically significant increase in SMR was obtained in the Hsieh et al. (1996) analysis using either national or local reference populations for the following cancer sites: males: nasopharynx, stomach, small intestine, liver and intrahepatic bile ducts, trachea-bronchus-lung, unspecified leukemia; females: liver and intrahepatic bile ducts, trachea-bronchus-lung, and bone.

g No statistically significant increase in SMR was obtained in the Sinks et al. (1992) analysis for the following cancer sites: buccal cavity-pharynx, digestive organs, liver-biliary passages-gallbladder, pancreas, rectum, respiratory system, kidney, lymphatic and hematopoietic tissue, and brain and nervous system.

h No statistically significant increase in SMR was obtained in the Svensson et al. (1995a) analyses stratified by east coast versus west coast fisherman for the following cancer sites: esophagus, stomach, colon, rectum, liver, pancreas, lung-larynx, breast, prostate, bladder, kidney, brain-nervous system, Hodgkins and non-Hodgkins lymphoma, and leukemia.

i No statistically significant increase in SMR was obtained in the Loomis et al. (1997) analyses for the following cancer sites: buccal cavity-pharynx, stomach, intestine, rectum, liver-biliary passages-gall bladder, liver (not specified), pancreas, trachea-bronchus-lung, breast, prostate, kidney, urinary organs, skin, brain and nervous system, lymphatic and hematopoietic systems, lymphosarcoma and reticulosarcoma, Hodgkins disease, leukemia and aleukemia, and other lymphatic neoplasms.

j No statistically significant increase in SIR was obtained in the Svensson et al. (1995a) analyses stratified by east coast versus west coast fishermen for the following sites: esophagus, colon, rectum, liver-bile ducts, pancreas, lung-larynx, prostate, renal parenchyma, urinary bladder, brain, soft tissue sarcoma, Hodgkins lymphoma, non-Hodgkins lymphoma, multiple myeloma, lymphatic leukemia, myeloic leukemia, and acute leukemia.

k No statistically significant increase in SIR was obtained in the Gustavsson and Hogstedt (1997) analysis conducted for the entire cohort, for the subgroup with time since first exposure >10 years, and for the high exposure group for the following cancer sites: esophageal, liver, larynx, lung, prostate, bladder, malignant melanoma, nervous system, soft tissue sarcoma, hematopoietic-lymphatic, non-Hodgkins lymphoma, and other sites.