# 9 REFERENCES

*Not cited in text

ACGIH. 2006. Ionizing radiation. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology a nd a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
AEC. 1955. Percutaneous absorption of plutonium solutions in rats. In: Biology Research Annual Report 1954. Washington, DC: U.S. Atomic Energy Commission, 56–63. HW 35917.
*AEC. 1970a. Cocarcinogenic studies in pulmonary carcinogenesis. In: Nettesheim P, ed. Morphology of experimental respiratory carcinogenesis. Symposium Series 21. Washington, DC: U.S. Atomic Energy Commission, 417–436.
AEC. 1970b. Problems of plutonium toxicology. Oak Ridge, TN: U.S. Atomic Energy Commission. Division of Biology and Medicine. LFTR41. UC48.
AEC. 1971. Plutonium in man: A twenty-five year review. Berkeley, CA: U.S. Atomic Energy Commission. UCRL20850.
*AEC. 1973a. Fallout program quarterly summary report. Health and Safety Laboratory. U.S. Atomic Energy Commission, Health and Safety Laboratory. HASL-274.
AEC. 1973b. Cocarcinogenesis of ^239^PuO_2_ with chrysotile asbestos or benzpyrene in the rat abdominal cavity. In: Sanders C, Cross FT, Dagle GE, , eds. Radionuclide carcinogenesis. Symposium series 29. Washington, DC: U.S. Atomic Energy Commission, 138–153.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry/EPA. 1990. Toxicological profile for radon. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Environmental Protection Agency. http://www.atsdr.cdc.gov/toxprofiles/tp145.pdf. July 23, 2007
Agency for Toxic Substances and Disease Registry. 1998. Appendix A: Historic releases of nonradioactive substances to water and air. In: Public Health Assessment. US DOE Mound Facility [a/k/a Mound Plant (USDOE)] Miamisburg, Montgromery County, Ohio. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/HAC/pha/pha.asp?docid=634&pg=3#appa. May 27, 2010. _______________________
Agency for Toxic Substances and Disease Registry. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofiles/tp149.pdf. August 30, 2007.
Agency for Toxic Substances and Disease Registry. 2005. Public health assessment for Rocky Flats Environmental Technology Site. U.S. Department of Energy. Golden, Colorada. EPA facility ID: CO7890010526. May 13, 2005. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/HAC/pha/RockyFlats(DOE)/RockyFlatsPHA051305a.pdf. May 27, 2010.
Agency for Toxic Substances and Disease Registry. 2007. Public health assessment for evaluation of off-site groundwater and surface water contamination at the Savannah River Site (USDOE). Savannah River Site. Aiken, South Carolina. EPA facility ID: SC1890008989. December 17, 2007. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/HAC/pha/SavannahRiverSite121707/SavannahRiverSiteFinalPHA121707.pdf. May 27, 2010.
Aghamohammadi SZ, Goodhead DT, Savage JR K. 1988. Induction of sister chromatid exchanges (SCE) in G_0_ lymphocytes by plutonium-238 α-particles. Int J Radiat Biol 53(6):909–915.
Ahier BA, Tracy BL. 1995. Radionuclides in the Great Lakes basin. Environ Health Perspect Suppl 103(9):89–101.
Aisen P, Listowsky I. 1980. Iron transport and storage proteins. Annu Rev Biochem 49:357–393.6996567
Akleyev AV, Kostyuchenko VA, Peremyslova LM, 2000. Radioecological impacts of the Techa River contamination. Health Phys 79(1):36–47.10855776
Albright D, Kramer K. 2004. Fissile material. Stockpiles still growing. Bull At Sci 60(6):14–16. http://www.isis-online.org/global_stocks/bulletin_albright_kramer.pdf. April 23, 2007.
Aliabadi M, Amidi J, Alirezazadeh N, 2005. Environmental study of fall-out ^239+240^Pu in soil samples in Iran. J Environ Radioact 79(3):309–314.15607517
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Alvarez A, Navarro N. 1996. Method for actinides and Sr90 determination in urine samples. Appl Radiat Isot 47(9/10):869–873.8976042
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Anderson DL, Cunningham WC, Capar SG, 2001. Nuclear methods for food analysis at the U.S. Food and Drug Administration. J Radioanal Nucl Chem 249(1):29–32.
Anderson EC, Holland LM, Prine JR, 1979. Tumorigenic hazard of particulate α activity in Syrian hamster lungs. Radiat Res 78(1):82–97.451147
Andrew FD, Bernstine RL, Mahlum DD, 1977. Distribution of ^239^Pu in the gravid baboon. Radiat Res 70(3):637–638.
AOAC. 1990. Radioactivity. In: Helrich K, eds. Official methods of analysis-AOAC. Vol 1. 15th ed. Arlington, VA: Association of Official Analytical Chemists, 349–355.
APHA. 1998a. Method 7110. Gross alpha and gross beta radioactivity (total, suspended, and dissolved). In: Clesceri LS, Greenberg AE, Eaton AD, eds. Standard methods for the examination of water and wastewater. 20th ed. Washington, DC: American Public Health Association. American Water Works Association. Water Environmental Federation, 7–15 to 7–20.
APHA. 1998b. Method 7120. B. Gamma-emitting radionuclides. In: Clesceri LS, Greenberg AE, Eaton AD, eds. Standard methods for the examination of water and wastewater. 20th ed. Washington, DC: American Public Health Association. American Water Works Association. Water Environmental Federation, 7–20 to 7–24.
Arimoto R, Webb JL, Conley M. 2005. Radioactive contamination of atmospheric dust over southeastern New Mexico. Atmos Environ 39(26):4745–4754.
Bair W, Ballou J, Park J, 1973. Plutonium in soft tissues with emphasis on the respiratory tract. In: Hodge H, Stannard JN, Hursh JB, eds. Uranium-plutonium. Transplutonic elements. New York, NY: Springer-Verlag, 503–568.
Bair WJ, Park JF, Clarke WJ. 1966. Long-term study of inhaled plutonium in dogs. Kirtland Air Force Base, NM: Air Force Weapons Laboratory, AFWL-TR-65–214.
Bair WJ, Willard DH, Herring JP, 1962b. Retention, translocation and excretion of inhaled Pu^239^O_2_. Health Phys 8:639–649.13969060
Bair WJ, Willard DH, Nelson IC, 1974. Comparative distribution and excretion of ^237^Pu and ^239^Pu nitrates in beagle dogs. Health Phys 27(4):392–396.4475045
Ballou JE, George LA, Thompson RC. 1962. The combined toxic effects of plutonium plus x-ray in rats. Health Phys 8:581–587.13966182
Ballou JE, Park JF, Morrow WG. 1972. On the metabolic equivalence of ingested, injected and inhaled ^239^Pu citrate. Health Phys 22(6):857–862.4656351
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnhart BJ, Cox SH. 1979. Mutagenicity and cytotoxicity of 4.4-MeV α particles emitted by plutonium-238. Radiat Res 80(3):542–548.515352
Baum EM, Knox HD, Miller TR. 2002. Nuclides and isotopes. Chart of the nuclides. 16th ed. KAPL, Inc. Lockheed Martin, 70–71.
Beechey CV, Green D, Humphreys ER, 1975. Cytogenetic effects of plutonium-239 in male mice. Nature 256(5518):577–578.1165773
Bell J, Bates TH. 1988. Distribution coefficients of radionuclides between soils and groundwaters and their dependence on various test parameters. Sci Total Environ 69:297–317.
Bennett BG. 1979. Environmental aspects of americium. New York: New York University.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bhattacharyya M, Larsen R, Oldham R, 1986. Effects of duration of fast and animal age on the gastrointestinal absorption of plutonium. Radiat Res 107(1):73–82.3737878
Bhattacharyya MH, Peterson DP, Lindenbaum A. 1978. Action of DTPA on hepatic plutonium. I. Quantitation of the DTPB-induced excretion of plutonium in the rat. Radiat Res 74(1):179–185.674564
Bice DE, Harris DL, Schnizlein CT, 1979. Methods to evaluate the effects of t oxic materials deposited in the lung on immunity in lung-associated lymph nodes. Drug Chem Toxicol 2(1–2):35–47.548254
Bilbao A, Prosser JS, Edwards AA, 1989. The induction of micronuclei in human lymphocytes by in vitro irradiation with alpha particles from plutonium-239. Int J Radiat Biol 56(3):287–292.2570814
Bolotov BM, Gaitinov AC, Polyakov AI, 2003. On the determination of 239Pu and 241Am content in human tissues. Radiat Meas 36:541–545.
Børretzen P, Standring WJ F, Oughton DH, 2005. Pu and U atom ratios and concentration factors in reservoir 11 and Asanov swamp, Mayak PA: an application of accelerator mass spectrometry. Environ Sci Technol 39:92–97.15667080
Brandom WF, McGavran L, Bistline RW, 1990. Sister chromatid exchanges and chromosome aberration frequencies in plutonium workers. Int J Radiat Biol 58(1):195–207.1973437
Brooks AL, Diel JH, McClennan RO. 1979. The influence of testicular microanatomy on the potential genetic dose from internally deposited ^239^Pu citrate in Chinese hamster, mouse, and man. Radiat Res 77(2):292–302.441246
Brooks AL, Guilmette RA, Hahn FF, 1992. Distribution and biological effects of inhaled ^239^Pu(NO_3_)_4_ in cynomolgus monkeys. Radiat Res 130(1):79–87.1561321
Brouns R. 1980. Analysis. In: Wock O, ed. Plutonium handbook: A guide to the technology. Vol. II. La Grange Park, Illinois: The American Nuclear Society, 709–720, 921–933.
Brown SC, Schonbeck MF, McClure D, 2004. Lung cancer and internal lung doses among plutonium workers at the Rocky Flats Plant: A case-control study. Am J Epidemiol 160(2):163–172.15234938
Bruenger FW, Lloyd RD, Miller SC. 1991a. The influence of age at time of exposure to ^226^Ra or ^239^Pu on distribution, retention, postinjection survival, and tumor induction in beagle dogs. Radiat Res 125:248–256.2000447
Buldakov LA, Kalmykova ZI, Nifatov AP, 1972. Metabolism and biological effects of inhaled ^241^Am and ^239^Pu in dogs. Health Phys 22:873–874.5084022
Bunzl K, Kracke W. 1983. ^239/240^Pu and ^238^Pu in human tissues from the Federal Republic of Germany. Health Phys 44(Suppl 1):441–449.6862920
Bunzl K, Kracke W. 1987. Simultaneous determination of plutonium and americium in biological and environmental samples. J Radioanal Nucl Chem 115(1):13–21.
Burger J, Gochfeld M. 2007. Metals and radionuclides in birds and eggs from Amchika and Kiska Islands in the Bering Sea/Pacific Ocean ecosystem. Environ Monit Assess 127(1–3):105–117.17206460
Carbaugh EH, La Bone TR. 2003. Two case studies of highly insoluble plutonium inhalation with implications for bioassay. Radiat Prot Dosimetry 105(1–4):133–138.14526943
Carlton WH, Murphy CE, Evans AG. 1996. Plutonium in the Savannah River Site environment. Health Phys 71(3):290–299.8698569
Carpenter LM, Higgins CD, Douglas AJ, 1998. Cancer mortality in relation to monitoring for radionuclide exposure in three UK nuclear industry workforces. Br J Cancer 78(9):1224–1232.9820185
Carritt J, Fryxell R, Kleinschmidt J, 1947. The distribution and excretion of plutonium administered intravenously to the rat. J Biol Chem 171:273–283.
Carroll J, Harms IH. 1999. Uncertainty analysis of partition coefficients in a radionuclide transport model. Water Res 33(11):2617–2626.
Carroll J, Boisson F, Teyssie J, 1999. Distribution coefficients (Kd's) for use in risk assessment models of the Kara Sea. Appl Radiat Isot 51(1): 121–129.10376324
Cataldo D, Wildung R, Garland T. 1987. Speciation of trace inorganic contaminants in plants and bioavailability to animals: An overview. J Environ Qual 16(4):289–295.
CDC. 2005. Report on the feasibility of a study of the health consequences to the American population from nuclear weapons tests conducted by the United States and other nations. Centers for Disease Control and Prevention. National Cancer Institute. http://www.cdc.gov/nceh/radiation/fallout/default.htm. May 27, 2010.
CEC/DOE. 1992. Guidebook for the treatment of accidental internal contamination of workers. Ashford, Kent, England: Commission of the European Communities. U.S. Department of Energy.
CEDR. 2007. About CEDR. Comprehensive Epidemiologic Data Resource. http://cedr.lbl.gov/aboutcedr.html. May 23, 2007.
ChemBioFinder 2009. Plutonium oxalate. CambridgeSoftCorporation. http://chembiofinderbeta.cambridgesoft.com/SimpleSearch.aspx. March 16, 2009.
ChemFinder. 2009. Plutonium and selected isotopes. ChemFinder.com database & internet searching. http://chem.sis.nlm.nih.gov/chemidplus/chemidlite.jsp. March 16, 2009.
ChemIDplus. 2009. Plutonium and selected isotopes. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine, http://chem.sis.nlm.nih.gov/chemidplus/chemidlite.jsp. March 16, 2009.
Chen DJ, Strniste GF, Tokita N. 1984. The genotoxicity of alpha particles in human embryonic skin fibroblasts. Radiat Res 100(2):321–327.6494443
Cizdziel JV, Hodge VF, Faller SH. 1998. Plutonium anomalies in attic dust and soils at locations surrounding the Nevada Test Site. Chemosphere 37(6):1157–1168.9722972
Clark DL, Hecker SS, Jarvinen GD, 2006. Plutonium and plutonium compounds. In: Kirk-Othmer encyclopedia of chemical toxicology, 667–712. John Wiley & Sons, Inc. http://www.mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/plutmors.a01/current/pdf. May 19, 2007.
Cleveland J, Rees T. 1982. Characterization of plutonium in groundwater near the Idaho chemical processing plant. Environ Sci Technol 16(7):437–439.22276763
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cooper EL, Zeller E, Ghods-Esphahani A, 1992. Radioactivity in food and total diet samples collected in selected settlements in the USSR. J Environ Radioact 17(2–3):147–157.
Corey JC, Pinder JE, Watts JR, 1982. Stack-released plutonium in the terrestrial environment of a chemical separations facility. Nucl Saf 23(3):310–319.
Cunningham WC, Stroube WB, Baratta EJ. 1989. Radionuclides in domestic and imported foods in the United States, 1983–1986. J Assoc Off Anal Chem 72(1):15–18.2715131
Dacheux N, Aupiais J. 1997. Determination of uranium, thorium, plutonium, americium, and curium ultratraces by photon electron rejecting α liquid scintillation. Anal Chem 69:2275–2282.21639361
Dagle GE, Bristline RW, Lebel JL, 1984. Plutonium-induced wounds in beagles. Health Phys 47(1):73–84.6469650
Dagle GE, Cannon WC, Stevens DL, 1983. Comparative disposition of inhaled ^238^Pu and ^239^Pu nitrates in beagles. Health Phys 44(3):275–277.6832980
Dagle GE, Park JF, Weller RE, 1986. Pathology associated with inhaled plutonium in beagles. In: Thompson R, McHaffey J, eds. Life-span radiation effects studies in animals: What can they tell us? Oak Ridge, TN: U.S. Department of Energy, 471–476. DE87000490.
Dagle GE, Weller RE, Filipy RE, 1996. The distribution and effects of inhaled ^239^Pu(NO_3_)_4_. Health Phys 71(2):198–205.8690603
Dai M, Buesseler KO, Pike SM. 2005. Plutonium in groundwater at the 100K-area of the U.S. DOE Hanford Site. J Contam Hydrol 76(3–4):167–189.15683879
Dai M, Kelley JM, Buesseler KO. 2002. Sources and migration of plutonium in groundwater at Savannah River Site. Environ Sci Technol 36(17):3690–3699.12322739
Davila DR, Guilmette R, Bice DE, 1992. Long-term consequences of ^239^PuO_2_ exposure in dogs: Persistent T lymphocyte dysfunction. Int J Radiat Biol 61(1):123–133.1345923
Diel JH, Mewhinney JA. 1983. Fragmentation of inhaled ^238^PuO_2_ particles in lung. Health Phys 44(2):135–143.
Diel JH, Guilmette RA, Muggenburg BA, 1992. Influence of dose rate on survival time for ^239^PuO_2_-induced radiation pneumonitis or pulmonary fibrosis in dogs. Radiat Res 129:53–60.1728058
DOE. 1976. Chromosome aberration frequency in blood lymphocytes of animals with ^239^Pu lung burdens. In: Radiation and the lymphatic system. Springfield, VA. U.S. Department of Energy. CONF-740930.
DOE. 1977a. Body-iron stores and plutonium metabolism. In: Drucker H, Wildung R, eds. Biological implications of metals in the environment. Proceedings 15th Hanford Life Sciences Symposium, Richland, WA. Springfield, VA: U.S. Department of Energy, Technical Information Center, 570–577.
DOE. 1978a. Effects of inhaled ^239^PuO_2_ on the primary immune response of beagle dogs. Part I: Biomedical sciences. 1977 Annual report. Washington, DC: U.S. Department of Energy, 3.119–3.120. PNL-2500.
*DOE. 1978b. Late effects of perinatally administered plutonium. In: Mahlum D, ed. Developmental toxicology of energy-related pollutants. Proceedings 17th Hanford Biology Symposium, Richland, WA. Springfield, VA: U.S. Department of Energy, Technical Information Center, 361–373.
DOE. 1978c. Cross-placental transfer of plutonium-239 in gravid baboons. Part 1. Biomedical sciences. 1977 Annual report. Washington, DC: U.S. Department of Energy, 3.87–3.88. PNL-2500.
DOE. 1978d. Distribution of ^239^Pu in neonatal beagles. In: Mahlum D, Sikov MR, Hackett PL, , eds. Developmental toxicology of energy-related pollutants. Proceedings 17th Hanford Biology Symposium, Richland, WA. Springfield, VA: U.S. Department of Energy, Technical Information Center, 344–360.
DOE. 1978e. Alcohol and radionuclide metabolism. Part I: Biomedical sciences. 1977 Annual report. Washington, DC: U.S. Department of Energy, PNL-2500.
*DOE. 1980a. Worldwide fallout. In: Hanson W, ed. Transuranic elements in the environment. Springfield, VA: U.S. Department of Energy, Technical Information Center, 53–82. DOE/TIC-22800.
DOE. 1980b. Geochemistry of transuranic elements at Bikini Atoll. In: Hanson W, ed. Transuranic elements in the environment. Springfield, VA: U.S. Department of Energy, Technical Information Center, 541–577. DOE/TIC-22800.
DOE. 1980c. The relationship of microbial processes to the fate and behavior of transuranic elements in soils, plants, and animals. In: Hanson W, ed. Transuranic elements in the environment. Springfield, VA: U.S. Department of Energy, Technical Information Center, 541–577. DOE/TIC-22800.
DOE. 1980d. Plutonium contents of field crops in the southeastern United States. In: Hanson W, ed. Transuranic elements in the environment. Transuranic elements in the environment. Springfield, VA: U.S. Department of Energy, Technical Information Center, 381–402. DOE/TIC-22800.
*DOE. 1980e. Pulmonary carcinogenesis with inhaled plutonium in rats and dogs. In: Sanders C, Cross FT, Dagle GE, , eds. Pulmonary toxicology of respirable particles. 19th Hanford Life Sciences Symposium, Richland, WA. Washington, DC: U.S. Department of Energy.
DOE. 1980f. The migration of plutonium from a freshwater ecosystem at Hanford. In: Hanson W, ed. Transuranic elements in the environment. Springfield, VA: U.S. Department of Energy, Technical Information Center. DOE/TIC-22800.
DOE. 1980g. Quantities of transuranic elements in the environment from operations relating to nuclear weapons. In: Hanson W, ed. Transuranic elements in the environments. Springfield, VA: U.S. Department of Energy, Technical Information Center, 86–91. DOE/TIC-22800.
DOE. 1980h. Short-term assays for risk evaluation of alpha irradiation. In: Sanders C, Cross FT, Dagle GE, , eds. Pulmonary toxicology of respirable particles. 19th Hanford Life Sciences Symposium, Richland, WA. Washington, DC: U.S. Department of Energy.
DOE. 1980i. Ecological relationships of plutonium in southwest ecosystems. In: Hanson W, ed. Transuranic elements in the environment. Springfield, VA: U.S. Department of Energy, Technical Information Center. DOE/TIC-22800.
DOE. 1985k. A comparison of lon-term retention of plutonium oxide in lung based on excretion data with observed lung burdens at autopsy. U.S. Department of Energy. PNL-SA-12759. DE85017901.
*DOE. 1986a. Cardiopulmonary function of dogs with plutonium-induced chronic lung injury. Washington, DC: U.S. Department of Energy. LMF-115.
DOE. 1986b. Determination of metabolic data appropriate for HLW dosimetry. II. Gastrointestinal absorption. Vol. II. Washington, DC: U.S. Department of Energy. NUREG/CR-3572.
DOE. 1986c. Biokinetics of ^239^Pu in immature dogs that inhaled ^239^PuO_2_. Annual report. Washington, DC: U.S. Department of Energy. LMF-115.
DOE. 1986d. Toxicity of inhaled polydisperse of monodisperse aerosols of ^238^PuO_2_ in Syrian hamsters. IV. Annual report. Washington, DC: U.S. Department of Energy. LMF-115.
DOE. 1987a. Chemical speciation of plutonium in natural waters. In: Pinder J, Alberts JJ, McLead KW, eds. Environmental research on actinide elements. Washington, DC: U.S. Department of Energy, Office of Science and Technical Information, 27–47. DE86008718.
DOE. 1987b. Plutonium interactions with soil microbial metabolites: Effect on plutonium sorption by soil. In: Pinder J, Alberts JJ, McLead KW, eds. Environmental research on actinide elements. Washington, DC: U.S. Department of Energy, Office of Science and Technical Information, 1–25. DE86008718.
DOE. 1987c. Factors affecting absorption, transport, and form of plutonium in plants. In: Pinder J, Alberts JJ, McLead KW, eds. Environmental research on actinide elements. Washington, DC: U.S. Department of Energy, Office of Science and Technical Information, 83–95. DE86008713.
*DOE. 1987d. Toxicity of ^239^PuO_2_ in inmature beagle dogs. IX. Inhalation toxicology research institute annual report. 1986–1987. Washington, DC: U.S. Department of Energy, 260–265. LMF-120.
*DOE. 1987e. Toxicity of ^238^PuO_2_ in beagle dogs. A. Monodisperse 1.5-μm AMAD particles. B. Monodisperse 3.0-μm AMAD particles. XIV. In: Inhalation toxicology research institute annual report. 1986–1987. Washington, DC: U.S. Department of Energy, 235–247. LMF-120.
DOE. 1987f. Toxicity of ^239^PuO_2_ in beagle dogs. A. Monodisperse 0.75-μm AMAD particles. B. Monodisperse 1.5-μm AMAD particles. C. Monodisperse 3.0-μm AMAD particles. X. In: Inhalation toxicology research institute annual report. 1986–1987. Washington, DC: U.S. Department of Energy, 248–265. LMF-120.
*DOE. 1987g. Toxicity of ^239^PuO_2_ inhaled by aged beagle dogs. IX. In: Inhalation toxicology research institute annual report. 1986–1987. Washington, DC: U.S. Department of Energy, 266–270. LMF-120.
DOE. 1987h. Laboratory studies of actinides in marine systems. In: Pinder J, Albert JJ, McLeod KW, , eds. Environmental research on actinide elements. Springfield, VA: U.S. Department of Energy, Office of Science and Technical Information. CONF-841142.
DOE. 1988a. Inhaled plutonium oxide in dogs. Pacific Northwest Laboratory Annual Report for 1987 to the DOE Office of Energy Research Part 1. Biomedical sciences. Richland, WA: Pacific Northwest Laboratory for the U.S. Department of Energy, Office of Energy Research, 9–23. PNL-6500-Part 1. DE88011885.
DOE. 1988b. Inhaled plutonium nitrate in dogs. Part 1. Biomedical sciences. 1987 Annual report. Washington, DC: U.S. Department of Energy, Office of Energy Research, 25–29. DE88011885.
*DOE. 1988c. Radiation-induced carcinogenesis in dogs. Annual report. Washington, DC: U.S. Department of Energy. PNL-SA-14723.
DOE. 1988d. Inhalation toxicology research institute annual report. 1987–1988. Washington, DC: U.S. Department of Energy, 220–223. LMF-121.
DOE. 1989. Life-span effects of ionizing radiation in the beagle dog: A summary account of four decades of research funded by the US Department of Energy and its predecessor agencies. Washington, DC: U.S. Department of Energy, Office of Health and Environmental Research. DE89014202.
DOE. 1990a. Life-span studies of inhaled plutonium in beagle dogs. Richland, WA: U.S. Department of Energy. DE90011926.
DOE. 1990b. Long-term follow-up of HAN-1, an acute plutonium oxide inhalation case. Richland, WA: U.S. Department of Energy. DE90017194.
DOE. 1991c. Human data demonstrating extra long retention of plutonium in the lung. Washington, DC: U.S. Department of Energy. DE92002991.
DOE. 1994a. Effects of inhaled plutonium nitrate on bone and liver in dogs. Richland: U.S. Department of Energy. PNLSA23309. DE94013326.
DOE. 1994b. Biennial report on long-term dose-response studies of inhaled or injected radionuclides. 1991–1993. Washington, DC: U.S. Department of Energy, 26–32. ITRI-139.
*DOE. 1996a. Plutonium: The first 50 years. United States plutonium production, acquisition, and utilization from 1944 through 1994. U.S. Department of Energy. DOE/DP-0137. http://www.fas.org/sgp/othergov/doe/pu50y.html. May 21, 2007.
DOE. 1996b. Closing the circle on the splitting of the atom: The environmental legacy of nuclear weapons in the United States and what the Department of Energy is doing about it. U.S. Department of Energy. http://ndep.nv.gov/lts/close/circle.htm. March 10, 2009.
DOE. 1997. EML procedures manual. 28th ed. U.S. Department of Energy. HASL-300. http://www.eml.st.dhs.gov/publications/procman/. March 10, 2009.
DOE. 1999a. Natural low-level waste management program radionuclide report series. Vol. 17: Plutonium-239. U.S. Department of Energy. DOE/LLW-251. www.osti.gov/bridge/servlets/purl/14779-bpnxma/webviewable/14779.PDF. May 21, 2007.
DOE. 1999b. Disposition of mixed waste organics at the Los Alamos plutonium factory. Los Alamos: Los Alamos National Laboratory. DE00003507. http://www.osti.gov/bridge/servlets/purl/3507-DzETqD/webviewable/3507.PDF. May 31, 2007.
DOE. 1999c. RESL Technical Procedure. CHEM-TP-A.20. Actinide separations for alpha spectrometry using neodymium fluoride coprecipitation. U.S. Department of Energy, Radiological and Environmental Services Laboratory. http://infotrek.er.usgs.gov/docs/nemi/method_pdf/CHEM-TP-A.20.pdf. July 06, 2007.
DOE. 2004. Water quality and stream flow after the Cerro Grande fire. U.S. Department of Energy. http://www.doeal.gov/SWEIS/LANLDocuments/155%20LALP_05_009_%20Water%20Quality%20and%20Stream%20Flow.pdf. May 27, 2010.
DOE. 2005a. Plutonium. Radiological and chemical fact sheet to support health risk analyses for contaminated areas. U.S. Department of Energy. http://www.evs.anl.gov/pub/doc/ANL_ContaminantFactSheets_All_070418.pdf. May 21, 2007.
DOE. 2005b. National emission standards for hazardous air pollutants. Washington, DC: U.S. Department of Energy. DOENV117181065. DE2005841797.
DOE. 2005c. Environmental and resource protection programs. In: Poston TM, Hanf RW, Dirkers RL, eds. Hanford site environmental report for calendar year 2004. Richland, WA: U.S. Department of Energy. http://hanford-site.pnl.gov/envreport/2004/15222.htm. May 21, 2007.
DOE. 2005d. Environmental surveillance report. Rocky Flats environmental technology site. Information exchange. First quarter 2005. U.S. Department of Energy. http://www.cdphe.state.co.us/HM/rf/documents/envsurveillancerpt1q2005.pdf. May 23, 2007.
DOE. 2005e. Environmental surveillance report. Rocky Flats environmental technology site. Information exchange. Second quarter 2005. U.S. Department of Energy. http://www.cdphe.state.co.us/HM/rf/documents/envsurveillancerpt2q2005.pdf. May 23, 2007.
DOE. 2005f. Environmental surveillance report. Rocky Flats environmental technology site. Information exchange. Third quarter 2005. U.S. Department of Energy. http://www.cdphe.state.co.us/HM/rf/documents/envsurveillancerpt3q2005.pdf. May 23, 2007.
DOE. 2005g. Appendix C. Additional monitoring results for 2004s. In: Poston TM, Hanf RW, Dirkers RL, eds. Hanford site environmental report for calendar year 2004. Richland, WA: U.S. Department of Energy, C1-C22. http://hanford-site.pnl.gov/envreport/2004/15222.htm. May 21, 2007.
DOE. 2006a. Environmental surveillance report. Rocky Flats environmental technology site. Information exchange. Fourth quarter 2005. U.S. Department of Energy. http://www.cdphe.state.co.us/HM/rf/documents/envsurveillancerpt4q2005.pdf. May 23, 2007.
DOE. 2006b. Hanford site environmental surveillance master sampling schedule for calendar year 2006. U.S. Department of Energy. http://www.pnl.gov/main/publications/external/technical_reports/PNNL-15618.pdf. May 23, 2007. PNNL15618. DE2006876851.
DOE. 2007a. Plutonium and selected isotopes. Isotope production and distribution catalog. U.S. Department of Energy. http://www.ornl.gov/sci/isotopes/catalog.html. March 10, 2009.
DOE. 2007b. News release: DOE to send proposed Yucca Mountain legislation to congress. Washington, DC: U.S. Department of Energy. http://www.ocrwm.doe.gov/info_library/newsroom/documents/Yucca_leg_03_06_07_press_release.pdf. March 10, 2009..
DOE/EPA. 1984. Estimating dose rates to organs as a function of age following internal exposure to radionuclides. Crystal City, VA: U.S. Department of Energy/U.S. Environmental Protection Agency. DE84008212. ORNL/TM8265.
Dougherty J, Rosenblatt L. 1970. The comparative toxicity of ^226^Ra, ^239^Pu, ^228^Th, ^228^Ra, and ^90^Sr to leukocytes of beagles. Radiat Res 43:56–70.5429850
Dougherty JH, Rosenblatt LS. 1971. Long-term hematological effects of internal emitters in beagles. Radiat Res 48:319–331.5115771
Dougherty T, Stover B, Dougherty J, 1962. Studies of the biological effects of Ra-226, Pu-239, Ra-228(MsThi), Th-228(RdTh), and Sr-90 in adult beagles. Radiat Res 17:625–681.
Douglas AJ, Omar RZ, Smith PG. 1994. Cancer mortality and morbidity among workers at the Seliafiled plant of British Nuclear Fuels. Br J Cancer 70(6):1232–1243.7981083
Dovgusha VV, Bychenkov VS, Blekher AY, 2001. State of the environment in the arrangement area of the enterprises for repairing and utilization of nuclear-powered submarines. Chemosphere 42(1):69–72.
Dudoignon N, Guillet K, Fritsch P. 2003. Evaluation of risk factors for lung tumour induction in rats exposed to NpO_2_ or PuO_2_ aerosols. Int J Radiat Biol 79(3):169–174.12745881
Dudoignon N, Guillet K, Rateau G, 2001. Survival, lung clearance, dosimetry and gross pathology of rats exposed to either NpO_2_ or PuO_2_ aerosols. Int J Radiat Biol 77(9):979–990.11576458
Durbin PW. 1972. Plutonium in man: A new look at the old data. In: Stover BJ, Jee WS S, eds. Radiobiology of plutonium. Salt Lake City, UT: J.W. Press, 469–530.
Durbin PW. 1973. Metabolism and biological effects of the transplutonium elements. In: Hodge HC, Stannard JN, Hursh JB, eds. Uranium, plutonium, transplutonic elements. New York, NY: Springer-Verlag, 739–896.
Durbin PW, Horovitz MW, Close ER. 1972. Plutonium deposition kinetics in the rat. Health Phys 22(6):731–741.5084003
Durbin PW, Kullgren B, Schmidt CT. 1997. Circulatory kinetics of intravenously injected ^238^Pu(IV) citrate and ^14^C-CaNa_3_-DTPA in mice: Comparison with rat, dog, and reference man. Health Phys 72(2):222–235.9003707
Durbin PW, Kullgren B, Xu J, 2003. Octadentate hydroxypyridinonate (HOPO) ligands for plutonium (IV): Pharmacokinetics and oral efficacy. Radiat Prot Dosimetry 105(1–4):503–508.14527018
Eisenbud M, ed. 1987. Environmental radioactivity from natural, industrial, and military sources. 3rd ed. New York, NY: Academic Press, Inc., 366, 376, 422–423.
Eisenbud M, Gesell T, eds. 1997. Environmental radioactivity. From natural, industrial, and military sources. 4th ed. San Diego, CA: Academic Press, 310–311, 489.
Ellenhorn MJ, Schonwald S, Ordog G, , eds. 1997. Radiation poisoning. Ellenhorn's medical toxicology. Diagnosis and treatment of human poisoning. Baltimore, MD: Williams & Wilkins, 1682–1723.
EPA. 1976a. Evaluation of sample collection and analysis techniques for environmental plutonium. In: Selected topics: Transuranium elements in the general environment, 1978. Washington, DC: U.S. Environmental Protection Agency, Office of Radiation Programs.
EPA. 1976b. Availability, uptake and translocation of plutonium within biological systems: A review of significant literature. EPA600376043.
EPA. 1979. Radiochemical analytical procedures for analysis of environmental samples. Las Vegas, NV: U.S. Environmental Protection Agency. EMAL-LV-0539–17.
EPA. 1980. Prescribed procedures for measurement of radioactivity in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency. Environmental Monitoring and Support Laboratory. EPA600480032.
EPA. 1982. Determination of plutonium in drinking water. Method 911. Cincinnati, OH: U.S. Environmental Protection Agency. http://www.epa.gov/ne/info/testmethods/pdfs/method%20911.pdf. August 17, 2007.
EPA. 1984. Radiochemistry procedures manual. Montgomery, AL: U.S. Environmental Protection Agency. Eastern Environmental Radiation Facility. EPA520584006.
EPA. 1987. Radiation protection guidance to federal agencies for occupational exposure; approval of Environmental Protection Agency recommendations. U.S. Environmental Protection Agency. Fed Regist 52:2823–2834.
*EPA. 1988a. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.
EPA. 1988b. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion. Federal Guidance Report No. 11. Washington, DC: U.S. Environmental Protection Agency, Office of Radiation Programs. EPA520188020.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1999. Cancer risk coefficients for environmental exposure to radionuclides. Federal Guidance Report No. 13. Washington, DC: U.S. Environmental Protection Agency. EPA402R99001. http://www.epa.gov/radiation/docs/federal/402-r-99-001.pdf. May 18, 2007.
EPA. 2000. Federal Guidance Report No. 13. Cancer risk coefficients for environmental exposure to radionuclides. CD Supplement [CD ROM]. EPA402C99001.
EPA. 2001. Radionuclide table: Radionuclide carcinogenicity–slope factors. (Federal Guidance Report No. 13 morbidity risk coefficients, in units of picocuries). Washington, DC: U.S. Environmental Protection Agency, Office of Radiation and Indoor Air. http://www.epa.gov/radiation/heast/docs/heast2_table_4-d2_0401.wpd. May 18, 2007.
EPA. 2002. Plutonium and selected isotopes. Federal Guidance Report No. 13. Cancer risk coefficients for environmental exposure to radiionuclides: CD supplement. Washington, DC: U.S. Environmental Protection Agency. EPA40299001, Rev 1.
EPA. 2003. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F03016. http://www.epa.gov/safewater/mcl.html. March 07, 2007.
EPA. 2006a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. April 11, 2007.
EPA. 2006b. Inventory of radiological methodologies. Montgomery, AL: U.S. Environmental Protection Agency. EPA402R06007. http://www.emsus.com/downloads/IRM.pdf. March 10, 2009.
EPA. 2007b. Acute exposure guideline levels (AEGLs) Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/pubs/compiled.pdf. April 11, 2007.
EPA. 2007c. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=e2e9f6b114c266e96a9eea3ea8e0e821&rgn=div8&view=text&node=40:27.0.1.1.2.0.1.4&idno=40. March 10, 2009
EPA. 2007d. National emission standards for hazardous air pollutants; national emission standards for emissions of radionuclides other than radon from Department of Energy facilities. Code of Federal Regulations.40 CFR 61 Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/epahome/cfr40.htm. July 11, 2007.
EPA. 2009. About Yucca Mountain standards. U.S. Environmental Protection Agency. http://www.epa.gov/radiation/yucca/about.html. March 18, 2009.
Epov VN, Benkhedda K, Cornett RJ, 2005. Rapid determination of plutonium in urine using flow injection on-line preconcentration and inductively coupled plasma mass spectrometry. J Anal Atom Spectrom 20:424–430.
Etherington G, Stradling GN, Hodgson A, 2003. Anomalously high excretion of Pu in urine following inhalation of plutonium nitrate? Radiat Prot Dosimetry 105(1–4):321–324.14526978
Evans P, Elahi S, Lee K, 2003. A rapid and accurate method for the determination of plutonium in food using magnetic sector ICP-MS with an ultra-sonic nebuliser and ion chromatography. J Environ Monit 5:175–179.12619774
FDA. 2004. Supporting document for guidance levels for radionuclides in domestic and imported foods. Washington, DC: U.S. Food and Drug Administration. http://www.cfsan.fda.gov/~dms/nucleve2.html. May 18, 2007.
FDA. 2005. CPG Sec. 560.750 Radionuclides in imported foods-levels of concern. http://www.fda.gov/ICECI/ComplianceManuals/CompliancePolicyGuidanceManual/UCM074576. May 27, 2010.
FEDRIP. 2007. Plutonium. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Figg D, Martinez A, Drake L, 2000. Inductively coupled plasma-mass spectrometry analysis of plutonium samples. Los Alamos, NM: Los Alamos National Laboratory. LA-13754-MS. http://www.osti.gov/bridge/product.biblio.jsp?query_id=0&page=0&osti_id=766949. June 25, 2007.
Filipy RE, Ford YC. 1997. A comparison of the distributions of actinide elements in selected tissues and organs of humans and beagle dogs. In: USTUR annual report for October 1, 1995 through September 30, 1996. Richland, WA: United States Transuranium and Uranium Registries, 45–51. USTUR-0072–97.
Filipy RE, Kathren RL. 1996. Changes in soft tissue concentrations of plutonium and americium with time after human occupational exposure. Health Phys 70(2):153–159.8567281
Filipy RE, Alldredge JR, Hall CA, 2003. Estimation of actinide skeletal content in humans based on bone samples collected at autopsy. Health Phys 84(1):34–45.12498516
Filipy RE, Kathren RL, McInroy JF, 1994. Soft tissue concentrations of plutonium and americium in occupationally-exposed humans. Health Phys 67(5):477–485.7928359
Finch GL, Lundgren DL, Barr EB, 1998. Chronic cigarette smoke exposure increases the pulmonary retention and radiation dose of ^239^Pu inhaled as ^239^PuO_2_ by F344 rats. Health Phys 75(6):597–609.9827506
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Fouillit M, Grillon G, Fritsch P, 2004. Comparative tissue uptake and cellular deposition of three different plutonium chemical forms in rats. Int J Radiat Biol 80(9):683–689.15586888
Fox JC, McNally NJ. 1990. The rejoining of DNA double-strand breaks following irradiation with ^238^Pu alpha-particles: Evidence for a fast component of repair as measured by neutral filter elution. Int J Radiat Biol 57(3):513–521.1968944
*Fresquez PR, Biggs JR, Bennett KD. 1999a. Radionuclides in deer and elk from Los Alamos National Laboratory and the doses to humans from the ingestion of muscle and bone. J Environ Sci Health B B34(5):901–915.
Fresquez PR, Kraig DH, Mullen MA, 1999b. Radionuclides and trace elements in fish collected upstream and downstream of Los Alamos National Laboratory and the doses to humans from the consumption of muscle and bone. J Environ Sci Health B 34(5):885–889.10466108
Fritsch P. 2007. Uncertainties in doses calculated according to ICRP recommendations after inhalation of ^239^PuO_2_ and early chest monitoring. Radiat Prot Dosimetry. (Advanced access published January)
Fritsch P, Beauvallet M, Moutairou K, 1987. Acute lesions induced by alpha-irradiation of intestine after plutonium gavage of neonatal rats. Int J Radiat Biol Relat Stud Phys Chem Med 52(1):1–6.3496302
Froidevaux P, Geering J, Pillonel L, 2004. 90Sr, 238U, 234U, 137Cs, 40K, and 239/240Pu in emmental type cheese produced in different regions of Western Europe. J Environ Radioact 72:287–298.14972411
Garger EK, Kashpur VA, Li WB, 2006. Radioactive aerosols released from the Chernobyl Shelter into the immediate environment. Radiat Environ Biophys 45(2):105–114.16733725
Garland TR, Cataldo DA, Wildung RE. 1981. Absorption, transport, and chemical fate of plutonium in soybean plants. J Agric Food Chem 29(5):915–920.7198131
Gauthier-Lafaye F, Pourcelot L, Eikenberg J, 2008. Radioisotope contaminations from releases of the Tomsk-Seversk nuclear facilitiy (Siberia, Russia) J Environ Radioact 99:680–693.17996340
Gearhart J, Diel J, McClellan R. 1980. Intrahepatic distribution of plutonium in beagles. Radiat Res 84(2):343–352.7443987
Generoso WM, Cain KT, Cacheiro NL, 1985. ^239^Plutonium-induced heritable translocations in male mice. Mutat Res 152(1):49–52.4047084
Gervelas C, Serandour AL, Geiger S, 2007. Direct lung delivery of a dry powder formulation of DTPA with improved aerosolization properties: Effect on lung and systemic decorporation of plutonium. J Control Release 118(1):78–86.17241685
Gilbert ES, Koshurnikova NA, Sokolnikov M, 2000. Liver cancers in Mayak workers. Radiat Res 154(3):246–252.10956429
Gilbert ES, Koshurnikova NA, Sokolnikov ME, 2004. Lung cancer in Mayak workers. Radiat Res 162(5):505–516.15624305
*Gilbert RO, Engel DW, Anspaugh LR. 1989a. Transfer of aged ^239+240^Pu, ^238^Pu, ^241^Am, and ^137^Cs to cattle grazing a contaminated arid environment. Sci Total Environ 85:53–62.2814465
Gilbert ES, Petersen GR, Buchanan JA. 1989b. Mortality of workers at the Hanford Site: 1945–1981. Health Phys 56(1):11–25.2909496
Gillett NA, Muggenburg BA, Mewhinney JA, 1988. Primary liver tumors in beagle dogs exposed by inhalation to aerosols of plutonium-238 dioxide. Am J Pathol 133:265–276.3142267
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gordeev SK, Ermakov AI, Kvasnikova EV. 2007. Radioactive composition of subterranean waters and soil near an underground nuclear explosion on the Semipalatinsk test area. At Energ (English) 103(3):741–745.
Gorden AE V, Xu J, Raymond KN. 2003. Rational design of sequestering agents for plutonium and other actinides. Chem Rev 103:4207–4282.14611263
Green D, Howells GR, Humphreys ER, 1976. Radiation dose to mouse testes from ^239^Pu. In: Webster S, ed. The health effects of plutonium and radium. Salt Lake City, UT: J.W. Press, 21–31.
Green D, Howells G, Vennart J, 1977. The distribution of plutonium in the mouse ovary. Int J Appl Radiat Isot 28(5):497–502.881271
Green D, Howells GR, Watts RH. 1979. Plutonium in the tissues of foetal, neonatal and suckling mice after Pu-administration to their dams. Int J Radiat Biol 35(5):417–432.
Griffin CS, Harvey AN, Savage JR. 1994. Chromatid damage induced by ^238^Pu alpha-particles in G2 and S phase Chinese hamster V79 cells (Comment in: Int J Radiat Biol 78(10):945–948). Int J Radiat Biol 66(1):85–98.8027615
Guilmette RA. 1986. A low-energy photon detector for the radioassay of Pu or Am in biological samples. Health Phys 51(6):797–803.3781853
Guilmette RA, Muggenburg BA. 1989. Effectiveness of continuously infused DTPA for decorporating inhaled plutonium-238 and curium-244 aerosols. Health Phys 56:S36.
Guilmette RA, Muggenburg BA. 1993. Decorporation therapy for inhaled plutonium nitrate using repeatedly and continuously administered DTPA. Int J Radiat Biol 63(3):395–403.8095291
Guilmette RA, Diel JH, Muggenburg BA, 1984. Biokinetics of inhaled plutonium-239 dioxide in the beagle dog: Effect of aerosol particle size. Int J Radiat Biol Relat Stud Phys Chem Med 45(6):563–581.6610656
Guilmette RA, Lindenbaum A, Friedman A, 1978. Influence of injected mass of plutonium on its biological distribution. Health Phys 35(4):529–536.748256
Guilmette RA, Muggenburg BA, Hahn FF, 1987. Dosimetry of ^230^Pu in dogs that inhaled monodisperse aerosols of ^239^PuO_2_. Radiat Res 110(2):199–218.3575651
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hahn FF, Brooks AL, Mewhinney JA. 1984. Inhalation toxicology research institute annual report. 1983–1984. Washington, DC: U.S. Department of Energy, 267–271. LMF-113.
Hahn FF, Gillett NA, Boecker BB, 1991a. Comparison of bone lesions by inhaled ^90^SrCl_2_ or ^238^PuO_2_. In: Proceedings from the Joint Bone Radiobiology Workshop, Toronto, Canada. Washingont, DC: U.S. Department of Energy DE91017509.
Hahn FF, Muggenburg BA, Guilmette RA, 1999. Comparative stochastic effects of inhaled alpha- and beta-particle-emitting radionuclides in beagle dogs. Radiat Res 152:S19–S22.10564929
Hahn FF, Romanov SA, Guilmette RA, 2003. Distribution of plutonium particles in the lungs of Mayak workers. Radiat Prot Dosimetry 105(1–4):81–84.14526932
Hahn FF, Romanov SA, Guilmette RA, 2004. Plutonium microdistribution in the lungs of Mayak workers. Radiat Res 161(5):568–581.15161366
Ham GJ, Harrison JD, Popplewell DS, 1994. The gastrointestinal absorption of neptunium, plutonium and americium in a primate (C. jacchus). Sci Total Environ 145:1–6.8016624
Hande MP, Azizova TV, Burak LE, 2005. Complex chromosome aberrations persist in individuals many years after occupational exposure to densely ionizing radiation: An mFISH study. Genes Chromosomes Cancer 44(1):1–9.15912529
Hande MP, Azizova TV, Geard CR, 2003. Past exposure to densely ionizing radiation leaves a unique permanent signature in the genome. Am J Hum Genet 72:1162–1170.12679897
Hanson WC. 1975. Ecological considerations of the behavior of plutonium in the environment. Health Phys 28:529–537.1099055
Harley JH. 1980. Plutonium in the environment - a review. J Radiat Res 21:83–104.6991684
Harrison JD, Naylor GP L, Stather JW. 1994. The gastrointestinal absorption of plutonium and americium in rats and guinea pigs after ingestion of dusts from the former nuclear weapons site at Maralinga: Implications for human exposure. Sci Total Environ 143(2–3):211–220.8209224
HazDat. 2007. Plutonium and selected isotopes. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. April 6, 2007.
Hempelmann LH, Langham WH, Richmond CR, 1973. Manhattan project plutonium workers: A twenty-seven year follow-up study of selected cases. Health Phys 25(5):461–479.4786576
Herbert RA, Gillett NA, Rebar AH, 1993. Sequential analysis of the pathogenesis of plutonium-induced pulmonary neoplasms in the rat: Morphology, morphometry, and cytokinetics. Radiat Res 134(1):29–42.8475252
Higgo JJ W, Rees LV C. 1986. Adsorption of actinides by marine sediments: Effect of the sediment/seawater ratio on the measured distribution ratio. Environ Sci Technol 20(5):483–490.19994932
Hindman FD. 1986. Actinide separations for α spectrometry using neodymium fluoride co-precipitation. Anal Chem 58:1238–1241.
Hindman FD. 1983. Neodymium fluoride mounting for α spectrometric determination of uranium, plutonium, and americium. Anal Chem 55:2460–2461.
Hirose K, Aoyama M. 2002. Chemical speciation of plutonium in seawater. Anal Bioanal Chem 372(3):418–420.11939526
Hirose K, Aoyama M. 2003. Present background levels of surface ^137^Cs and ^239,240^Pu concentrations in the Pacific. J Environ Radioact 69(1):53–60.12860089
Hirose K, Aoyama M, Fukasawa M, 2007. Plutonium and 137Cs in surface water of the South Pacific Ocean. Sci Total Environ 381:243–255.17459459
Hisamatsu S, Takizawa Y, Abe T. 1987. Ingestion intake of fallout Pu in Japan. Health Phys 52(2):193–200.3818286
Hodgson A, Shutt Al, Etherington G, 2003. Comparison of predicted with observed biokinetics of inhaled plutonium nitrate and gadolinium oxide in humans. Radiat Prot Dosimetry 105(1–4):91–94.14526934
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hölgye Z. 2008. Plutonium isotopes in surface air of Prague in 1986–2006. J Environ Radioact 99:1653–1655.18597907
HSDB. 2009. Plutonium and selected isotopes. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov/cgi-bin/sis/search. March 10, 2009.
Hunt GJ. 1998. Transfer across the human gut of environmental plutonium, americium, cobalt, cesium and technetium: Studies with cockles (Cerastod ermaedule) from the Irish sea. J Radiol Prot 18(2):101–109.9656190
Hunt GJ, Leonard DRP, Lovett MB. 1986. Transfer of environmental plutonium and americium across the human gut. Sci Total Environ 53:89–109.3749873
Hunt GJ, Leonard DRP, Lovett MB. 1990. Transfer of environmental plutonium and americium across the human gut: A second study. Sci Total Environ 90:273–282.2305242
*IAEA. 1976a. Biological effect of focal alpha radiation on the hamster lung. In: Biological and environmental effects of low-level radiation. Vol. 2. Vienna: International Atomic Energy Agency, 121–129.
IAEA. 1976b. Biological effectiveness of ^239^Pu, ^144^Ce and ^90^Sr citrate in producing chromosome damage, bone-related tumours, liver tumours and life shortening in the Chinese hamster. In: Biological and environmental effects of low-level radiation. Vienna: International Atomic Energy Agency, 143–152.
*IAEA. 1976c. Transuranic element pathways to man. In: Transuranium nuclides in the environment. Vienna: International Atomic Energy Agency, 367–383. IAEA-SM-199/40.
IAEA. 1976d. Interaction of plutonium with complexing substances in soils and natural waters. In: Transuranium nuclides in the environment. Proceedings of the symposium on transuranium nuclides in the environment. Vienna: International Atomic Energy Agency, 273–287. IAEA-SM-199/51.
IAEA. 1976e. Effect of size and alpha flux of ^239^PuO_2_ particles on production of chromosome aberrations in liver of Chinese hamster. In: Biological and environmental effects of low-level radiation. Vol. 2. Vienna: International Atomic Energy Agency, 131–142.
*IAEA. 1976f. Removal of plutonium from drinking water by community water treatment facilities. In: Transuranium nuclides in the environment. Proceedings of the symposium on transuranium nuclides in the environment. Vienna: International Atomic Energy Agency, 401–408. IAEA-SM-199/81.
IAEA. 1976g. Plutonium and americium in Lake Michigan sediments. In: Transuranium nuclides in the environment. Proceedings of the symposium on transuranium nuclides in the environment. Vienna: International Atomic Energy Agency, 493–514. IAEA-SM-199/47.
*IAEA. 1976h. Plutonium in Atlantic coastal estuaries in the Southeastern United States of America. In: Transuranium nuclides in the environment. Proceedings of the symposium on transuranium nuclides in the environment. Vienna: International Atomic Energy Agency, 79–87. IAEA-SM-199/84.
*IAEA. 1976i. Environmental and public health consequences of the controlled disposal of transuranic elements to the marine environment. In: Transuranium nuclides in the environment. Proceedings of the symposium on transuranium nuclides in the environment. Vienna: International Atomic Energy Agency, 139–153. IAEA-SM-199/11.
*IAEA. 1976j. Current status of Utah long-term ^239^Pu studies. In: Biological and environmental effects of low-level radiation. Vol. 2. Vienna: International Atomic Energy Agency, 79–94.
IAEA. 1976k. Dominant lethal tests of male mice given ^239^Pu salt injections. In: Biological and environmental effects of low-level radiation. Vol. 1. Vienna: International Atomic Energy Agency, 39–49.
IAEA. 1979. Chromosome changes in somatic cells of workers with internal depositions of plutonium. In: Biological implications of radionuclides released from nuclear industries. Vol. 2. Vienna: International Atomic Energy Agency, 195–210. STI/PUB/522.
IAEA. 2004. Sediment distribution coefficients and concentration factors for biota in the marine environment. Technical report series no. 422. International Atomic Energy Agency. http://www-pub.iaea.org/MTCD/publications/PDF/TRS422_web.pdf. May 08, 2007.
IARC. 2006. Agents reviewed by the IARC Monographs. Volumes 1–96. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. April 11, 2007.
Ibrahim SA, Warren GM, Whicker FW, 2002. Plutonium in Colorado residents: Results of autopsy bone samples collected during 1975–1979. Health Phys 83(2):165–177.12132705
Ibrahim SA, Webb SB, Whicker FW. 1997. Contributions of Rocky Flats releases to the total plutonium in regional soils. Health Phys 72(1):42–48.8972825
Ibrahim SA, Whicker FW, Reuss SK, 1999. Plutonium excretion in urine of residents living near the Rocky Flats environmental technology site. Health Phys 76(4):368–379.10086597
ICRP. 1972. The metabolism of compounds of plutonium and other actinides. ICRP Publication 19. International Commission on Radiological Protection. New York, NY: Pergammon Press, 2–59.
ICRP. 1979. Limits for intakes of radionuclides by workers. Part 1. Volume 2, No. 3/4. ICRP Publication 30. International Commission on Radiological Protection. Elmsford, NY: Pergammon Press, 23–46.
ICRP. 1986. The metabolism of plutonium and related elements. ICRP Publication 48. International Commission on Radiological Protection. Elmsford, NY: Pergamon Press.
ICRP. 1990. Age-dependent doses to members of the public from intake of radionuclides. Part 1. ICRP Publication 56. International Commission on Radiological Protection. Elmsford, NY: Pergamon Press Inc., 6–11, 63–66, 75–89.
ICRP. 1991. 1990 Recommendations of the International Commission on Radiological Protection. ICRP Publication 60. International Commission on Radiological Protection. Elmsford, NY: Pergamon Press Inc., 32–77.
ICRP. 1994a. Age-dependent doses to members of the public from intake of radionuclides: Part 2. Ingestion dose coefficients. ICRP Publication 67. The International Commission on Radiological Protection. Tarrytown, NY: Elsevier Science Inc.
ICRP. 1994b. Human respiratory tract model for radiological protection. ICRP Publication 66. International Commission on Radiological Protection. Tarrytown, NY: Elsevier Science, Inc.
ICRP. 1996a Age-dependent doses to members of the public from intake of radionuclides: Part 4. Inhalation dose coefficients. Publication No. 71. International Commission on Radiological Protection Tarrytown, NY: Elsevier Sciences, Inc., 9–23, 328–343.
ICRP. 1996b. Age-dependent doses to members of the public from intake of radionuclides. Part 5. International Commission on Radiological Protection. Publication No. 72. Tarrytown, NY: Elsevier Science, Inc., 41, 80.
ICRP. 2001. Plutonium. The ICRP database of dose coefficients workers and members of the public. Version 2.01. International Commission on Radiological Protection. Elsevier Science Ltd.
*IRIS. 2009. Plutonium. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. March 19, 2009.
Iranzo E, Salvador S, Iranzo CE. 1987. Air concentrations of ^239^Pu and ^240^Pu and potential radiation doses to persons living near Pu-contaminated areas in Palomares, Spain. Health Phys 52(4):453–461.3570788
Ivanova NP, Shvydko NS, Ershov EB, 1995. Population doses in Russia from plutonium fallout following the Chernobyl accident. Radiat Prot Dosimetry 58(4):255–260.
Jacob V, Jacob P, Meckbach R, 2005. Lung cancer in Mayak workers: Interaction of smoking and plutonium exposure. (Erratum in: Radiat Environ Biophys 44(4):307). Radiat Environ Biophys 44(2):119–129.16136318
Jacob V, Jacob P, Meckbach R, 2006. Lung cancer in Mayak workers: Interaction of smoking and plutonium exposure. (Erratum to: Radiat Environ Biophys 44(2):119–129). Radiat Environ Biophys 44(4):307.
James AC, Filipy RE, Russell JJ, 2003. USTUR case 0259 whole body donation: A comprehensive test of the current models for the behavior of inhaled ^238^PuO_2_ ceramic particles. Health Phys 84(1):2–33.12498515
Jenner TJ, deLara CM, O’Neill P, 1993. Induction and rejoining of DNA double-strand breaks in V79–4 mammalian cells following γ- and α- irradiation. Int J Radiat Biol 64(3):265–273.8105005
Jimenez-Ramos MC, Garcia-Tenorio R, Vioque I, 2006. Presence of plutonium contamination in soils from Palomares (Spain) Environ Pollut 142:487–492.16413954
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190(1):3–16.6769537
Kabata-Pendias A, Pendias H. 1984. Trace elements in soils and plants. Boca Raton, Florida: CRC Press, Inc., 147.
Kadhim MA, Macdonald DA, Goodhead DT, 1992. Transmission of chromosomal instability after plutonium α-particle irradiation. Nature 355(6362):738–740.1741061
Kathren RL. 2004. A review of contributions of human tissue studies to biokinetics, bioeffects and dosimetry of plutonium in man. Radiat Prot Dosimetry 109(4):399–407.15273358
Kathren RL, McInroy JF. 1991. Comparison of systemic plutonium deposition estimates from urinalysis and autopsy data in five whole-body donors. Health Phys 60(4):481–488.2001943
Kathren RL, McInroy JF, Reichert MM, 1988. Partitioning of ^238^Pu, ^239^Pu and ^241^Am in skeleton and liver of U.S. transuranium registry autopsy cases. Health Phys 54:181–188.3338916
Kathren RL, McInroy JF, Swint MJ. 1987. Actinide distribution in the human skeleton. Health Phys 52:179–192.3818285
Kawamura H. 1987. Plutonium and Am contamination of tourist property and estimated inhalation intake of visitors to Kiev after the Chernobyl accident. Health Phys 52:793–795.3583744
Kawamura H, Tanaka G. 1983. Actinides concentrations in human tissues. Health Phys 44(1):451–456.6305880
Ketterer ME, Szechenyi SC. 2008. Determination of plutonium and other transuranic elements by inductively coupled plasma mass spectrometry: a historical perspective and new frontiers in the environmental sciences. Spectrochim Acta, Part B 63:719–737.
Khokhryakov VF, Belyaev AP, Kudryavtseva TI, 2003. Successful DTPA therapy in the case of ^239^Pu penetration via injured skin exposed to nitric acid. Radiat Prot Dosimetry 105(1–4):499–502.14527017
Khokhryakov VF, Kellerer AM, Kreisheimer M, 1998. Lung cancer in nuclear workers of Mayak. Radiat Environ Biophys 37(1):11–17.9615338
Khokhryakov VF, Menshikh ZS, Suslova KG, 1994. Plutonium excretion model for healthy man. Radiat Prot Dosimetry 53(1–4):235–239.
*Khokhryakov VF, Suslova KG, Filipy RE, 2000. Metabolism and dosimetry of actinide elements in occupationally-exposed personnel of Russia and the United States: A summary progress report. Health Phys 79(1):63–71.10855779
Khokhryakov VF, Suslova KG, Kudryatseva TI, 2004. Relative role of plutonium excretion with urine and feces from human body. Health Phys 86(5):523–527.15083148
Khokhryakov VF, Suslova KG, Vostrotin VV, 2002. The development of the plutonium lung clearance model for exposure estimation of the Mayak production association, nuclear plant workers. Health Phys 82(4):425–431.11906131
Khokhryakov VF, Suslova KG, Vostrotin VV, 2005. Adaptation of the ICRP publication 66 respiratory tract model to data on plutonium biokinetics for Mayak workers. Health Phys 88(2):125–132.15650587
Koch L. 2005. Plutonium and plutonium compounds. Ullmann's encyclopedia of industrial chemistry. Wiley-VCH Verlag GmbH & Co. http://www.mrw.interscience.wiley.com/emrw/9783527306732/ueic/article/a21_133/current/pdf. May 22, 2007.
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Koshurnikova NA, Gilbert ES, Sokolnikov M, 2000. Bone cancers in Mayak workers. Radiat Res 154(3):237–245.10956428
Krahenbuhl MP, Bess JD, Wilde JL, 2005. Uncertainties analysis of doses resulting from chronic inhalation of plutonium at the Mayak production association. Health Phys 89(1):33–45.15951690
Kreisheimer M, Sokolnikov ME, Koshurnikova NA, 2003. Lung cancer mortality among nuclear workers of the Mayak facilities in the former Soviet Union. An updated analysis considering smoking as the main confounding factor. Radiat Environ Biophys 42(2):129–135.12851829
Kressin IK, Moss WD, Campbell EE, 1975. Plutonium-242 vs plutonium-236 as an analytical tracer. Health Phys 28:41–47.1110164
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubota Y, Sato H, Koshimoto C, 1993. Transfer of ^239^Pu to mouse fetoplacental tissues. J Radiat Res (Tokyo) 34(2):157–163.8360858
Kurihara O, Momose T, Tasaki T, 2002. Early faecal excretion of inhaled plutonium. Radiat Prot Dosimetry 102(2):137–144.12408490
LaBauve RJ, Brooks AL, Mauderly JL, 1980. Cytogenetic and other biological effects of ^239^PuO_2_ inhaled by the Rhesus monkey. Radiat Res 82(2):310–335.6769136
Langham WH. 1959. Physiology and toxicology of plutonium-239 and its industrial medical control. Health Phys 2:172–185.14413981
Langham WH, Bassett SH, Harris PS, 1950. Distribution and excretion of plutonium administered intravenously to man. Los Alamos Scientific Laboratory of the University of California and the Los Alamos Scientific Laboratory of the University of Rochester School of Medicine and Dentistry. LA-1151. http://www.fas.org/sgp/othergov/doe/lanl/lib-www/la-pubs/00329054.pdf. August 29, 2007.
Langham WH, Bassett SH, Harris PS, 1980. Distribution and excretion of plutonium administered intravenously to man. Health Phys 38:1031–1060.
Lansard B, Charmasson S, Gasco C. 2007. Spatial and temporal variations of plutonium isotopes (238Pu and 239,240Pu) in sediments off the Rhone River mouth (NW Mediterranean) Sci Total Environ 376:215–227.17335871
Lataillade G, Verry M, Rateau G, 1995. Translocation of plutonium from rat and monkey lung after inhalation of industrial plutonium oxide and mixed uranium and plutonium oxide. Int J Radiat Biol 67(3):373–380.7897285
Lee MH, Clark SB. 2005. Activities of Pu and Am isotopes and isotopic ratios in a soil contaminated by weapons-grade plutonium. Environ Sci Technol 39(15):5512–5516.16124281
Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leggett RW. 1985. A model of the retention, translocation and excretion of systemic Pu. Health Phys 49(6):1115–1137.4077514
Leggett RW, Eckerman KF, Khokhryakov VF, 2005. Mayak worker study: An improved biokinetic model for reconstructing doses fron internally deposited plutonium. Radiat Res 164:111–122.16038582
Lehmann M, Culig H, Taylor DM. 1983. Identification of transferrin as the principal plutonium-binding protein in the blood serum and liver cytosol of rats: Immunological and chromatographic studies. Int J Radiat Biol 44(1):65–74.
Lehto J, Salminen S, Jaakkola T, 2006. Plutonium in the air in Kurchatov, Kazakhstan. Sci Total Environ 366(1):206–217.16197982
Leonard BR. 1980. Properties of plutonium isotopes. In: Plutonium handbook: A guide to the technology. Vol. I, II. La Grange Park, IL: The American Nuclear Society, 1–8.
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Liao H, Zheng J, Wu F, 2008. Determination of plutonium isotopes in freshwater lake sediments by sector-field ICP-MS after separation using ion-exchange chromatography. Appl Radiat Isot 66:1138–1145.18276148
Lide DR. 2005. CRC handbook of chemistry and physics. 2005–2006. 86th ed. Boca Raton, FL: CRC Press. Taylor & Francis Group, 4–27, 4–79, 11–174, 11–175.
Lide DR. 2008. CRC handbook of chemistry and physics. 2007–2008. 88th ed. Boca Raton, FL: CRC Press. Taylor & Francis Group, 4–26, 4–27, 4–81, 11–197, 11–198.
Lister BA J, Morgan A, Sherwood RJ. 1963. Excretion of plutonium following accidental skin contamination. Health Phys 9:803–815.14060354
Litaor MI. 1999. Plutonium contamination in soils in open space and residential areas near Rocky Flats, Colorado. Health Phys 76(2):171–179.9929128
Little CA, Whicker FW. 1978. Plutonium distribution in Rocky Flats soil. Health Phys 34(5):451–457.711456
Livens FR, Baxter MS. 1988. Particle size and radionuclide levels in some West Cumbrian soils. Sci Total Environ 70:1–17.3363331
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Livingston GK, Falk RB, Schmid E. 2006. Effect of occupational radiation exposures on chromosome rates in former plutonium workers. Radiat Res 166(1):89–97.16808624
Lloyd RD, Angus W, Taylor GN, 1995a. Soft tissue tumors induced by monomeric ^239^Pu. Health Phys 69(4):530–537.7558844
Lloyd RD, Boseman JJ, Taylor GN, 1978c. Decorporation from beagles of a mixture of monomeric and particulate plutonium using Ca-DTPA and Zn-DTPA: Dependence upon frequency of administration. Health Phys 35(2):217–227.701018
*Lloyd RD, Bruenger FW, Angus W, 1995b. Mammary tumor occurrence in beagles given ^239^Pu. Health Phys 69(3):385–390.7635735
Lloyd RD, Miller SC, Taylor GN, 1999a. Is there a difference in radionuclide-induced bone tumor sensitivity between male and female beagles? Health Phys 77(2):178–182.12877339
Lloyd RD, Taylor GN, Angus W, 1993. Bone cancer occurrence among beagles given ^239^Pu as young adults. Health Phys 64(1):45–51.8416214
Lloyd RD, Taylor GN, Jee WS, 1999b. Relative radiosensitivity of bone tumor induction among beagles as a function of age at injection of ^239^Pu or ^226^Ra. Health Phys 76(1):50–56.9883947
Luciani A, Polig E. 2000. Verification and modification of the ICRP-67 model for plutonium dose calculation. Health Phys 78(3):303–310.10688453
Luciani A, Doerfel H, Polig E. 2001. Sensitivity analysis of the urinary excretion of plutonium. Radiat Prot Dosimetry 93(2):179–183.11548342
Luciani A, Doerfel H, Polig E. 2003. Uncertainty analysis of the urinary excretion of plutonium. Radiat Prot Dosimetry 105(1–4):383–386.14526992
Luksiene B, Druteikiene R, Gvozdaite R, 2006. Comparative analysis of ^239^Pu, ^137^Cs, ^210^Pb and ^40^K spatial distributions in the top soil layer at the Baltic coast. J Environ Radioact 87(3):305–314.16497419
Lund E, Tkatchev AV. 1996. Concentration of plutonium in placentas from the Nenetz autonomous district close to the Novaya Zemlaye nuclear weapons test site. Radiat Prot Dosimetry 67(2):135–137.
Lundgren DL, Damon EG, Diel JH, 1981. The deposition, distribution and retention of inhaled ^239^PuO_2_ in the lungs of rats with pulmonary emphysema. Health Phys 40(2):231–235.6908591
Lundgren DL, Gillett NA, Hahn FF, 1987. Effects of protraction of the alpha dose to the lungs of mice by repeated inhalation exposure to aerosols of ^239^PuO_2_. Radiat Res 111(2):201–224.3628712
Lundgren DL, Hahn FF, Rebar AH, 1983. Effects of the single or repeated inhalation exposure of Syrian hamsters to aerosols of ^239^PuO_2_. Int J Radiat Biol Relat Stud Phys Chem Med 43(1):1–18.6601068
Lundgren DL, Haley PJ, Hahn FF, 1995. Pulmonary carcinogenicity of repeated inhalation exposure of rats to aerosols of ^239^PuO_2_. Radiat Res 142(1):39–53.7899558
Lüning KG, Frolen H, Nilsson A. 1976. Genetic effects of ^239^Pu salt injections in male mice. Mutat Res 34(3):539–542.1264113
MAFF. 1997b. Radioactivity in food and the environment, 1996. London: Ministry of Agriculture, Fisheries and Food. RIFE-2. http://www.sepa.org.uk/pdf/publications/rife/rife2.pdf. March 31, 2007.
MAFF. 1997a. Number 110. A survey of levels of radioactivity in UK produced beverages. Ministry of Agriculture, Fisheries and Food. http://archive.food.gov.uk/maff/archive/food/infsheet/1997/no110/110bev.htm. May 21, 2007.
Makhijani A. 1997. Technical aspects of the use of weapons plutonium as reactor fuel. Science for democratic action. An IEER publication. Vol. 5(4). Institute for Energy and Environmental Research. http://www.ieer.org/sdafiles/vol_5/5-4/moxmain4.html. August 28, 2007.
Martin JE. 1986. Determination of ^241^Pu in low-level radioactive wastes from reactors. Health Phys 51(5):621–631.3771223
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McGeoghegan D, Gillies M, Riddell AE, 2003. Mortality and cancer morbidity experience of female workers at the British nuclear fuels Sellafield plant, 1946–1998. Am J Ind Med 44(6):653–663.14635242
McInroy JF, Kathren RL, Swint MJ. 1989. Distribution of plutonium and americium in whole bodies donated to the United States transuranium registry. Radiat Protect Dosimet 26(1–4):151–158.
McInroy JF, Kathren RL, Voelz GL, 1991. U.S. Transuranium Registry report on the ^239^Pu distribution in a human body. Health Phys 60(3):307–333.1847360
Ménétrier F, Grappin L, Raymond P, 2005. Treatment of accidental intakes of plutonium and americium: Guidance notes. Appl Radiat Isot 62(6):829–846.15799861
*Metivier H, Masse R, Legendre N, 1978a. Pulmonary connective tissue modifications induced by internal alpha irradiation. I. Effect of time and dose on alterations following inhalation of plutonium-239 dioxide aerosol in rat. Radiat Res 75(2):385–396.715180
Métivier H, Masse R, Wahrendorf J, 1986. Combined effects of inhaled plutonium oxide and benzo[a]pyrene on lung carcinogenesis in rats. In: Thompson R, McHaffey J, eds. Life-span radiation effects studies in animals: What can they tell us? Proceedings 22nd Hanford Life Sciences Symposium, Richland, WA. Oak Ridge, TN: U.S. Department of Energy, 413–428. DE87000490.
Metivier H, Nolibe D, Masse R, 1974. Excretion and acute toxicity of ^239^PuO_2_ in baboons. Health Phys 27:512–514.
Metivier H, Nolibe D, Masse R, 1978b. New data on toxicity and translocation of inhaled ^239^PuO_2_ in baboons. Health Phys 35(2):401–404.100475
Métivier H, Wahrendorf J, Masse R. 1984. Multiplicative effect of inhaled plutonium oxide and benzo(a)pyrene on lung carcinogenesis in rats. Br J Cancer 50(2):215–221.6087866
Metz CF, Waterbury GR. 1962. The transuranium actinide elements. In: Kolthoff I, Elving P, eds. Treatise on analytical chemistry. Part II. Analytical chemistry of the elements. Vol. 9. The transuranium actinide elements. New York, NY: Interscience Publishers, 228–229.
Mewhinney JA, Diel JH. 1983. Retention of inhaled ^238^PuO_2_ in beagles: A mechanistic approach to description. Health Phys 45(1):39–60.6874351
Mewhinney JA, Eidson AF, Wong VA. 1987. Effect of wet and dry cycles on dissolution of relatively insoluble particles containing Pu. Health Phys 53(4):377–384.3654225
Michel H, Gasparro J, Barci-Funel G, 1999. Radioanalytical determination of actinides and fission products in Belarus soils. Talanta 48:821–825.18967524
Michel H, Barci-Funel G, Dalmasso J, 2002. Plutonium and americium inventories in atmospheric fallout and sediment cores from Blelham Tarn, Cumbria (UK). J Environ Radioact 59(2):127–137.11900201
Miller SC, Liu G, Bruenger FW, 2006. Efficacy of orally administered amphipathic polyaminocarboxylic acid chelators for the removal of plutonium and americium: Comparison with injected Zn-DTPA in the rat. Radiat Prot Dosimetry 118(4):412–420.16332916
Mitchell RF. 1960. Electrodeposition of actinide elements at tracer concentrations. Anal Chem 32:326–328.
Mitchell CR, Azizova TV, Hande MP, 2004. Stable intra-chromosomal biomarkers of past exposure to densely ionizing radiation in several chromosomes of exposed individuals. Radiat Res 162:257–263.15378838
Mitchell PI, Vintro LL, Dahlgaard H, 1997. Perturbation in the ^240^Pu/^239^Pu global fallout ratio in local sediments following the nuclear accidents at Thule (Greenland) and Palomares (Spain). Sci Total Environ 202:147–153.9241884
Moores SR, Talbot RJ, Evans N, 1986. Macrophage depletion of mouse lung following inhalation of ^239^PuO_2_. Radiat Res 105(3):387–404.3961100
Morgan A, Haines JW, Harrison JD. 1991. The incorporation of plutonium by the embryo and fetus of rats and guinea-pigs. Int J Radiat Biol 59(6):1395–1413.1677384
Morgan A, Harrison JD, Stather JW. 1992. Estimates of embryonic and fetal doses from ^239^Pu. Health Phys 63(5):552–559.1399641
Morin M, Nenot JC, Lafuma J. 1972. Metabolic and therapeutic study following administration to rats of ^238^Pu nitrate--A comparison with ^239^Pu. Health Phys 23(4):475–480.4634927
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5(6):485–527.
Moss WD, Gautier MA. 1983. Additional short-term plutonium urinary excretion data from the 1945–1947 plutonium injection studies. In: Voelz GL, ed. Occupational Health and Environment Research 1983: Health, Safety and Environment Division. Los Alamos, NM: Los Alamos National Laboratory; Report LA-10365-PR.
Muggenburg BA, Guilmette RA, Hahn FF, 2008. Radiotoxicity of inhaled ^239^PuO_2_ in dogs. Radiat Res 170:736–757.19138039
Muggenburg BA, Guilmette RA, Mewhinney JA, 1996. Toxicity of inhaled plutonium dioxide in beagle dogs. Radiat Res 145(3):361–381.8927705
Muggenburg BA, Hahn FF, Menache MG, 1999. Comparative deterministic effects of inhaled, insoluble alpha- and beta-particle-emitting radionuclides in dogs. Radiat Res 152:S23–S26.10564930
Muggenburg BA, Wolff RK, Mauderly JL, 1988. Cardiopulmonary function of dogs with plutonium-induced chronic lung injury. Radiat Res 115(2):314–324.3406370
Mulsow S, Coquery M, Dovlete C. 1999. Radionuclide concentrations in underground waters of Mururoa and Fangataufa Atolls. Sci Total Environ 237/238:287–300.10568283
*Muramatsu Y, Hamilton T, Uchida S, 2001b. Measurement of ^240^Pu/^239^Pu isotopic ratios in soils from the Marshall Islands using ICP-MS. Sci Total Environ 278(1–3):151–159.11669263
Muramatsu Y, Yoshida S, Tagami K, 2001a. ICP-MS analysis of environmental plutonium. In: Kudo A, ed. Plutonium in the environment. Edited proceedings of the second invited International Symposium November 9–12, 1999, Osakam, Japan. Kidlington, Oxford: Elsevier Science Ltd., 63–77.
Murray RL. 2005. Nuclear reactors. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 17. John Wiley & Sons, Inc., 561–602. http://www.mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/reacmurr.a01/current/pdf. May 22, 2007.
Murray RL, Fentiman AW. 2006. Waste management, radioactive. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 25. John Wiley & Sons, Inc., 850–862. http://www.mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/wastmurr.a01/current/pdf. May 22, 2007.
Mussalo H, Jaakola T, Miettinen JK, 1981. Distribution of plutonium fallout in Southern Finns. Health Phys 39(2):245–255.
Mussalo-Rauhamaa H, Jaakkola T, Miettinen JK, 1984. Plutonium in Finnish Lapps - An estimate of the gastrointestinal absorption of plutonium by m an based on a comparison of the plutonium content of Lapps and southern Finns. Health Phys 46(3):549–559.6698783
Nagasawa H, Little JB. 1992. Induction of sister chromatid exchanges by extremely low doses of alpha-particles. (Comment in: Cancer Res 53:2188). Cancer Res 52(22):6294–6396.
Nagasawa H, Little JB, Inkret WC, 1990b. Cytogenetic effects of extremely low doses of plutonium-238 alpha-particle irradiation in CHO K-1 cells. Mutat Res 244(3):233–238.2366817
Nagasawa H, Robertson J, Little JB. 1990a. Induction of chromosomal aberrations and sister chromatid exchanges by alpha particles in density-inhibited cultures of mouse 10T1/2 and 3T3 cells. Int J Radiat Biol 57:35–44.1967292
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NCRP. 1984. Radiological assessment: Predicting the transport, bioaccumulation, and uptake by man of radionuclides released to the environment. NCRP Report No. 76. Bethesda, MD: National Council on Radiation Protection and Measurements, 73–85, 127–152.
NCRP. 1985. A handbook of radioactivity measurements procedures. 2nd ed. NCRP Report No. 58. Bethesda, MD: National Council on Radiation Protection and Measurements, 247–259.
NCRP. 1987. Ionizing radiation exposure of the population of the United States. Recommendations of the NCRP. NCRP Report No. 93. Bethesda, MD: National Council on Radiation Protection and Measurements, 1–60.
NCRP. 1997. Deposition, retention and dosimetry of inhaled radioactive substances. Bethesda, MD: National Council on Radiation Protection and Measurements, 104–142, 186–188.
NEA/OECD. 1981. The environmental and biological behaviour of plutonium and some other transuranium elements. Paris, France: Nuclear Energy Agency, OECD.
Nelson IC, Thomas VW, Kathren RL. 1993. Plutonium in south-central Washington State autopsy tissue samples-1970–1975. Health Phys 65(4):422–428.8376124
Nenot JC, Stather JW. 1979. The toxicity of plutonium, americium and curium. A report prepared under contract for the Commission of the European Communities within its Research and Development Programme on "Plutonium Recycling in Light Water Reactors." New York: Pergammon Press, 1–9.
Nenot J, Masse R, Morin M, 1972. An experimental comparative study of the behaviour of ^237^Np, ^238^Pu, ^239^Pu, ^241^Am and ^242^Cm in bone. Health Phys 22(6):657–665.5083996
Nero A. 1979. Instrumentation for monitoring plutonium in the environment. Nuclear Safety 20:280–290.
Newman LS, Mroz MM, Ruttenber AJ. 2005. Lung fibrosis in plutonium workers. Radiat Res 164(2):123–131.16038583
Newton D, Talbot RJ, Kang C, 1998. Uptake of plutonium by the human liver. Radiat Prot Dosimetry 80(4):385–395.
Nielson JM, Beasley TM. 1980. Radiochemical determination of plutonium for radiological purposes. In: Wick O, ed. Plutonium handbook: A guide to the technology. Vol. 2. La Grange Park, IL: The American Nuclear Society, 921–933.
Nikitin AI, Chumichev VB, Valetova NK, 2007. The current content of artifical radionuclides in the water of the Tobol-Irtysh river system (from the mouth of the Iset River to the confluence with the Ob River) J Environ Radioact 96:138–143.17428590
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press. National Research Council.
NRPB. 2002. Industrial uranium compounds: Exposure limits, assessment of intake and toxicity after inhalation. Chilton: National Radiological Protection Board. NRPB-W22.
NTP. 2005. Ionizing radiation. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program. U.S. Department of Health and Human Services. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. May 11, 2007.
O'Donnell RG, Mitchell PI, Priest ND, 1997. Variations in the concentration of plutonium, strontium-90 and total alpha-emitters in human teeth collected within the British Isles. Sci Total Environ 201(3):235–243.9241873
Oghiso Y, Yamada Y. 2000a. Pathogenetic process of lung tumors induced by inhalation exposure of rats to plutonium dioxide aerosols. Radiat Res 154:253–260.10956430
*Oghiso Y, Yamada Y. 2000b. Strain differences in carcinogenic and hematopoietic responses of mice after injection of plutonium citrate. Radiat Res 154(4):447–454.11023609
Oghiso Y, Yamada Y. 2003a. Comparisons of pulmonary carcinogenesis in rats following inhalation exposure to plutonium dioxide or x-ray irradiation. J Radiat Res (Tokyo) 44(3):261–270.14646231
*Oghiso Y, Yamada Y. 2003b. The specific induction of osteosarcomas in different mouse strains after injections of ^239^Pu citrate. J Radiat Res (Tokyo) 44(2):125–132.13678341
Oghiso Y, Yamada Y, Iida H. 1994a. Differential induction of bone and hematopoietic tumors in C3H mice after the injection of ^239^Pu citrate. J Radiat Res (Tokyo) 35(4):236–247.7752107
Oghiso Y, Yamada Y, Iida H, 1998. Differential dose responses of pulmonary tumor types in the rat after inhalation of plutonium dioxide aerosols. J Radiat Res (Tokyo) 39(1):61–72.9610033
*Oghiso Y, Yamada Y, Ishigure N, 1994b. High incidence of malignant lung carcinomas in rats after inhalation of ^239^PuO_2_ aerosol. J Radiat Res (Tokyo) 35(4):222–235.7752106
Oikawa S, Yamamoto M. 2007. Plutonium concentration and 240Pu/239Pu atomic ratio in liver of squid collected in the coastal sea areas of Japan. J Environ Radioact 93:170–180.17270324
Okladnikova ND, Scott BR, Tokarskaya ZB, 2005. Chromosomal aberrations in lymphocytes of peripheral blood among Mayak facility workers who inhaled insoluble forms of ^239^Pu. Radiat Prot Dosimetry 113(1):3–13.15585521
Omar RZ, Barber JA, Smith PG. 1999. Cancer mortality and morbidity among plutonium workers at the Sellafield plant of British nuclear fuels. (Erratum in: Br J Cancer 79(11–12):1946). Br J Cancer 79(7–8):1288–1301.10098774
OSHA. 2006. Ionizing radiation. Toxic and hazardous substances. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1096. http://www.osha.gov/comp-links.html. May 11, 2007.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Paquet F, Poncy J-L, Ham GJ, 1998. Transfer of polonium, neptunium, plutonium and americium to the primate fetus. Radiat Prot Dosimetry 79(1–4):303–306.
Park JF, Bair WJ, Busch RH. 1972. Progress in beagle dog studies with transuranium elements at Battelle-Northwest. Health Phys 22(6):803–810.5084014
Park JF, Buschbom RL, Dagle GE, 1995. Inhaled plutonium in dogs. In: DOE, ed. Pacific Northwest Laboratory annual report for 1994 to the DOE Office of Energy Research. Washington, DC: U.S. Department of Energy. PNL10500 Pt. 1. UC-408
Park JF, Buschbom RL, Dagle GE, 1997. Biological effects of inhaled ^238^PuO_2_ in beagles. Radiat Res 148:365–381.9339953
Pesce AM, First MR. 1979. Proteins in urine. In: Proteinuria. An integrated review. New York, NY: Marcel Dekker, 54–79.
Phan G, Le Gall B, Grillon G, 2006b. Enhanced decorporation of plutonium by DTPA encapsulated in small PEG-coated liposomes. Biochimie 88:1843–1849.16860919
Phan G, Ramounet-Le Gall B, Manceau J, 2004. Targeting of diethylene triamine pentaacetic acid encapsulated in liposomes to rat liver: An effective strategy to prevent bone deposition and increase urine elimination of plutonium in rats. Int J Radiat Biol 80(6):413–422.15362694
Pietrzak-Flis Z, Orzechowska G. 1993. Plutonium in daily diet in Poland after the Chernobyl accident. Health Phys 65(5):489–492.8225984
Pinder JE, Adriano DC, Ciravolo TG, 1987. The interception and retention of ^238^Pu deposition by orange trees. Health Phys 52(6):707–715.3583736
Polig E. 1989. Kinetic model of the distribution of ^239^Pu in the beagle skeleton. Health Phys 57(3):449–460.2777550
Polig E, Bruenger FW, Lloyd RD, 2000. Biokinetics and dosimetric model of plutonium in the dog. Health Phys 78(2):182–190.10647984
Pomerantseva MD, Ramaya LK, Shevchenko VA, 1989. Evaluation of the genetic effects of ^238^Pu incorporated into mice. Mutat Res 226(2):93–98.2733722
Popplewell DS, Ham GJ. 1989. Distribution of plutonium and americium in tissues from a human autopsy case. J Radiol Prot 9(3):159–164.
Popplewell DS, Ham GJ, Dodd NJ, 1988. Plutonium and Cs-137 in autopsy tissues in Great Britain. Sci Total Environ 70:321–334.3363334
Popplewell DS, Ham GJ, Johnson TE, 1985. Plutonium in autopsy tissues in Great Britain. Health Phys 49(2):304–309.4019203
Popplewell DS, Ham GJ, McCarthy W, 1994. Transfer of plutonium across the human gut and its urinary excretion. Radiat Prot Dosimetry 53(1–4):241–244.
Priest ND. 1990. The distribution and behaviour in metals in the skeleton and body: Studies with radionuclides. In: Priest ND, Van De Vyver F, eds. Trace metals and fluoride in bones and teeth. Boca Raton, FL: CRC Press, 87–139.
Priest ND, Pich GM, Fifield LK, 1999. Accelerator mass spectrometry for the detection of ultra-low levels of plutonium in urine, including that excreted after the ingestion of Irish Sea sediments. Radiat Res 152:S16–S18.10564928
Prise KM, Davies S, Michael BD. 1987. The relationship between radiation-induced DNA double-strand breaks and cell kill in hamster V79 fibroblasts irradiated with 250 kVp X-rays, 2.3 MeV neutrons or ^238^Pu α-particles. Int J Radiat Biol 52(6):893–902.
Prosser SL, McCarthy W, Lands C. 1994. The plutonium content of human fetal tissue and implications for fetal dose. Radiat Prot Dosimetry 55(1):49–55.
Purrott RJ, Edwards AA, Lloyd DC, 1980. The induction of chromosome aberrations in human lymphocytes by in vitro irradiation with alpha-particles from plutonium-239. Int J Radiat Biol 38(3):277–284.
Ragan HA, Park JF, Olson RJ, 1976. Lymphocytopenia induced in beagle dogs by inhalation of 239Pu02. In: Radiation and the lymphatic system: Proceedings of the Fourteenth Annual Hanford Biology Symposium at Richland, Washington, September 30-October 2, 1974. Washington, DC: U.S. Atomic Energy Commission, Division of Biomedical and Environmental Research. CONF-740930, 100–105.
Rahman YE, Rosenthal YE, Cierny EA. 1973. Intracellular plutonium: Removal by liposome encapsulated chelating agents. Science 180:300–302.4633691
Ramounet-Le Gall B, Grillon G, Rateau G, 2003. Comparative decorporation efficacy of 3,4,3-LIHOPO, 4,4,4-LIHOPO and DTPA after contamination of rats with soluble forms of ^238^Pu and ^233^U. Radiat Prot Dosimetry 105(1–4):535–538.14527023
Rapiejko A, Rosson R, Lahr J, 2001. Radionuclides in Peconic River fish, mussels, and sediments. Health Phys 81(6):698–703.11725889
REAC/TS. 2010a. Package insert-instructions for use: Pantetate calcium trisodium injection. Radiation Emergency Assistance Center/Training Site. Oak Ridge Institute for Science and Education. U.S. Department of Energy. http://orise.orau.gov/files/reacts/Calcium-DTPA-package-insert.pdf. May 22, 2010.
REAC/TS. 2010b. Package insert-instructions for use: Pantetate zinc trisodium injection. Radiation Emergency Assistance Center/Training Site. Oak Ridge Institute for Science and Education. U.S. Department of Energy. http://orise.orau.gov/files/reacts/Zinc-DTPA-package-insert.pdf. May 22, 2010.
Robertson JB, Raju MR. 1980. Sudden reversion to normal radiosensitivity to the effects of x-irradiation and plutonium-238 alpha particles by a radioresistant rat-mouse hybrid cell line. Radiat Res 83(1):197–204.7394165
Romanov SA, Guilmette RA, Hahn FF, 2003. Modifying the ICRP 66 dosimetry m odel based on results obtained from Mayak plutonium workers. Radiat Prot Dosimetry 105(1–4):85–90.14526933
Rosenthal MW, Lindenbaum A, Russell JJ, 1972a. Metabolism of monomeric and polymeric plutonium in the rabbit; comparison with the mouse. Health Phys 23:231–238.4644589
Rosenthal MW, Moretti E, Russell JJ, 1972b. Marrow deposition and distribution of monomeric and polymeric ^239^Pu in the mouse, estimated by use of ^59^Fe. Health Phys 22:743–748.5084004
Rosenthal MW, Rahman YE, Moretti ES, 1975. Removal of polymeric plutonium by DTPA directed into cells by liposome encapsulation. Radiat Res 63:262–274.1144691
Rubio Montero P, Martin Sanchez A. 2001. Plutonium contamination from accidental release or simply fallout: study of soils at Palomares (Spain) J Environ Radioact 55:157–165.11398375
Rundo J, Starzyk PM, Sedlet J, 1976. The excretion rate and retention of plutonium 10,000 days after acquistion. Diagnosis and treatment of incorporated radionuclides. Viema, Austriz: International Atomic Energy, 15–23.
Russell JJ, Sikov MR, Kathren RL. 2003. Plutonium content of human placental tissues after occupational exposure. Radiat Prot Dosimetry 104(3):231–236.14565729
Sanchez AL, Walters CB, Singleton DL, 1999. Food ingestion doses from artificial radionuclides in Cumbrian diets, ten years post-Chernobyl. J Environ Radioact 46(3):301–317.
Sanders C. 1973. Carcinogenicity of inhaled plutonium-238 in the rat. Radiat Res 56:540–553.4358363
*Sanders CL. 1975a. Effects of PuO_2_ particles deposited in the lung following intraperitoneal injection. Health Phys 28(1):84–86.1110174
Sanders CL. 1975b. Dose distribution and neoplasia in the lung following intratracheal instillation of ^239^PuO_2_ and asbestos. Health Phys 28(4):383–386.1120670
Sanders CL. 1977. Inhalation toxicology of ^238^PuO_2_ and ^239^PuO_2_ in Syrian golden hamsters. Radiat Res 70(2):334–344.860009
Sanders CL, Lundgren DL. 1995. Pulmonary carcinogenesis in the F344 and Wistar rat after inhalation of plutonium dioxide. Radiat Res 144(2):206–214.7480647
Sanders CL, Mahaffey JA. 1979. Carcinogenicity of inhaled air-oxidized plutonium-239 dioxide in rats. Int J Radiat Biol Relat Stud Phys Chem Med 35(1):95–98.312780
Sanders CL, Mahaffey JA. 1983. Action of vitamin C on pulmonary carcinogenesis from inhaled ^239^PuO_2_. Health Phys 45(3):794–798.6885492
Sanders CL, Cannon WC, Powers GJ. 1978. Lung carcinogenesis induced by inhaled high-fired oxides of beryllium and plutonium. Health Phys 35(2):193–199.701015
Sanders CL, Dagle GE, Cannon WC, 1976. Inhalation carcinogenesis of high-fired ^239^PuO_2_ in rats. Radiat Res 68(2):349–360.988604
Sanders CL, Dagle GE, Cannon WC, 1977. Inhalation carcinogenesis of high-fired ^238^PuO_2_ in rats. Radiat Res 71(3):528–546.897081
*Sanders CL, Lauhala KE, McDonald KE, 1993a. Lifespan studies in rats exposed to ^239^PuO_2_ aerosol. (Erratum in: Health Phys 65(5):576). Health Phys 64(5):509–521.8491602
Sanders CL, Lauhala KE, McDonald KE. 1993b. Lifespan studies in rats exposed to ^239^PuO_2_ aerosol. III. Survival and lung tumours. Int J Radiat Biol 64(4):417–430.7901303
Sanders CL, McDonald KE, Lauhala KE. 1988a. Promotion of pulmonary carcinogenesis by plutonium particle aggregation following inhalation of ^239^PuO_2_. Radiat Res 116(3):393–405.2974596
Sanders CL, McDonald KE, Mahaffey JA. 1988b. Lung tumor response to inhaled Pu and its implications for radiation protection. Health Phys 55(2):455–462.3410719
Sato H, Takahashi S, Kubota Y. 2001. Effects of gadoinium on the retention and translocation of ^239^Pu-hydroxide. Health Phys 80(2):164–169.11197465
Schofield GB. 1980. Biological control in a plutonium production facility. Br J Radiol 53(629):398–409.7388271
Schofield G, Howells H, Ward F, 1974. Assessment and management of a plutonium contaminated wound case. Health Phys 26:541–554.4836700
Searle A, Beechey C, Green D, 1976. Cytogenetic effects of protracted exposures to alpha-particles from plutonium-239 and to gamma-rays from cobalt-60 compared in male mice. Mutat Res 41:297–310.1012301
Searle A, Beechey C, Green D, 1982. Dominant lethal and ovarian effects of plutonium-239 in female mice. Int J Radiat Biol 42:235–244.
Sérandour AL, Tsapis N, Gervelas C, 2007. Decorporation of plutonium by pulmonary administration of Ca-DTPA dry powder: A study in rat after lung contamination with different plutonium forms. Radiat Prot Dosimetry 127(1–4):472–476.17562654
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shilnikova NS, Preston E, Ron ES, 2003. Cancer mortality risk among workers at the Mayak Nuclear Complex. Radiat Res 159:787–798.12751962
Sill C. 1975. Some problems in measuring plutonium in the environment. In: Healy J, ed. Plutonium - health implications for man. New York, NY: Pergammon Press, 619–626.
Sill CW, Williams RL. 1981. Preparation of actinides for α spectrometry without electrodeposition. Anal Chem 53:412–415.
Singh NP, Wrenn ME. 1983. Plutonium concentration in human tissues: Comparison to thorium. Health Phys 44:469–476.
Singh NP, Wrenn ME. 1988. Determinations of actinides in biological and environmental samples. Sci Total Environ 70:187–204.2834820
Singh IS, Sharma RC, Abani MC. 2003. A computational study of the urinary excretion rates for 239Pu using new ICRP internal dosimetry models. Radiat Prot Dosimetry 105(1–4):361–364.14526987
Skipperud L, Brown J, Fifield LK, 2009. Association of plutonium with sediments fromthe Ob and Yenisey rivers and estuaries. J Environ Radioact 100:290–300.19157655
Smith B, Amonette A. 2006. The environmental transport of radium and plutonium: A review. Institute for Energy and Environmental Research.
Smith PG, Douglas AJ. 1986. Mortality of workers at the Sellafield plant of British nuclear fuels. Br Med J 293(6551):845–854.3094683
Sokolnikov ME, Gilbert ES, Preston DL, 2008. Lung, liver and bone cancer mortality in Mayak workers. Int J Cancer 123:905–911.18528867
Stanley JA, Edison AF, Mewhinney JA. 1982. Distribution, retention, and dosimetry of plutonium and americium in the rat, dog, and monkey after inhalation of an industrial-mixed uranium and plutonium oxide aerosol. Health Phys 43(4):521–530.7152912
Stevens W, Bruenger FW, Stover BJ. 1968. In vivo studies on the interaction of PuIV with blood constituents. Radiat Res 33(3):490–500.5640789
Stover BJ, Atherton DR, Keller N. 1959. Metabolism of Pu239 in adult beagle dogs. Radiat Res 10(2):130–147.13645924
Stover BJ, Bruenger FW, Stevens W. 1968a. The reaction of Pu(IV) with the iron transport system in human blood serum. Radiat Res 33(2):381–394.5637301
Stradling GN, Henge-Napoli M-H, Paquet F, 2000a. Approaches for experimental evaluation of chelating agents. Radiat Prot Dosimetry 87(1):19–27.
Stradling GN, Henge-Napoli M-H, Paquet F, 2000b. Optimum treatment regimes with animals. Radiat Prot Dosimetry 87(1):29–40.
Stroud AN. 1977. Chromosome aberrations induced in Syrian hamster lung cells by inhaled ^238^PuO_2_-ZrO_2_ particles. Radiat Res 69(3):583–590.847105
Struminska DI, Skwarzec B. 2004. Plutonium concentrations in waters from the southern Baltic Sea and their distribution in cod (Gadus morhua) skin and gills. J Environ Radioact 72(3):355–361.14972415
Sullivan MF. 1980a. Absorption of actinide elements from the gastrointestinal tract of rats, guinea pigs and dogs. Health Phys 38:159–171.6246038
Sullivan MF. 1980b. Absorption of actinide elements from the gastrointestinal tract of neonatal animals. Health Phys 38:173–185.6246039
Sullivan MF, Gorham LS. 1983. Can information on the gastrointestinal absorption of actinide elements by neonatal rats, guine pigs, dogs and swine be extrapolated to man? Health Phys 44:411–417.
Sullivan MF, Ruemmler PS. 1988. Absorption of ^233^U, ^237^Np, ^238^Pu, ^241^Am and ^244^Cm from the gastrointestinal tracts of rats fed an iron-deficient diet. Health Phys 54(3):311–316.3346162
Sullivan MF, Garland TR, Cataldo DA, 1980. Absorption of plutonium from the gastrointestinal tract of rats and guinea pigs after ingestion of alfalfa containing ^238^Pu. Health Phys 38(2):215–221.7372486
Sullivan MF, Hackett PL, George LA, 1960. Irradiation of the intestine by radioisotopes. Radiat Res 13:343–355.13835647
Sullivan MF, Miller BM, Ruemmler PS, 1985. Further studies on the influence of chemical form and dose on absorptions of Np, Pu, Am and Cm from the gastrointestinal tracts of adult and neonatal rodents. Health Phys 48(1):61–73.2981787
Sullivan MF, Reummler PS, Buschbom RL. 1986. Influence of iron on plutonium absorption by the adult and neonatal rat. Toxicol Appl Pharmacol 85(2):239–247.3764911
Sun LC, Meinhold CB. 1997. Gastrointestinal absorption of plutonium by the Marshall islanders. Health Phys 73(1):167–175.9199226
Suslova KG, Khokhryakov V F, Sokolova AB. 2007. Plutonium in the Ozyorsk population. Radiat Prot Dosimetry 127(1–4):502–506.17545660
Suslova KG, Khokhryakov VF, Tokarskaya ZB, 2002. Extrapulmonary organ distribution of plutonium in healthy workers exposed by chronic inhalation at the Mayak Production Assaociation. Health Phys 82(4):432–444.11906132
Suslova KG, Khokhryakov V F, Tokarskaya ZB, 2003. The effect of state of health on organ distribution and excretion of systemic plutonium in the Mayak workers. Radiat Prot Dosimetry 105(1–4):229–233.14526961
Suslova KG, Khokhryakov VF, T okarskaya ZB, 2006. Modifying effects of health status, physiological, and dosimetric factors on extrapulmonary organ distribution and excretion of inhaled plutonium in workers at the Mayak Production Association. Health Phys 90(4):299–311.16538136
Suzuki K, Sekimoto H, Ishigure N. 2002. Effect of uncertainty in transfer rates for the ICRP publication 67 biokinetic model on dose estimation for ^239^Pu from results of individual monitoring. Radiat Prot Dosimetry 102(4):383–341.
Svoboda V, Sedlak A, Kypenova H, 1987. Long-term effects of low-level ^239^Pu contamination on murine bone-marrow stem cells and their progeny. Int J Radiat Biol 52(4):517–526.
Swift DJ. 1992. The accumulation of plutonium by the European lobster (Homarus gammarus L.). J Environ Radioact 16(1):1–24.
Takizawa Y. 1982. Plutonium in Japanese tissues. J Radiat Res (Tokyo) 23(2):198–203.7131382
Talbot RJ, Moores SR, Morgan A, 1986. The induction of micronuclei in mouse pulmonary alveolar macrophages by inhaled alpha-emitting ^239^PuO_2_. Br J Cancer 53:340–342.
Talbot RJ, Morgan A, Moores SR, 1987. Preliminary studies of the interaction between ^239^PuO_2_ and cigarette smoke in the mouse lung. Int J Radiat Biol 51(6):1101–1110.
Talbot RJ, Newton D, Dmitriev SN. 1997. Sex-related differences in the human metabolism of plutonium. Radiat Prot Dosimetry 71(2):107–121.
Talbot RJ, Newton D, Warner AJ. 1993. Metabolism of injected plutonium in two healthy men. Health Phys 65(1):41–46.8505229
Talbot RJ, Nicholls L, Morgan A, 1989. Effect of inhaled alpha-emitting nuclides on mouse alveolar macrophages. Radiat Res 119:271–285.2756118
Talvitie NA. 1972. Electrodeposition of actinides for alpha spectrometric determination. Anal Chem 44(2):280–283.
Tawn EJ, Hall JW, Schofield GB. 1985. Chromosome studies in plutonium workers. Int J Radiat Biol 47(5):599–610.
Taylor DM. 1973. Chemical and physical properties of plutonium. In: Hodge H, Stannard JN, Hursh JB, eds. Uranium, plutonium. Transplutonic elements. New York, NY: Springer-Verlag, 323–347.
Taylor DM. 1977. The uptake, retention and distribution of plutonium-239 in rat gonads. Health Phys 32(1):29–31.838586
Taylor GN, Lloyd RD, Mays CW, 1991. Plutonium- or americium-induced liver tumors and lesions in beagles. Health Phys 61(3):337–347.1880023
Thacker J, Stretch A, Goodhead DT. 1982. The mutagenicity of α particles from plutonium-238. Radiat Res 92(2):343–352.7163484
Thannoo DR, Paquet F. 1996. Early ultrastructural alterations in rats after administration of ^239^Pu-citrate. Cell Mol Biol 42(3):431–438.8793196
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Tokarskaya ZB, Zhuntova GV, Scott BR, 2006. Influence of alpha and gamma radiations and non-radiation risk factors on the incidence of malignant liver tumors among Mayak PA workers. Health Phys 91(4):296–310.16966873
Toohey RE, Bhattacharyya MH, Oldham RD, 1984. Retention of plutonium in the beagle after gastrointestinal absorption. Radiat Res 97(2):373–379.6695054
Turner GA, Taylor DM. 1968. The binding of plutonium to serum proteins in vitro. Radiat Res 36(1):22–30.17387923
UNSCEAR. 2000a. Annex C: Exposures to the public from man-made sources of radiation. United Nations Scientific Committee on the Effects of Atomic Radiation. http://www.unscear.org/docs/reports/annexc.pdf. August 17, 2007.
UNSCEAR. 2000b. Annex J: Exposures and effects of the Chernobyl accident. United Nations Scientific Committee on the Effects of Atomic Radiation. http://www.unscear.org/docs/reports/annexj.pdf. August 10, 2007.
USNRC. 1985. ^238^Pu(IV) in monkeys: Overview of metabolism. NUREGICR-4355. Vol. 1. Washington DC: U.S. Nuclear Regulatory Commission. LBL-20022.
USNRC. 1992. Gastrointestinal absorption of plutonium, uranium and neptunium in fed and fasted adult baboons: Application to humans. Washington, DC: U.S. Nuclear Regulatory Commission. NUREGCR5842.
USNRC. 2007a. Annual limits on intake (ALI) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. U.S. Nuclear Regulatory Commission. Code of Federal Regulations. 10 CFR 20, App. B. http://www.nrc.gov/reading-rm/doc-collections/cfr/. May 10, 2007.
USNRC. 2008. Storage of spent nuclear fuel. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/waste/spent-fuel-storage.html. March 10, 2009.
USNRC. 2009a. Standards for protection against radiation. Code of Federal Regulations. 10 CFR 20. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/reading-rm/doc-collections/cfr/part020/full-text.html. March 10, 2009.
USNRC. 2009b. Export-import. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/aboutnrc/ip/export-import.html. March 10, 2009.
USNRC. 2009c. Locations of independent fuel storage installations. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/waste/spent-fuel-storage/locations.html. March 10, 2009.
USTUR. 1993. Annual Report of the United States Transuranium and Uranium Registries. United States Transuranium and Uranium Registries. http://nsdl.org/resource/2200/20061005071626266T. March 11, 2009.
USTUR. 2001. United States Transuranium and Uranium Registries radiochemical analysis procedures manual. United States Transuranium and Uranium Registries. http://www.ustur.wsu.edu/Publications/Files_Abstracts/Abstracts03/USTUR-193-03.pdf. March 10, 2009.
USTUR. 2003. National human radiobiology tissue repository. Richland, WA: U.S. Transuranium and Uranium Registries. USTUR-0193–03. http://www.tricity.wsu.edu/ustur/publications/NHRTRREV03.pdf. May 23, 2007.
Valislenko EK, Khokhryakov VF, Miller SC, 2007. Mayak worker dosimetry study: An overview. Health Phys 93(3):190–206.17693770
Varga B, Tarjan S. 2008. Determination of 241Pu in the environmental samples. Appl Radiat Isot 66:265–270.17988880
Varga Z, Surányi G, Vajda N, 2007. Determination of plutonium and americium in environmental samples by inductively coupled plasma sector field mass spectrometry and alpha spectrometry. Microchem J 85(1):39–45.
Vaughan J, Bleaney B, Taylor DM. 1973. Distribution, excretion, and effects of plutonium as a bone seeker. In: Hodge HC, Stannard JN, Hursh JB, eds. Uranium, plutonium. Transplutonic elements. New York, NY: Springer-Verlag, 349–502.
Viccellio P, Bania T, Brent J, , eds. 1998. Ionizing radiation. Emergency toxicology. 2nd ed. Philadelphia, PA: Lippincott-Raven Publishers, 991–996.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Voelz GL, Lawrence JN. 1991. A 42-y medical follow-up of Manhattan Project plutonium workers. Health Phys 6(12):181–190.
Voelz GL, Grier RS, Hempelmann LH. 1985. A 37-year medical follow-up of Manhattan project Pu workers. Health Phys 48(3):249–259.3980212
Voelz GL, Hempelmann LH, Lawrence JN, 1979. A 32-year medical follow-up of Manhattan project plutonium workers. Health Phys 37(4):445–485.536211
Voelz GL, Lawrence JN, Johnson ER. 1997. Fifty years of plutonium exposure to the Manhattan Project plutonium workers: An update. Health Phys 73(4):611–619.9314220
Volf V. 1980. Influence of cadmium and copper on the distribution pattern of plutonium in the rat. J Toxicol Environ Health 6(3):493–501.7420459
Volf V, Luz A, Scaffer E, 1999. Effect of oral ZnDTPA on late effects of injected plutonium in rat. Int J Radiat Biol 75(8):929–941.10465359
Wang RY, Chiang WK. 1998. Radiation poisoning. In: Haddad LM, Shannon MW, Winchester JF, eds. Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA: W.B. Sanders Company, 413–425.
Warner AJ, Talbot RJ, Newton D. 1994. Deposition of plutonium in human testes. Radiat Prot Dosimetry 55(1):61–63.
Weiss JF, Walburg HE. 1978. Influence of the mass of administered plutonium on its cross-placental transfer in mice. Health Phys 35:773–777.738881
Weller RE, Buschbom RL, Dagle GE, 1995a. Hepatic effects of inhaled plutonium dioxide in beagles. Radiat Res 144(1):73–81.7568774
Weller RE, Buschbom RL, Park JF, 1995b. Hematological effects of inhaled plutonium dioxide in beagles. Radiat Res 143(1):69–76.7597146
Welleweerd J, Wilder ME, Carpenter SG, 1984. Flow cytometric determination of radiation-induced chromosome damage and its correlation with cell survival. Radiat Res 99(1):44–51.6739726
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Whitehouse CA, Tawn EJ, Riddell AE. 1998. Chromosome aberrations in radiation workers with internal deposits of plutonium. Radiat Res 150(4):459–468.9768861
WHO. 1983. Environmental health criteria 25: Selected radionuclides. Geneva: World Health Organization, 169–229.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. March 08, 2006.
WHO. 2004. Guidelines for drinking-water quality. Volume 1. Recommendations. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Vol. II: The elements Part A. New York: Academic Press, 1–247.
Wiggs LD, Johnson ER, Cox-DeVore CA, 1994. Mortality through 1990 among white male workers at the Los Alamos national laboratory: Considering exposures to plutonium and external ionizing radiation. Health Phys 67(6):577–588.7960779
Wing S, Richardson DB. 2005. Age at exposure to ionising radiation and cancer mortality among Hanford workers: Follow up through 1994. Occup Environ Med 62:465–472.15961623
Wing S, Richardson D, Wolf S, 2004. Plutonium-related work and case-specific mortality at the United States Department of Energy Hanford Site. Am J Ind Med 45(2):153–164.14748046
Wolf SF. 2006. Trace analysis of actinides in geological, environmental, and biological matrices. In: Morss LR, Edelstein NM, Fuger J, eds. The chemistry of the actinide and transactinide elements. Vol. 5. 3rd ed. Dordrecht, The Netherlands: Springer, 3273–3338.
Wood R, Sharp C, Gourmelon P, 2000. Decorporation treatment-medical overview. Radiat Prot Dosimetry 87(1):51–57.
Woodhouse JA, Shaw IC. 1998. Identification of plutonium retention parameters in humans via pharmacokinetic analysis of occupational plutonium urinary excretion data. Radiat Prot Dosimetry 79(1–4):95–98.
Wrenn ME, Cohen N. 1977. Determination of Pu-239, 240 tissue concentrations in nonoccupationally exposed residents of New York City. New York, NY: New York University Medical Center, Institute of Environmental Medicine. COO-2968–1.
Yamada M, Zheng J. 2008. Determination of 240Pu /239Pu atom ratio in coastal surface seawaters from the western North Pacific Ocean and Japan Sea. Appl Radiat Isot 66:103–107.17870557
Yamada M, Zheng J, Wang Z. 2007. 240Pu/239Pu atom ratios in searwater from Sagami Bay, western Northwest Pacific Ocean: sources and scavenging. J Environ Radioact 98:274–284.17618019
Yamamoto M, Oikawa S, Sakaguchi A, 2008b. Determination of the ^240^Pu/^239^Pu isotopic ratios in human tissues collected from areas around the Semilapatinsk Nuclear Test Site by sector-field high-resolution ICP-MS. Heath Phys 95(3):291–299.
Yamamoto M, Tomita J, Sakaguchi A, 2008b. Spatial distribution of soil contamination by 137Cs and 239,240Pu in the village of Dolon near the Semipalatinsk Nuclear Test Site: New information on traces of the radioactive plume from the 29 August 1949 nuclear test. Health Phys 94(4):328–337.18332724
Yoshida S, Muramatsu Y, Yamazaki S, 2007. Distribution of nuclear bomb Pu in Nishiyama area, Nagasaki, estimated by accurate and precise determination of 240Pu/239Pu ratio in soils. J Environ Radioact 96:85–93.17420076
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372