# PEER REVIEW

A peer review panel was assembled for plutonium. The panel consisted of the following members:

1. Lynn Anspaugh, Ph.D., Research Professor, Department of Radiology, Radiobiology Division, University of Utah, Salt Lake City, Utah;
2. Fletcher Hahn, D.V.M., Ph.D., Scientist Emeritus, Lovelace Respiratory Research Institute, Albuquerque, New Mexico;
3. Richard Leggett, Ph.D., Research Scientist, Life Sciences Division, Oak Ridge National Laboratory, Oak Ridge, Tennessee;
4. Nicholas Priest, Ph.D., Head, Radiobiology Section, AECL Chalk River Laboratory, Chalk River, Ontario, Canada; and
5. Ethel Gilbert, Ph.D., M.P.H., Expert (biostatistician), Radiation Epidemiology Branch, Division of Cancer Epidemiology and Genetics, National Cancer Institute, Bethesda, Maryland.

These experts collectively have knowledge of plutonium’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers' comments and determined which comments will be included in the profile. A listing of the peer reviewers' comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile's final content. The responsibility for the content of this profile lies with the ATSDR.