# 4 CHEMICAL, PHYSICAL, AND RADIOLOGICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of plutonium and selected plutonium compounds is located in Table 4-1.

## 4.2 PHYSICAL, CHEMICAL, AND RADIOLOGICAL PROPERTIES

Information regarding the physical and chemical properties of plutonium and selected plutonium compounds is located in Table 4-2. Information regarding the radiological properties of selected plutonium isotopes is located in Table 4-3. The decay schemes for ^239^Pu and ^241^Pu are summarized in Figures 4-1 and 4-2, respectively.

Plutonium is a member of the actinide series and is a human-made element (atomic number 94). Actinides are the 15 elements starting with actinium, atomic number 89, and extending to lawrencium, atomic number 103. All of the isotopes of the actinide elements are radioactive. Plutonium was the first human-made element to be synthesized in weighable amounts. ^238^Pu was discovered in 1940 by Seaborg and co-workers; it was synthesized by the bombardment of uranium with deuterons (^2^H). Isotopes with mass numbers 228–247 have been identified for plutonium; all are radioactive. The most important isotope is ^239^Pu, which has a half-life that is sufficiently long (24,100 years) to permit its preparation in large amounts, making it possible to perform chemical studies. Metallic plutonium exists in six allotropic modifications under ordinary pressure; a seventh phase exists under high pressure. Five oxidation states, Pu(III), Pu(IV), Pu(V), Pu(VI), and Pu(VII), are known to exist in compounds and solution (Clark et al. 2006). Plutonium(III) and plutonium(IV) are considered to be the reduced forms of plutonium, while plutonium(V) and plutonium(VI) are the oxidized forms (DOE 1987a). While the atomic mass of plutonium depends on the isotope, 244 is frequently listed as the mass of plutonium on periodic tables. ^244^Pu is the isotope with the longest half-life.

Table 4-1 Chemical Identity of Plutonium and Selected Plutonium Compounds

Characteristic | | Information^a^
Chemical name | Plutonium | | Plutonium(IV) dioxide | Plutonium nitride
Synonym(s) | No data | | Plutonium dioxide | No data
Registered trade name(s) | No data | | No data | No data
Chemical formula | Pu | | PuO_2_ | PuN
Identification numbers:
CAS registry | 7440-07-5^b^ | | 12059-95-9 | 12033-54-4
NIOSH RTECS | No data | | No data | No data
EPA hazardous waste | No data | | No data | No data
OHM/TADS | No data | | No data | No data
DOT/UN/NA/IMDG shipping | No data | | No data | No data
EINECS | 231-117-7 | | 235-037-3 | No data
HSDB | 6465 | | No data | No data
NCI | No data | | No data | No data
Chemical name | Plutonium nitrate | Plutonium(VI) fluoride | Plutonium(IV) Oxalate^c^ | Plutonium(IV) fluoride
Synonym(s) | Nitric acid, plutonium(4+) salt | Plutonium hexafluoride | No data | Plutonium tetrafluoride
Registered trade name(s) | No data | No data | No data | No data
Chemical formula | Pu(NO_3_)_4_ | PuF_6_ | Pu(C_4_O_8_)_2_ | PuF_4_
Identification numbers:
CAS registry | 13823-27-3 | 13693-06-6 | 14448-76-1^c^ 13278-81-4^d^ | 13709-56-3
NIOSH RTECS | No data | No data | No data | No data
EPA hazardous waste | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data | No data
EINECS | 238-979-3^e^ | No data | No data | No data
HSDB | No data | No data | No data | No data
NCI | No data | No data | No data | No data

a All information obtained from ChemIDplus 2009, Lide 2008, and HSDB 2009 except where noted

b This is the generic CAS Registry Number for plutonium (unspecified form). Each isotope has an individual CAS Registry Number (Table 4-3)

c ChemBioFinder 2009

d Clark et al. 2006

e This EINCES number refers to plutonium nitrate (CAS Registry No. 14913-29-2) with a chemical formula of Pu(NO_3_)_x_. (ChemIDplus 2009)

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Chemical Substances EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Plutonium and Selected Plutonium Compounds

Property | Information^a^
Chemical name | Plutonium | | Plutonium dioxide | Plutonium nitride
Molecular weight^b^ | 244 | | 276 | 258
Physical description | Silver, white metal Six allotropic modifications under ordinary pressure^c^ | | Yellow-brown cubic crystals | Gray cubic crystals
Melting point | 640 °C | | 2,390 °C | 2,550 °C
Boiling point | 3,228 °C | | No data | No data
Density | 19.7 g/cm^3^ | | 11.5 g/cm^3^ | 14.4 g/cm^3^
Odor | No data | | No data | No data
Odor threshold:
Water | No data | | No data | No data
Air | No data | | No data | No data
Solubility:
Water | No data | | No data | No data
Organic solvents | No data | | No data | No data
Other | Soluble in hydrochloric acid; insoluble in nitric acid, concentrated hydrogen sulfide | | No data | No data
Partition coefficients:
Log K_ow_ | No data | | No data | No data
Log K_oc_ | No data | | No data | No data
Vapor pressure | No data | | No data | No data
Henry’s law constant | No data | | No data | No data
Autoignition temperature | No data | | No data | No data
Flashpoint | No data | | No data | No data
Flammability limits | No data | | No data | No data
Conversion factors | No data | | No data | No data
Explosive limits | No data | | No data | No data
Chemical name | Plutonium nitrate | Plutonium hexafluoride | Plutonium oxalate | Plutonium tetrafluoride
Molecular weight^b^ | No data | 358 | No data | 320
Physical description | No data | Red-brown orthorhombic crystals | Green-yellow solid^d^ | Red-brown monoclinic crystals
Melting point | No data | 51.6 °C | No data | 1,037 °C
Boiling point | No data | No data | No data | No data
Density | No data | 5.08 g/cm^3^ | No data | 7.1 g/cm^3^
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | No data | No data | No data | No data
Organic solvents | No data | No data | No data | No data
Other | No data | No data | No data | No data
Partition coefficients: | | | | No data
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | No data | No data | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

a All information obtained from HSDB 2009 and Lide 2008, except where noted

b Molecular weights will be dependent on the isotope of plutonium

c α-phase, simple monoclinic; β-phase, body-centered monoclinic; γ-phase, face-centered orthorhombic; δ” phase, face-centered cubic; εε phase, body-centered tetragonal; gg phase, body-centered cubic (Clark et al. 2006)

d Pu(C_2_C_4_)_2_•6H_2_O (CAS No. 26588-74-9) (Clark et al. 2006)

Table 4-3 Radiological Properties of Plutonium Isotopes

Isotope | CAS Registry No. | Half-life | Decay mode(s)/Energy (MeV) | Decay product(s) | Specific activity (Ci/g)
^236^Pu | 15411-92-4 | 2.87 years; 1.5×10^9^ years | α/5.867 MeV; SF/1.9×10^−7^ MeV | ^232^U | 540
^237^Pu | 15411–93-5 | 45.7 days | EC/0.220(99.9%); α/ 5.747 (0.003%) | ^233^U | 12,100^a^
^238^Pu | 13981–16-3 | 87.7 years; 4.75×10^10^ years | α/5.593 SF/ 1.8×10^−7^ | ^234^U | 17
^239^Pu | 15117–48-3^b^; 19257–39-7^c^ | 2.410×10^4^ years; 8×10^15^ years | α/5.244; SF/3×10^−10^ | ^235^U | 0.063
^240^Pu | 14119–33-6 | 6.56×10^3^ years; 1.14×10^11^ years | α/5.255; SF/5.7×10^−6^ | ^236^U | 0.23
^241^Pu | 14119–32-5 | 14.3 years; <6×10^16^ years | β^−^/0.0208 (99+%); α/5.139 (0.002%); SF/>2.4×10^−14^ | ^241^Am; ^237^U | 100
^242^Pu | 13982–10-0 | 3.75×10^5^ years; 6.77×10^10^ years | α/4.983; SF/5.5×10^−4^ | ^238^U | 0.0040
^243^Pu | 15706–37-3 | 4.956 hours | β^−^/0.582 | ^243^Am | 2.6×10^6c^
^244^Pu | 14119–34-7 | 8.00×10^7^ years; 6.6×10^10^ years | α/4.665 (99.9%) SF/0.12 | ^240^U | 1.8×10^−5^

a Calculated values

b Another CAS Registry number listed for ^239^Pu is 97918-67-7

c CAS Registry Number for ^239^Pu^4+^ ion

α = alpha particle emission; β^−^ = negative beta emission; SF = spontaneous fission

Sources: Baum et al. 2002; ChemIDplus 2009; Clark et al. 2006; DOE 2005a; Lide 2008

Figure 4-1 ^238^Pu Decay Series

Sources: Baum et al. 2002; Lide 2005

Figure 4-2 ^239^Pu Decay Series

Sources: Baum et al. 2002; Lide 2005