# 9 REFERENCES

* Not cited in text

Abe A, Urano K. 1994. Influence of chemicals commonly found in a water environment on the Salmonella mutagenicity test. Sci Total Environ 153(1–2):169–175.7939619
Abou-Donia MB. 1995. Organophosphorus pesticides. In: Chang L, Dyer RS, eds. Neurological disease and therapy. New York, NY: Marcel Dekker, Inc., 419–473.
Abou-Donia MB, Lapadula DM. 1990. Mechanisms of organophosphorus ester-induced delayed neurotoxicity: type I and type II. Annu Rev Pharmacol Toxicol 30:405–440 2188574
Abou-Donia MB, Nomeir AA. 1986. The role of pharmacokinetics and metabolism in species sensitivity to neurotoxic agents. Fundam Appl Toxicol 6:190–207.2422085
ACGIH. 2001. Documentation of the threshold limit values and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2008. Triphenyl phosphate. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1997. Toxicological profile for hydraulic fluids. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofiles/tp99.pdf. September 09, 2009.
AIHA. 2008. Emergency response planning guidelines (ERPG). American Industrial Hygiene Association. Fairfax, VA. http://www.aiha.org/1documents/Committees/ERP-erpglevels.pdf. May 19, 2009.
Akzo Chemicals Inc. 1991. Summary of the meeting between Akzo Chem Inc and US EPA concerning the pharmacokinetics tests on tributyl phosphate. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0534064. EPA 40–9121301.
Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Anderson C, Wischer D, Schmieder A, 1993. Fate of triphenyl phosphate in soil. Chemosphere 27(5):869–879.
Anderson JA, Grundmann A, Bester K. 2004. Organophosphorus flame retardants and plasticisers in surface waters. Sci Total Environ 332:155–166.15336899
Andresen J, Bester K. 2006. Elimination of organophosphate ester flame retardants and plasticizers in drinking water purification. Water Res 40(3):621–629.16413933
Andresen JA, Grundmann A, Bester K. 2004. Organophosphorus flame retardants and plasticisers in surface waters. Sci Total Environ 332(1–3):155–166.15336899
Anonymous. 1977. Health and safety data for 4 chemicals with cover letter dated 021089 (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–8900001189. OTS0516689, p 1-Slide 10–14; p 4-Slide 214, 222, 223; p 5-Slide 271; p 13; Slide814–815 p 15; Slide 954–984 p 20; Slide 1227, 1253, 1278; p 25.
Arnold LL, Christenson WR, Cano M, 1997. Tributyl phosphate effects on urine and bladder epithelium in male Sprague-Dawley rats. Fundam Appl Toxicol 40(2):247–255.9441721
Ashford RD. 1994. Ashford's dictionary of industrial chemicals. Properties, production, uses. London, England: Wavelength Publications, Ltd., 925–926.
Auletta CS. 1991. A 90-day dietary study of tributyl phosphate in the mouse. Synthetic Organic Chemical Manufacturers Association, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0534083.
Auletta CS, Kotkoskie LA, Saulog T, 1998b. A dietary oncogenicity study of tributyl phosphate in the CD-1 mouse. Toxicology 128(2):135–141.9710154
Auletta CS, Weiner ML, Richter WR. 1998a. A dietary toxicity/oncogenicity study of tributyl phosphate in the rat. Toxicology 128(2):125–134.9710153
Bacaloni A, Cucci F, Guarino C, 2008. Occurrence of organophosphorus flame retardant and plasticizers in three volcanic lakes of central Italy. Environ Sci Technol 42(6):1898–1903.18409610
Baldwin DS, Beattie JK, Coleman LM. 1995. Phosphate ester hydrolysis facilitated by mineral phases. Environ Sci Technol 29(6):1706–1709.22276899
Banerjee BD, Saha S, Ghosh KK, 1992. Effect of tricresyl phosphate on humoral and cell-mediated immune responses in albino rats. Bull Environ Contam Toxicol 49(2):312–317.1611256
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnes KK, Kolpin DW, Furlong ET, 2008. A national reconnaissance of pharmaceuticals and other organic wastewater contaminants in the United States 1 groundwater. Sci Total Environ 402(2–3):192–200.18556047
Batt KJ, Healy CE, Kneiss JJ, 1992. Genotoxicity testing of tributyl phosphate. Environ Mol Mutagen 19(20):5.
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Blair RM, Fang H, Branham WS, 2000. The estrogen receptor relative binding affinities of 188 natural and xenochemicals: Structural diversity of ligands. Toxicol Sci 54:138–153.10746941
Boethling RS, Cooper JC. 1985. Environmental fate and effects of triaryl and tri-alkyl/aryl phosphate esters. Res Rev 94:49–99.
Brusick D, Matheson D, Jagannath DR, 1979. A comparison of the genotoxic properties of tris(2,3-dibromopropyl)phosphate and tris(1,3-dichloro-2-propyl)phosphate in a battery of short-term bioassays. J Environ Pathol Toxicol 3(1–2):207–226.121137
Burka LT, Sanders JM, Herr DW, 1991. Metabolism of tris(2-chloroethyl) phosphate in rats and mice. Drug Metab Dispos 19(2):443–447.1676651
Camarasa JG, Serra-Baldrich E. 1992. Allergic contact dermatitis from triphenyl phosphate. Contact Dermatitis 26(4):264–265.1395566
Carlsen L, Andersen KE, Egsgaard H. 1986. Triphenyl phosphate allergy from spectacle frames. Contact Dermatitis 15(5):274–277.3816190
Carlsson H, Nilsson U, Ostman C. 2000. Video display units: An emission source of the contact allergenic flame retardant triphenyl phosphate in the indoor environment. Environ Sci Technol 34:3885–3889.
Carlton BD, Basaran AH, Mezza LE, 1987. Examination of the reproductive effects of tricresyl phosphate administered to Long-Evans rats. Toxicology 46(3):321–328.3672537
Carrington CD, Lapadula DM, Othman M, 1996. Assessment of the delayed neurotoxicity of tributylphosphate, tributoxyethyl phosphate, and dibutylphenyl phosphate. Int J Occup Med Immunol Toxicol 5(1):61–68.
Chapin RE, George JD, Lamb Jc IV. 1988. Reproductive toxicity of tricresyl phosphate in a continuous breeding protocol in swiss (CD-1) mice. Fundam Appl Toxicol 10:344–354.3356322
Chapman DE, Michener SR, Powis G. 1991. Metabolism of the flame retardant plasticizer tris(2-chloroethyl)phosphate by human and rat liver preparations. Fundam Appl Toxicol 17(2):215–224.1765216
ChemIDplus. 2009. Phosphate flame retardants. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. July 8, 2009.
ChemIDplus. 2011. Tricresyl phosphate (mixed isomers) RN: 1330–78-5. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. December 13, 2011.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Daft JL. 1982. Identification of aryl alkyl phosphate residues in foods. Bull Environ Contam Toxicol 29(2):221–227.7126910
*David MD, Seiber JN. 1999a. Accelerated hydrolysis of industrial organophosphates in water and soil using sodium perborate. Environ Pollut 105(1):121–128.
David MD, Seiber JN. 1999b. Analysis of organophosphate hydraulic fluids in U.S. Air Force base soils. Arch Environ Contam Toxicol 36(3):235–241.10047589
Davis CS, Richardson RJ. 1980. Organophosphorus compounds. In: Spencer PS, Schaumburg HH, eds. Experimental and clinical neurotoxicology. New York, NY: Oxford University Press, 527–544.
Degeus H, Zegers BN, Lingeman H, 1994. Determination of trialkyl and triaryl phosphates in sediment using microwave extraction and packed-capillary supercritical fluid chromatography. Int J Environ Anal Chem 56:119–132.
Denniston AD. 1995. Hydraulic Fluids. In: Kirk-Othmer encylcopedia of chemical technology. John Wiley & Sons, 1–22. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/hydrdenn.a01/current/pdf. June 03, 2009.
Dodi A, Verda G. 2001. Improved determination of tributyl phosphate degradation products (mono- and dibutyl phosphates) by ion chromatography. J Chromatogr A 920(1–2):275–281.11453010
*Dow Chemical Co.. 1956. Results of range finding toxicological tests on tributyl phosphate with cover letter and attachments (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0530109.
Dybing E, Soederlund E, Holme J, 1983. Comparative genotoxicity studies of the flame retardants tris-bp and tris-cp. [Abstract]. Toxicol Lett 18(Suppl 1):58.
Eastman Kodak Co. 1968. Toxicity and health hazard study for tri-n-butyl phosphate with cover letter dated 081186. Eastman Kodak Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510265. EPA86860000118.
*Eastman Kodak Co. 1987. Letter dated 03/11/87 from Eastman Kodak Co. Regarding toxicity report of tributyl phosphate. Eastman Kodak Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0523050. EPA40–8721015.
Eastman Kodak Co. 1990. Letter from Eastman Kodak Company to US EPA submitting enclosed health and safety studies on triiosbutyl phosphate with attachments. Eastman Kodak Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0528335. EPA86–910000041.
*EF Houghton & Co. 1996. Product data sheet from EF Houghton & Co. containing acute toxicity values for four triaryl phosphate esters. EF Houghton & Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0519194.
EI Dupont Denemours. 1953a. Toxicity of tributyl phosphate, "Alkaterge" c, and "Foamex" with cover letter dated 070286. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510228. EPA868600078.
*EI Dupont Denemours. 1953b. Toxicity of tributyl phosphate, Alkaterge C, and Foamex with cover letter (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0530140.
Eldefrawi AT, Mansour NA, Brattsten LB, 1977. Further toxicologic studies with commercial and candidate flame retardant chemicals part 2. Bull Environ Contam Toxicol 17(6):720–726.880389
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 1617–1621.
EPA. 1979. Assessment of the need for limitation on triaryl and trialkyl/aryl phosphates. Draft final report. Washington, DC: Environmental Protection Agency.
EPA. 1989. Method 1618: Organo-halide pesticides, organo-phosphorus pesticides, and phenoxy-acid herbicides by wide bore capillary column gas chromatography with selective detectors. U.S. Environmental Protection Agency. http://www.epa.gov/region1/info/testmethods/pdfs/1618.pdf. December 13, 2011.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
EPA. 1994. Method 8141B. Organophosphorus compounds by gas chromatography. SW-846. Test methods for evaluating solid wastes physical/chemical methods. U.S. Environmental Protection Agency. http://www.epa.gov/osw/hazard/testmethods/sw846/pdfs/8141b.pdf. December 13, 2011.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum.
EPA. 1998a. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
EPA. 1998b. Inert ingredients no longer used in pesticide products. U.S. Environmental Protection Agency. Fed Regist 63(121):34384–34390. http://www.gpo.gov/fdsys/pkg/FR-1998-06-24/pdf/98-16571.pdf. December 14, 2011.
EPA. 2000. Benchmark dose technical guidance document. Washington, DC: U. S. Environmental Protection Agency, Risk Assessment Forum. EPA630R00001.
EPA. 2003. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F03016. http://www.epa.gov/safewater/contaminants/index.html. May 19, 2009.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2006a. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. May 19, 2009.
EPA. 2006b. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/criteria/wqcriteria.html. May 11, 2009.
*EPA. 2009a. Acute exposure guideline levels (AEGLs). Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/. May 19, 2009.
EPA. 2009b. Hazardous air pollutants. Clean Air Act. Washington, DC: U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. May 19, 2009.
EPA. 2009c. Inert pesticide ingredients in pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opprd001/inerts/lists.html. May 19, 2009.
EPA. 2009d. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009e. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/lawsregs/search/40cfr.html. May 11, 2009.
EPA. 2009f. Toxic substances control act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.30. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009g. Toxic substances control act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009h. Estimation program interface (EPI) suite. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/exposure/pubs/episuite.htm. July 21, 2009.
EPA. 2010. Inventory update reporting. Non-confidential 2006 IUR records by chemical, including manufacturing, processing and use information.. U.S. Environmental Protection Agency. http://cfpub.epa.gov/iursearch/index.cfm?s=comp. December 13, 2011.
EPA. 2011. Master testing list. Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. www.epa.gov/oppt/chemtest/pubs/index1.pdf. December 14, 2011.
Eto M, Casida JE, Eto T. 1962. Hydroxylation and cyclization reactions involved in the metabolism of tri-o-cresyl phosphate. Biochem Pharmacol 11:337–352.13890904
Exxon Research. 1975. An acute inhalation toxicity study in rats, mice and guinea pigs exposed to MRD-ECH-75–14 vapors. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0519216
Fang H, Tong W, Branham WS, 2003. Study of 202 natural, synthetic, and environmental chemicals for binding to the androgen receptor. Chem Res Toxicol 16(10):1338–1358.14565775
FDA. 2006. Total diet study: Market baskets 1991–3 through 2003–4. U.S. Food and Drug Administration. Center for Food Safety & Applied Nutrition. http://vm.cfsan.fda.gov/~acrobat/TDS1byfd.pdf. June 24, 2009.
FDA. 2008. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms.eafus.html. May 19, 2009.
FEDRIP. 2009. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Fee DC, Gard DR, Yang CD. 2006. Phosphorus compounds. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, 1–73. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/phosfee.a01/current/pdf. June 03, 2009.
Fink U, Hajduk R, Mori H, 2008. Flame retardants. SRI Consulting SCUP Report Flame Retardants. http://www.novapdf.com/. April 27, 2009.
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17(5):617–636.2337085
Flowers LJ, Garrett SL. 1992. Mouse micronucleus study of MCS-2518 (final report) with cover letter dated 030493. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–930000153. OTS0538147.
FMC. 1976a. Acute inhalation study in rats with kronitex TBP with cover letter dated 0080886. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510262. EPA86860000114.
FMC. 1976b. Acute oral toxicity in rats with Kronitex TBP. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0512723.
FMC. 1976c. Acute oral toxicity studies in rats with Kronitex TBP. Submitted to the U.S. Environmental Protection Agency under TSCA Section Section 4. OTS0512745.
FMC. 1978. Acute toxicity studies (skin and eye irritation, dermal corrosion, dermal LD50 and oral LD50) of Kronitex TCP. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0519258.
FMC. 1979a. Dermal corrosion in rabbits with TBP with cover letter dated 080886. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510257. EPA868600000109.
FMC. 1979b. Memo from FMC Corp to the Office of Toxic Substances regarding a summary of mutagenic screening tests for aryl and alkyl/aryl phosphate esters dated 052179. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0519265.
FMC. 1981a. Aryl phosphate epidemiology study with cover letter and memo. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8d. OTS0206272.
FMC. 1981b. Rabbit skin irritation testing on tributyl phosphate with cover letter 080886. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510255. EPA868600000107.
FMC. 1982b. Acute toxicity screening tests triphenyl phosphate (commercial non-FMC product) with cover letter. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206297. EPA878213753.
FMC. 1982a. Report of the epidemiologic study of the FMC plant in Nitro, West Virginia. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 4. OTS0518413.
FMC. 1985a. Thirteen week feeding study of tributyl phosphate in rats. FMC Toxicology Laboratory. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0523056.
*FMC. 1985b. Thirteen week feeding study of tributyl phosphate in rats final report. Volume 2. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS02850380.
Focazio MJ, Kolpin DW, Barnes KK, 2008. A national reconnaissance for pharmaceuticals and other organic wastewater contaminants in the United States. II. Untreated drinking water so urces. Sci Total Environ 402(2–3):201–216.18433838
Föllmann W, Wober J. 2006. Investigation of cytotoxic, genotoxic, mutagenic, and estrogenic effects of the flame retardants tris-(2-chloroethyl)-phosphate (TCEP) and tris-(2-chloropropyl)-phosphate (TCPP) in vitro. Toxicol Lett 161:124–134.16154716
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Fries E, Puttmann W. 2001. Occurrence of organophosphate esters in surface water and ground water in Germany. J Environ Monit 3(6):621–626.11785636
Fries E, Puttmann W. 2003. Monitoring of the three organophosphate esters TBP, TCEP and TBEP in river water and ground water (Oder, Germany). J Environ Monit 5(2):346–352.12729280
Fukushima M, Kawai S, Yamaguchi Y. 1992. Behavior of organophosphoric acid triesters in Japanese riverine and coastal environment. Water Sci Technol 25(11):271–278.
Galloway SM, Armstrong MJ, Reuben C, 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen 10(Suppl 10):1–175.3319609
Gann RG, Gilman JW. 2003. Flame retardants: an overview. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, 447–454. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/overgann.a01/current/pdf. June 03, 2009.
Garcia M, Rodriguez I, Cela R. 2007. Microwave-assisted extraction of organophosphate flame retardants and plasticizers from indoor dust samples. J Chromatogr A 1152(1–2):280–286.17140588
Gard DR. 2005. Phosphate acids and phosphates. In: Kirk-Other encyclopedia of chemical technology. John Wiley & Sons, 1–56. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/phosgard.a01/current/pdf. June 03, 2009.
Gartrell MJ, Craun JC, Podrebarac DS, 1985. Pesticides, selected elements, and other chemicals in infant and toddler diet samples, October 1979-September 1980. J Assoc Off Anal Chem 68:1163–1183.4086441
Gee P, Sommers CH, Melick AS, 1998. Comparison of responses of base-specific Salmonella testes strains with the traditional strains for identifying mutagens: The results of a validation study. Mutat Res 412(2):115–130.9539966
Gilbert J, Shepherd MJ, Wallwork MA, 1986. A survey of trialkyl and triaryl phosphates in United Kingdom total diet samples. Food Addit Contam 3(2):113–122.3709885
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Gold MD, Blum A, Ames BN. 1978. Another flame retardant, tris-(1,3-dichloro-2-propyl)phosphate, and its expected metabolites are mutagens. Science 200:785–787.347576
Goldfrank LR, Flomenbaum NE, Lewin NA , eds. 2002. Goldfrank’s toxicologic emergencies. 7^th^ ed. New York, NY: McGraw-Hill, 1346–136.5.
Gomez-Belinchon JI, Grimalt JO, Albaiges J. 1988. Analysis and persistence of tributyl phosphates in riverine and marine coastal waters. Chemosphere 17(11):2189–2198.
Green J. 1992. A review of phosphorus-containing flame retardants. J Fire Sci 10(6):470–487.
Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements and other chemicals. J AOAC Int 71:1200–1209.
Gunderson EL. 1995a. FDA total diet study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Int 78(6):1353–1363.8664570
Gunderson EL. 1995b. Dietary intake of pesticides, selected elements, and other chemicals: FDA total diet study, June 1984-April 1986. J AOAC Int 78(4):910–921.7580329
Guzelian PS, Henry CJ, Olin SS. 1992. In: Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Haraguchi K, Yamashita T, Shigemori N. 1985. Sampling and analysis of phosphoric acid triesters in ambient air. Taiki Osen Gakkaishi 20:407–415.
Hardin BD, Schuler RL, Burg JR, 1987. Evaluation of 60 chemicals in a preliminary developmental toxicity test. Teratog Carcinog Mutagen 7:29–48.2884741
Hartley GS. 1959. Hydrolysis and phosphoric esters and related compounds. Chemical Society (London) Special Publication 8:33–45.
Hartmann PC, Burgi D, Giger W. 2004. Organophosphate flame retardants and plasticizers in indoor air. Chemosphere 57(8):781–787.15488569
Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):3–142.
HazDat. 2007. Phosphate ester flame retardants. HazDat Database. ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic substances and Disease Registry.
Healy CE, Beyrouty PC, Broxup BR. 1995. Acute and subchronic neurotoxicity studies with tri-N-butyl phosphate in adult Sprague-Dawley rats. Am Ind Hyg Assoc J 56(4):349–355.7726100
Herr DW, Sanders JM, Matthews HB. 1991. Brain distribution and fate of tris(2-chloroethyl) phosphate in Fischer 344 rats. Drug Metab Dispos 19(2):436–442.1676650
Hinton DM, Jessop JJ, Arnold A, 1996. Evaluation of immunotoxicity in a subchronic feeding study of triphenyl phosphate. Int J Occup Med Immunol Toxicol 5(1):43–60.
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Honkakoski P, Palvimo JJ, Penttila L, 2004. Effects of triaryl phosphates on mouse and human nuclear receptors. Biochem Pharmacol 67(1):97–106.14667932
Howard PH, Deo PG. 1979. Degradation of aryl phosphates in aquatic environments. Bull Environ Contam Toxicol 22(3):337–344.465801
HSDB. 2009. Phosphate ester flame retardants. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov.
HSDB. 2011. Tricresyl phosphate. Hazardous Substances Data Bank. http://toxnet.nlm.nih.gov. December 8, 2011.
*Hudec T, Thean J, Kuehl D, 1981. Tris(dichloropropyl)phosphate, a mutagenic flame retardant: Frequent occurrence in human seminal plasma. Science 211(4485):951–952.7466368
Hughes MF, Edwards BC, Mitchell CT, 2001. In vitro dermal absorption of flame retardant chemicals. Food Chem Toxicol 39(12):1263–1270.11696400
Hutter HP, Moshammer H, Wallner P, 2006. Health complaints and annoyances after moving into a new office building: A multidisciplinary approach including analysis of questionnaires, air and house dust samples. Int J Hyg Environ Health 209(1):65–68.16373203
IARC. 1999. Tris(2-chloroethyl) phosphate. In: IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 71 1999/09/07 ed. Lyon, France: International Agency for Research on Cancer, 1543–1548.
IARC. 2009. Agents reviewed by the IARC monographs. Volumes 1–99. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. May 11, 2009.
Ingerowski G, Friedle A, Thumulla J. 2001. Chlorinated ethyl and isopropyl phosphoric acid triesters in the indoor environment--an inter-laboratory exposure study. Indoor Air 11(3):145–149.11521497
IPCS. 1990. Tricresyl phosphate. Environmental Health Criteria 112. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc110.htm. December 12, 2011.
IPCS. 1991a. Tri-n-butyl phosphate. Environmental Health Criteria 112. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc112.htm. April 23, 2009.
IPCS. 1991b. Triphenyl phosphate. Environmental Health Criteria 111. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc111.htm. April 13, 2009.
IPCS. 1997. Flame retardants: A general introduction. Environmental Health Criteria 1997. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc192.htm. June 4, 2009.
IPCS. 1998. Flame retardants: Tris(Chloropropyl) phosphate and tris(2-chloreothyl) phosphate. Environmental Health Criteria 209. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc209.htm. April 13, 2009.
IPCS. 2000a. Tris(1-chloro-2-propyl)phosphate. Screening Information Data Set (SIDS) for high production volume chemicals. International Programme on Chemical Safety. http://www.inchem.org/documents/sids/sids/13674845.pdf. April 28, 2009.
IPCS. 2000b. Flame retardants: Tris(2-butoxyethyl) phosphate, tris (2-ethylehexyl) phosphate and tetrakis (hydroxymethyl) phosphonium salts. Environmental Health Criteria 218. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc218.htm. April 13, 2009.
IPCS. 2004. Tributyl phosphate. Screening Information Data Set (SIDS) for high production volume chemicals. International Programme on Chemical Safety. http://www.inchem.org/documents/sids/sids/126-73-8.pdf. April 28, 2009.
IPCS. 2006. Triphenyl phosphate. Screening Information Data Set (SIDS) for high production volume chemicals. International Programme on Chemical Safety. http://www.inchem.org/documents/sids/sids/115866.pdf. June 3, 2009.
IRIS. 2009. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. May 11, 2009.
Ishikawa S, Baba K. 1988. Reaction of organic phosphate esters with chlorine in aqueous solution. Bull Environ Contam Toxicol 41(1):143–150.3179521
Ishikawa S, Taketomi M, Shinohara R. 1985. Determination of trialkyl and triaryl phosphates in environmental samples. Water Res 19(1):119–125.
Ishikawa S, Uchimura Y, Baba K, 1992. Photochemical behavior of organic phosphate esters in aqueous solution irradiated with a mercury lamp. Bull Environ Contam Toxicol 49:368–374.1498472
Jackson J, Sutton R. 2008. Sources of endocrine-disrupting chemicals in urban wastewater, Oakland, CA. Sci Total Environ 405(1–3):153–160.18684489
Johannsen FR, Wright PL, Gordon DE, 1977. Evaluation of delayed neurotoxicity and dose-response relationships of phosphate esters in the adult hen. Toxicol Appl Pharmacol 41(2):291–304.898200
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190(1):3–16.6769537
Jonsson OB, Nilsson UL. 2003. Miniaturized dynamic liquid-liquid extraction of organophosphate triesters from blood plasma using the hollow fibre-based XT-tube extractor. Anal Bioanal Chem 377(1):182–188.12898117
Junk GA, Ford CS. 1980. A review of organic emissions from selected combustion processes. Chemosphere 9(4):187–230.
Katagi T. 2002. Abiotic hydrolysis of pesticides in the aquatic environment. Rev Environ Contam Toxicol 175:79–261.12206055
Kawagoshi Y, Nakamura S, Fukunaga I. 2002. Degradation of organophosphoric esters in leachate from a sea-based solid waste disposal site. Chemosphere 48(2):219–225.12117057
Kawasaki H, 1982. Studies on the toxicity of insecticides and food additives in pregnant rats-(5) foetal toxicity of tris-(chloropropyl) phosphate. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–950000008. OTS0557521.
Kawashima K, Tanaka S, Nakaura S, 1983a. Effect of oral administration of tris(2-chloroethyl)phosphate to pregnant rats on prenatal and postnatal developments. Eisei Shikenjo Hokoku 101:55–61.
*Kawashima K, Tanaka S, Nakaura S, 1983b. Effect of phosphoric acid tri-esters flame retardants on the prenatal and postnatal development of rats. J Toxicol Sci 8:339.
Kelly PF. 2006. Phosphorus: Inorganic chemistry. In: Encyclopedia of inorganic chemistry. John Wiley & Sons, 1–21. http://mrw.interscience.wiley.com/emrw/9780470862100/eic/article/ia185/current/pdf. June 4, 2009.
Kenaga EE, Goring CAI. 1980. Relationship between water solubility, soil, sorption, octanol-water partitioning, and concentration of chemicals in biota. In: Aquatic toxicology. Philadelphia, PA: American Society for Testing and Materials, 78–115.
Kolpin DW, Furlong ET, Meyer MT, 2002. Pharmaceuticals, hormones, and other organic wastewater contaminants in U.S. streams, 1999–2000: A national reconnaissance. Environ Sci Technol 36:1202–1211.11944670
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Komsta E, Secours VE, Chu I, 1989. Short-term toxicity of nine industrial chemicals. Bull Environ Contam Toxicol 43(1):87–94.2758143
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kurebayashi H, Tanaka A, Yamaha T. 1985. Metabolism and disposition of the flame retardant plasticizer, tri-p-cresyl phosphate, in the rat. Toxicol Appl Pharmacol 77(3):395–404.3919466
Laham S, Broxup B, Long G. 1985a. Induction of urinary bladder hyperplasia in Sprague-Dawley rats orally administered tri-n-butyl phosphate. Arch Environ Health 40(6):301–306.4083910
Laham S, Long G, Broxup B. 1984b. Subacute oral toxicity of tri-n-butyl phosphate in the Sprague-Dawley rat. J Appl Toxicol 4(3):150–154.6747197
Laham S, Szabo J, Long G. 1983. Effects of tri-n-butyl phosphate on the peripheral nervous system of the Sprague-Dawley rat. Drug Chem Toxicol 6(4):363–377.6617531
*Laham S, Szabo J, Long G. 1984a. Short-term neurotoxicity studies on tributoxyethyl phosphate orally administered to Sprague-Dawley rats. Chemosphere 13(7):801–812.
Laham S, Szabo J, Long G, 1985b. Dose-response toxicity studies on tributoxyethyl phosphate orally administered to Sprague-Dawley rats. Am Ind Hyg Assoc J 46(8):442–448.4050681
Lamouroux C, Virelizier H, Moulin C, 2000. Direct determination of dibutyl and monobutyl phosphate in a tributyl phosphate/nitric aqueous-phase system by electrospray mass spectrometry. Anal Chem 72(6):1186–1191.10740858
Landahl HD, Tracewell TN, Lassen WH. 1951. On the retention of air-borne particulates in the human lung: II. Arch Ind Hyg Occup Med 3(4):359–366.
Landahl HD, Tracewell TN, Lassen WH. 1952. Retention of air-borne particulates in the human lung: III. Arch Ind Hyg Occup Med 6(6):508–511.
LANXESS. 2005. Technical datasheets. Triisobutyl phosphate. LANXESS Corporation. http://www.phosphorous-chemicals.com/P/download/Phosphorchemikalien_e/TiBP_e.pdf. June 23, 2009.
Latendresse JR, Azhar S, Brooks CL, 1993. Pathogenesis of cholesteryl lipidosis of adrenocortical and ovarian interstitial cells in F344 rats caused by tricresyl phosphate and butylated triphenyl phosphate. Toxicol Appl Pharmacol 122(2):281–289.8212010
Latendresse JR, Brooks CL, Capen CC. 1994a. Pathologic effects of butylated triphenyl phosphate-based hydraulic fluid and tricresyl phosphate on the adrenal gland, ovary, and testis in the Fischer-344 rat. Toxicol Pathol 22(4):341–352.7817124
Latendresse JR, Brooks CL, Capen CC. 1995. Toxic effects of butylated triphenyl phosphate-based hydraulic fluid and tricresyl phosphate in female F344 rats. Vet Pathol 32(4):394–402.7483214
Latendresse JR, Brooks CL, Flemming CD, 1994b. Reproductive toxicity of butylated triphenyl phosphate and tricresyl phosphate fluids in F344 rats. Fundam Appl Toxicol 22(3):392–399.8050634
Lebel G. L, Williams DT. 1983. Determination of organic phosphate triesters in human adipose tissue. Journal of the Association of Official Analytical Chemists 66(3):691–699.
LeBel GL, Williams DT. 1986. Levels of triaryl phosphates in human adipose tissue from eastern Ontario. Bull Environ Contam Toxicol 37(1):41–46.3719141
LeBel GL, Williams DT, Berard D. 1989. Triarylalkyl phosphate residues in human adipose autopsy samples from six Ontario municipalities. Bull Environ Contam Toxicol 43(2):225–230.2775890
LeBel GL, Williams DT, Griffith G, 1979. Isolation and concentration of organophosphorus pesticides from drinking water at the ng/L level, using macroreticular resin. J Assoc Off Anal Chem 62(2):241–249.447594
Lee CJ, Rasmussen TJ. 2006. Occurrence of organic wastewater compounds in effluent-dominated streams in northeastern Kansas. Sci Total Environ 371(1–3):258–269.16935319
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lewis RJ. 2000. Sax's dangerous properties of industrial materials. 10th ed. New York, NY: John Wiley & Sons, Inc., 2131, 3622.
Lewis RJ. 2007. Hawley’s condensed chemical dictionary. 15^th^ ed. New York, NY: John Wiley & Sons, 1261, 1262, 1286, 1288.
Lide DR. 2008. CRC handbook of chemistry and physics. 88^th^ ed. Boca Raton, FL: CRC Press, 3–502.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lorenz W, Bahadir M. 1993. Recycling of flame retardants containing printed circuits: A study of the possible formation of polyhalogenated dibenzodioxins/-furans. Chemosphere 26:2221–2229.
Lynn RK, Wong K, Garve-Gould C, 1981. Disposition of the flame retardant, tris(1,3-dichloro-2-propyl) phosphate, in the rat. Drug Metab Dispos 9(5):434–441.6117442
Mack AG. 2004. Flame retardants, halogenated. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, 454–483. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/halopett.a01/current/pdf. June 03, 2009.
MacKellar DG. 1976. Acute toxicity screening tests for Kronitex TBP with cover letter dated 080886. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510263. EPA868600000116.
Marklund A, Andersson B, Haglund P. 2003. Screening of organophosphorus compounds and their distribution in various indoor environments. Chemosphere 53:1137–1146.14512118
Marklund A, Andersson B, Haglund P. 2005a. Traffic as a source of organophosphorus flame retardants and plasticizers in snow. Environ Sci Technol 39(10):3555–3562.15952358
Marklund A, Andersson B, Haglund P. 2005b. Organophosphorus flame retardants and plasticizers in Swedish sewage treatment plants. Environ Sci Technol 39(19):7423–7429.16245811
Marzulli FN, Callahan JF, Brown DWC. 1965. Chemical structure and skin penetrating capacity of a short series of organic phosphates and phosphoric acid. J Invest Dermatol 44:339–344.14290305
Mayer FL, Adams WJ, Finley MT, 1981. Phosphate ester hydraulic fluids: An aquatic environmental assessment of Pydrauls 50E and 115E. In: Branson DR, Dickson KL, eds. Aquatic toxicology and hazard assessment. American Society for Testing Materials (ASTM). Vol. STP 737. Philadelphia, PA, 103–123.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Minegishi K, Kurebayashi H, Nambaru, 1988. Comparative studies on absorption, distribution, and excretion of flame retardants halogenated alkyl phosphate in rats. Eisei Kagaku 2:102–114.
*Mobil Oil Co. 1979a. Initial submission: Acute oral toxicity study with trisbutoxyethyl phosphate in rats (final report) with cover letter dated 063092. Mobil Oil Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0540432. EPA88–920004084.
*Mobil Oil Co. 1979b. Dermal corrosion assay (D.O.T.) in rabbits with tributyl phosphate with cover letter dated 071586. Mobil Oil Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510232. EPA86860000082.
Mobil Oil Co. 1981. Four hour acute inhalation toxicity study in Sprague-Dawley rats with 2263–80 with cover letter and attachment (sanitized). Mobil Oil Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0530431.
Mobil Oil Co. 1991. Evaluation of test article tributoxyethyl phosphate for mutagenic potential employing the L5178Y TK+/− mutageneisis assay with cover letter dated 052091 (sanitized). Mobil Oil Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0530432.
Moller K, Crescenzi C, Nilsson U. 2004. Determination of a flame retardant hydrolysis product in human urine by SPE and LC-MS. Comparison of molecularly imprinted solid-phase extraction with a mixed-mode anion exchanger. Anal Bioanal Chem 378(1):197–204.14614582
Monsanto Co. 1979. A three-week dermal toxicity study of santicizer-154 and triphenyl phosphate in rabbits. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211874. OTS206227.
Monsanto Co. 1980. Evaluation of health hazards associated with occupational exposure to skydrol hydraulic fluids with attachments, cover sheet and letter dated 020190. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–900000073. OTS0522305.
Monsanto Co. 1985d. A 21-day dermal toxicity study in rabbits with tributoxyethyl phosphate (final report) with attachments and cover letter dated 062785. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–910000306. OTS0526536.
Monsanto Co. 1985a. Tributoxyethyl phosphate: Range-finding teratology study in rats (final report) with cover letter dated 060485. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–910000305. OTS0528535.
Monsanto Co. 1985b. Tributoxyethyl phosphate: Teratology study in rats with attachments and cover letter dated 083085. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA96–910000298. OTS0528528.
Monsanto Co. 1985c. Tributoxyethyl phosphate: CHO/HGPRT mammalian cell forward gene mutation assay with attachments, cover sheets and letter dated 121285. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–910000299. OTS0528529.
Monsanto Co. 1985e. In vitro microbiological mutagenicity assays with tributoxyethyl phosphate (final report) with cover letter dated 010884. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–910000304. OTS0528534.
*Monsanto Co. 1986. Studies on the delayed neurotoxicity of tributyl phosphate. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0523069. EPA40–8621033.
Monsanto Co. 1989a. Acute oral toxicity study in rats with tri-isobutyl phosphate (final report) with cover letter dated 072189. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0528540. EPA86–910000310.
Monsanto Co. 1989b. Primary dermal irritation study in rabbits (4-hour exposure/semi-occlusive covering) with tri-isobutyl phosphate (final report) with cover sheets and letter dated 121890. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0528542. EPA86–910000312.
Monsanto Co. 1992. Evaluation of the skin irritating and sensitizing propensities of MCS 2495 in humans (final report) with attachments and cover letter dated 022692 (sanitized). Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535407.
Morales NM, Matthews HB. 1980. In-vivo binding of the flame retardants tris-(2 3 di bromopropyl) phosphate and tris-1 3 di chloro-2-propyl phosphate to macro molecules of mouse liver kidney and muscle. Bull Environ Contam Toxicol 25(1):34–38.6161654
Morgan AA, Hughes JP. 1981. An investigation into the value of cholinesterase estimations of workers in a plant manufacturing tri-aryl phosphate plasticizers. J Soc Occup Med 31(2):69–75.7242037
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Mortelmans K, Haworth S, Lawlor T, 1986. Salmonella mutagenicity tests. 2. Results from the testing of 270 chemicals. Environ Mutagen 8(Suppl 7):1–119.
Muir DCG. 1984. Phosphate esters. In: Hutzinger O, ed. The Handbook of environmental chemistry. Vol. 3. Part C. Anthropogenic compounds. New York, NY: Springer-Verlag, 41–66.
Muir DC, Grift NP, Blouw AP, 1980. Environmental dynamics of phosphate esters: 1. Uptake and bioaccumulation of triphenyl phosphate by rainbow trout (Salmo gairdneri). Chemosphere 9(9):525–532.
Muir DC, Yarechewski AL, Grift NP. 1983a. Environmental dynamics of phosphate esters: 3. Comparison of the bioconcentration of 4 triaryl phosphates by fish. Chemosphere 12(2):155–166.
Muir DCG, Grift NP, Lockhart WL. 1981. Comparison of laboratory and field results for prediction of the environmental behavior of phosphate esters. Environ Toxicol Chem 1:113–119.
*Muir DCG, Townsend BE, Lockhart WL. 1983b. Bioavailability of 6 organic chemicals to Chironomus tentans larvae in sediment and water. Environ Toxicol Chem 2:269–281.
Muir DCG, Yarechewski AL, Grift NP. 1989. Biodegradation of four triaryl/alkyl phosphate esters in sediment under various temperature and redox conditions. Toxicol Environ Chem 18:269–286.
Muszkat L, Lahav D, Ronen D, 1993. Penetration of pesticides and industrial organics deep into soil and into groundwater. Arch Insect Biochem Physiol 22(3–4):487–499.
Nagase M, Toba M, Kondo H, 2003. Estimation of organophosphoric acid triesters in soft polyurethane foam using a concentrated sulfuric acid dissolution technique and gas chromatography with flame photometric detection. Anal Sci 19(12):1617–1620.14696924
Nakamura A, Tateno N, Kojima S, 1979. Mutagenicity of halogenated alkanols and their phosphoric acid esters for Salmonella typhimurium. Mutat Res 66:373–380.379633
NAS. 2000. Toxicological risks of selected flame-retardant chemicals. Washington, DC: National Academy Press. http://www.nap.edu/catalog.php?record_id=9841#orgs. June 23, 2009.
NAS/NRC. 1989. Report of the oversight committee. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. Biologic markers in reproductive toxicology.
Naylor MW, Ribelin WR. 1990. 90-Day study of triisobutyl phosphate (TIBP) administered in feed to albino rats. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–920000201. OTS0534406.
Neerathilingam M, Volk DE, Sarkar S, 2010. 1H NMR-based metabonomic investigation of tributyl phosphate exposure in rats. Toxicol Lett 199(1):10–16.20688139
NIOSH. 1990. Tributoxyethyl phosphate; tributyl phosphate; triphenyl phosphate; tris(2-chloro-isopropyl) phosphate (TCPP; Tris-(2-chloroethyl)-phosphate and tricresyl phosphate. Estimated numbers of employees potentially exposed to specific agents by 2-digit Standard Industrial Classification (SIC). National Occupational Exposure Survey conducted from 1981–1983. Centers for Disease Control. National Institute for Occupational Safety and Health. http://www.cdc.gov/noes/ December 13, 2011.
NIOSH. 1994a. Tributyl phosphate. Method 5034. NIOSH manual of analytical methods. National Institute of Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/5034.pdf. June 4, 2009.
NIOSH. 1994b. Triphenyl phosphate. Method 5038. National Institute of Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/5038.pdf. June 4, 2009.
NIOSH. 1994c. Triorthocresyl phosphate. Method 5037. NIOSH Manual of Analytical Methods (NMAM). www.cdc.gov/niosh/docs/2003-154/pdfs/5037.pdf. December 13, 2011.
NIOSH. 2005a. Tributyl phosphate. ICSC: 0584. International Chemical Safety Cards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/ipcsneng/neng0584.html. June 23, 2009.
NIOSH. 2005b. Tributyl phosphate and triphenyl phosphate. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. May 19, 2009.
NIOSH. 2007. Tris(2-chloroethyl) phosphate. ICSC: 1677. International Chemical Safety Cards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/ipcsneng/neng1677.html. June 23, 2009.
Nishihara T, Nishikawa J, Kanayama T, 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci 46(4):282–298.
Noda T, Yamano T, Shimizu M, 1994. Effects of tri-n-butyl phosphate on pregnancy in rats. Food Chem Toxicol 32(11):1031–1036.7959457
Nomeir AA, Kato S, Matthews HB. 1981. The metabolism and disposition of tris(1,3-dichloro-2-propyl) phosphate (Fyrol FR-2) in the rat. Toxicol Appl Pharmacol 57(3):401–413.7222047
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
NRC. 2000. Exposure assessment methodology. In: Toxicological risks of selected flame-retardant chemicals. National Research Council. Washington, DC: National Academy Press, 35–52.
NTP. 1982. Mutagenesis testing results. National Toxicology Program. NTP Tech Bull 7:5–9.
NTP. 1983. Salmonella mutagenesis test results. National Toxicology Program. NTP Tech Bull 9:5–6.
NTP. 1991b. Final report on the reproductive toxicity of tris(2-chloroethyl)phosphate reproduction and fertility assessment in Swiss CD-1 mice when administered via gavage.
NTP. 1991a. NTP toxicology and carcinogenesis studies of tris(2-chloroethyl) phosphate (CAS No. 115–96-8) in F344/N rats and B6C3F1 mice (gavage studies). Program NT. TR 391. http://ntp.niehs.nih.gov/ntp/htdocs/LT_rpts/tr391.pdf. May 6, 2009.
NTP. 1994. NTP technical report on the toxicology and carcinogenesis studies of tricresyl phosphate (CAS No. 1330–78-5) in F344/N rats and B6C3F1 mice (gavage and feed studies). TR-433. National Toxicology Program.
NTP. 2005. Report on carcinogens. 11^th^ ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp.roc/toc11.html. May 11, 2009.
NTP. 2011. Report on carcinogens. 12th ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. December 14, 2011.
*Oishi H, Oishi S, Hiraga K. 1980. Toxicity of tri-n-butyl phosphate, with special reference to organ weights, serum components and cholinesterase activity in male rats. Toxicol Lett 6(2):81–85.7414624
Oishi H, Oishi S, Hiraga K. 1982. Toxicity of several phosphoric acid esters in rats. Toxicol Lett 13:29–34.7179306
O'Neil MJ, Heckelman PE, Koch CB, 2006. The Merck index. Whitehouse Station, NJ: Merck & Co., Inc, 1676.
OSHA. 2009. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000, Table Z1. http://www.osha.gov/comp-links.html. May 19, 2009.
Otake T, Yoshinaga J, Yanagisawa Y. 2001. Analysis of organic esters of plasticizer in indoor air by GC-MS and GC-FPD. Environ Sci Technol 35(15):3099–3102.11505983
Otake T, Yoshinaga J, Yanagisawa Y. 2004. Exposure to phthalate esters from indoor environment. J Expo Anal Environ Epidemiol 14(7):524–528.15039795
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Owens CV Jr., Lambright C, Bobseine K, 2007. Identification of estrogenic compounds emitted from the combustion of computer printed circuit boards in electronic waste. Environ Sci Technol 41(24):8506–8511.18200886
Pedersen JA, Soliman M, Suffet IH. 2005. Human pharmaceuticals, hormones, and personal care product ingredients in runoff from agricultural fields irrigated with treated wastewater. J Agric Food Chem 53:1625–1632.15740050
Peterman PH, Delfino JJ, Dube DJ, 1980. Chloro-organic compounds in the lower Fox River, Wisconsin. In: Afghan BK, Mackay D, eds. Hydrocarbons and halogenated hydrocarbons in the aquatic environment. New York, NY: Plenum Press, 145–160.
Quintana JB, Reemtsma T. 2006. Potential of membrane-assisted solvent extraction for the determination of phosphoric acid triesters in wastewater samples by liquid chromatography-tandem mass spectrometry. J Chromatogr A 1124(1–2):22–28.16647073
Reemtsma T, Weiss S, Mueller J, 2006. Polar pollutants entry into the water cycle by municipal wastewater: A European perspective. Environ Sci Technol 40(17):5451–5458.16999124
Ren X, Lee Y, Han HJ, 2008. Effect of tris-(2-chloroethyl)-phosphate (TCEP) at environmental concentration on the levels of cell cycle regulatory protein expression in primary cultured rabbit renal proximal tubule cells. Chemosphere 74:84–88.18952254
Reyna MS, Thake DG. 1987a. Eighteen week feeding study of tributoxyethyl phosphate (TBEP) administered to Sprague-Dawley rats. Monsanto Agricultural Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0530087.
Reyna MS, Thake DG. 1987b. Evaluation of the peripheral nervous system of Sprague-Dawley rats after 19 weeks of feeding tributoxyethyl phosphate (TBEP). Monsanto Agricultural Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0530086.
RTECS. 2009. Phosphate ester flame retardants. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc.
RTECS. 2011. Phosphoric acid, tritolyl ester. Registry of toxic effects on chemical substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc.
Saboori AM, Lang DM, Newcombe DS. 1991. Structural requirements for the inhibition of human monocyte carboxylesterase by organophosphorus compounds. Chem Biol Interact 80(3):327–338.1954660
Saeger VW, Hicks O, Kaley RG, 1979. Environmental fate of selected phosphate esters. Environ Sci Technol 13(7):840–844.
Saito I, Onuki A, Seto H. 2007. Indoor organophosphate and polybrominated flame retardants in Tokyo. Indoor Air 17(1):28–36.17257150
Sala M, Gu ZG, Moens G, 1982. In vivo and in vitro biological effects of the flame retardants tris(2,3-dibromopropyl) phosphate and tris(2-chlorethyl)orthophosphate. Eur J Cancer Clin Oncol 18(12):1337–1344.6891932
Sasaki K, Suzuki T, Takeda M, 1982. Bioconcentration and excretion of phosphoric-acid triesters by killifish Oryzias-latipes. Bull Environ Contam Toxicol 28(6):752–759.7104508
Sasaki K, Suzuki T, Takeda M, 1984. Metabolism of phosphoric acid triesters by rat liver homogenate. Bull Environ Contam Toxicol 33(3):281–288.6478075
Sasaki K, Takeda M, Uchiyama M. 1981. Toxicity, absorption, and elimination of phosphoric acid triesters by killifish and goldfish. Bull Environ Contam Toxicol 27:775–782.7337849
Schlede E, Aberer W, Fuchs T, 2003. Chemical substances and contact allergy: 244 substances ranked according to allergenic potency. Toxicology 193(3):219–259.14599761
Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shah M, Meija J, Cabovska B, 2006. Determination of phosphoric acid triesters in human plasma using solid-phase microextraction and gas chromatography coupled to inductively coupled plasma mass spectrometry. J Chromatogr A 1103(2):329–336.16337211
Shankwalker SG, Placek DG. 1992. Oxidation and weight loss characteristics of commercial phosphate esters. Ind Eng Chem Res 31(7):1810–1813.
Sjodin A, Carlsson H, Thuresson K, 2001. Flame retardants in indoor air at an electronics recycling plant and at other work environments. Environ Sci Technol 35(3):448–454.11351713
Smyth HF, Carpenter CP, Weil CS. 1951. Range-finding toxicity data: List IV. AMA Arch Ind Hyg Occup Med 4:119–122.14856438
Sobotka TJ, Brodie RE, Arnold A, 1986. Neuromotor function in rats during subchronic dietary exposure to triphenyl phosphate. Neurobehav Toxicol Teratol 8(1):7–10.3703097
*SOCMA. 1990. Tributyl phosphate: Skin sensitization study in guinea pigs (final report) with cover letter dated 032690. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0528314. EPA40–9021192.
SOCMA. 1992. Letter from SOCMA to USEPA regarding oral/dermal pharmacokinetic testing of tributyl phosphate (TBP) with attachments, dated 12/23/92. Synthetic Organic Chemical Manufacturers Association, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0572980.
SOCMA. 1994. Metabolism of tributyl phosphate in Yucatan minipigs following intravenous and dermal exposure (part II), with cover letter dated 05/16/94. Synthetic Organic Chemical Manufacturers Association, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–940000966. OTS0557376.
Søderlund EJ, Dybing E, Holme JA, 1985. Comparative genotoxicity and nephrotoxicity studies of the two halogenated flame retardants tris(1,3-dichloro-2-propyl)phosphate and tris(2,3-dibromopropyl)phosphate. Acta Pharmacol Toxicol (Copenh) 56(1):20–29.3883695
Solbu K, Daae HL, Olsen R, 2011. Organophosphates in aircraft cabin and cockpit air--method development and measurements of contaminants. J Environ Monit 3(5):1393–1403.
Solbu K, Thorud S, Hersson M, 2007. Determination of airborne trialkyl and triaryl organophosphates originating from hydraulic fluids by gas chromatography-mass spectrometry. Development of methodology for combined aerosol and vapor sampling. J Chromatogr A 1161(1–2):275–283.17574560
SRI. 2000. Directory of chemical producers. United States: Menlo Park, CA: SRI Consulting, 956.
SRI. 2008. Directory of chemical producers: United States. Menlo Park, CA: SRI Consulting, 781–782.
Stauffer Chemical Co. 1973. Toxicology laboratory report-phosflex 4 with cover letter dated 081286. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510245. EPA86860000097.
Stauffer Chemical Co. 1981a. A two year oral toxicity/carcinogenicity study of Fyrol FR-2 in rats. In: A two-year oral toxicity/carcinogenicity study of fyrol FR-2 in rats (volume I-IV) (final reports) with attachments, cover sheets and letter dated 093081. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. EPA88–8100282. OTS0204911.
Stauffer Chemical Co. 1981b. Toxicology reports on FYROL FR-2 (volume I-II) with attachments and cover letters dated 020381. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. EPA88–8100271. OTS0204911.
Stauffer Chemical Co. 1983. A mortality study of workers employed at a Fyrol FR-2 manufacturing plant with attachment and cover letter dated 040384. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. EPA88–8400615. OTS0204911.
Stegeman SD, Costello JG, Garrett SL. 1992. Ames/Salmonella mutagenicity assay of MCS-2518 (final report) with cover letter dated 030493. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86–930000154. OTS0538148.
Stevens GW, Lo TC, Baird MHI. 2007. Extraction, liquid-liquid. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, 1–62. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/liqulo.a01/current/pdf. June 02, 2009.
Stiles R, Yang I, Lippincott RL, 2008. Measurement of drinking water contaminants by solid phase microextraction initially quantified in source water samples by the USGS. Environ Sci Technol 42(8):2976–2981.18497153
*Stropp G. 1996. Tris (2-chloroisopropyl) phosphat-acute oral toxicity study in male and female Wistar rats, with TSCA health and safety study cover letter dated 08/23/96. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0558767. EPA86960000566.
Sutton WL, Terhaar CJ, Miller FA, 1960. Studies on the industrial hygiene and toxicology of triphenyl phosphate. Arch Environ Health 1:33–46.13835853
Suzuki T, Sasaki K, Takeda M, 1984a. Metabolism of tributyl phosphate in male rats. J Agric Food Chem 32(3):603–610.
Suzuki T, Sasaki K, Takeda M, 1984b. Some S-containing metabolites of tributyl phosphate in the rat. J Agric Food Chem 32(6):1278–1283.
Takada K, Yasuhara K, Nakaji Y, 1989. Carcinogenicity study of tris (2-chloroethyl) phosphate in ddY mice. J Toxicol Pathol 2:213–222.
Tarvainen K. 1995. Analysis of patients with allergic patch test reactions to a plastics and glues series. Contact Dermatitis 32(6):346–351.7554881
Tennant RW, Ashby J. 1991. Classification according to chemical structure, mutagenicity to Salmonella and level of carcinogenicity of a further 39 chemicals tested for carcinogenicity by the U.S. National Toxicology Program. Mutat Res 257(3):209–228.2014033
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thomas RA, Macaskie LE. 1996. Biodegradation of tributyl phosphate by naturally occurring microbial isolates and coupling to the removal of uranium from aqueous solution. Environ Sci Technol 30(7):2371–2375.
Thomas RA, Macaskie LE. 1998. The effect of growth conditions on the biodegradation of tributyl phosphate and potential for the remediation of acid mine drainage waters by a naturally-occurring mixed microbial culture. Appl Microbiol Biotechnol 49(2):202–209.9534259
Thomas RA, Morby AP, Macaskie LE. 1997. The biodegradation of tributyl phosphate by naturally occurring microbial isolates. FEMS Microbiol Lett 155(2):155–159.9351197
Thruston AD, Richardson SD, McGuire JM, 1991. Multispectral identification of alkyl and chloroalkyl phosphates from an industrial effluent. J Am Soc Mass Spectrom 2:419–426.24242693
Tilson HA, Veronesi B, McLamb RL, 1990. Acute exposure to tris(2-chloroethyl)phosphate produces hippocampal neuronal loss and impairs learning in rats. Toxicol Appl Pharmacol 106(2):254–269.2256115
Tyl RW, Gerhart JM, Myers CB, 1997. Two-generation reproductive toxicity study of dietary tributyl phosphate in CD rats. Fundam Appl Toxicol 40(1):90–100.9398491
Umezu T, Yonemoto J, Soma Y, 1998. Tris(2-chloroethyl)phosphate increases ambulatory activity in mice: Pharmacological analyses of its neurochemical mechanism. Toxicol Appl Pharmacol 148(1):109–116.9465270
Union Carbide Corportation. 1943. Range finding tests on tributyl phosphate with cover letter dated 081186. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0510270. EPA86860000125.
USGS. 2001. Methods of analysis by the U. S. Geological Survey National Water Quality Laboratory. Determination of wastewater compounds by polystyrene-divinylbenzene solid-phase extraction and capillary-column gas chromatography/mass spectrometry. Denver, CO: U. S. Geological Survey.
Vernon CA. 1959. The mechanisms of hydrolysis of organic phosphates. In: Phosphoric esters and related compounds. Special Publication. Vol. 8. London: Chemical Society, 17–32.
Viccellio P, Bania T, Brent J, , 1988. Insecticides and pesticides. In: Emergency toxicology. 2nd ed. Philadelphia, PA; Lippincott-Raven Press, 401–413.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vogel EW, Nivard MJ. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8(1):57–81.8450769
Watanabe K, Sakamoto K, Sasaki T. 1996. Comparisons on chemically-induced mutagenicity among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: Collaborative study I. Mutat Res 361(2–3):143–155.8980700
Watts MJ, Linden KG. 2008. Photooxidation and subsequent biodegradability of recalcitrant tri-alkyl phosphates TCEP and TBP in water. Water Res 42(20):4949–4954.18986671
Watts MJ, Linden KG. 2009. Advanced oxidation kinetics of aqueous trialkyl phosphate flame retardants and plasticizers. Environ Sci Technol 43(8):2937–2942.19475974
Weil ED. 2001. Flame retardants, phosphorus. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: Wiley & Sons, 484–510. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/phosweil.a01/current/pdf. June 02, 2009.
Weiner ML, Jortner BS. 1999. Organophosphate-induced delayed neurotoxicity of triarylphosphates. Neurotoxicology 20(4):653–674.10499364
Welsh JJ, Collins TF, Whitby KE, 1987. Teratogenic potential of triphenyl phosphate in Sprague-Dawley (Spartan) rats. Toxicol Ind Health 3(3):357–369.3686538
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2000. Air quality guidelines. 2^nd^ ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/activities/20050223_4. May 11, 2009.
WHO. 2006. Guidelines for drinking-water quality. 3^rd^ ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. May 11, 2009.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Williams DT, LeBel GL, Benoit FM. 1981. Identification of trialkyl and triaryl phosphates in distilled and Super-Q water. J Assoc Off Anal Chem 64(3):635–640.
Williams DT, Nestmann ER, Lebel GL, 1982. Determination of mutagenic potential and organic contaminants of Great Lakes (Canada, USA) drinking water. Chemosphere 11(3):263–276.
Winder C, Balouet JC. 2002. The toxicity of commercial jet oils. Environ Res 89(2):146–164.12123648
Wolf R, Kaul BL. 2005. Plastics, adhesives. In: Ullmann's encyclopedia of industrial chemistry. John Wiley & Sons, 1–51. http://mrw.interscience.wiley.com/emrw/9783527306732/ueic/article/a20_459/current/pdf. June 4, 2009.
Yamada S. 1987. Water pollution by organophosphoric acid triesters and its effects of aquatic organisms- a review. Bull Tokai Reg Fish Res Lab 123:15–30.
Zeiger E, Anderson B, Haworth S, 1987. Salmonella mutagenicity tests. III. Results from the testing of 255 chemicals. Environ Mutagen 9(Suppl 9):1–110.
Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 19(Suppl 21):2–141.1541260
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372