# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Phosphate esters are considered derivatives of the tri protic acid, phosphoric acid O=P(OH)_3_, with the general formula of R_x_H_3-x_PO_4_ where x=1 for mono, x=2 for di, and x=3 for triesters. Phosphorus has a high affinity for oxygen due to the difference in electronegativity (1.4), and consequently, the P=O bond possesses more σ character than π character. Therefore, the P=O bond, which dominates phosphate chemistry, can be more accurately depicted as a coordinate bond, P→O, or as P^+^–O^−^. These phosphoric acid esters are often referred to as organophosphates. Trialkyl, triaryl, and trihaloalkyl/aryl, and mixed phosphate esters possess a central phosphorus atom with an oxidation state of +5 and an approximate tetrahedral geometry (Fee 2005; Gard 2005).

A wide array of substituents can occur as esters of phosphates. In many cases, all of the substituents are identical, as is the case for this profile; however, variable, mono-, di-, or tri-substituted as well as mixed substituents are common. The selected compounds, shown above, are trisubstituted, contain identical substituents, and fall into the following categories: alkyl (TnBP, TiBP), alkyl ether (TBEP), chloroalkyl (TCEP, TCPP, TDCP), and aryl (TPP, TCP) phosphate esters. Although the majority of selected compounds are discrete chemicals, commercial formulations of TCPP may contain minor amounts of structural isomers (NAS 2000). In addition, the commercial mixture of TCP as described here is an unspecified mixture of isomers, but commercial mixtures are predominantly meta and para isomers with less than 1% ortho (Winder and Balouet 2002). Table 4-1 lists common synonyms, trade names, and other pertinent information to identify the selected phosphate esters for this profile.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important chemical and physical properties of the selected phosphate esters.

Table 4-1 Chemical Identity of Selected Phosphate Ester Flame Retardants^a^

Characteristic | Tributyl phosphate | Triisobutyl phosphate | Tris(2-butoxyethyl) phosphate | Triphenyl phosphate | Tricresyl phosphate | Tri-(2-chloroisopropyl) phosphate | Tris(1,3-dichloro-2-propyl) phosphate | Tris(2-chloroethyl) phosphate
Synonym(s) | TnBP; butyl phosphate; phosphoric acid tributyl ester; tri-n-butyl phosphate; tributoxyphosphine oxide | TiBP; isobutyl phosphate; phosphoric acid, tris(2-methylpropyl) ester | TBEP; tri(2-butoxyethyl) phosphate; tributoxyethyl phosphate; 2-butoxyethanol, phosphate; ethanol, 2-butoxy-, phosphate (3:1); phosphoric acid, tributoxyethyl ester; tributyl cellosolve phosphate | TPP; phosphoric acid, triphenyl ester; triphenoxyphosphine oxide | TCP; phosphoric acid, tris(methylphenyl) ester; phosphoric acid, tritolyl ester; tris(methylphenyl) phosphate | TCPP; tris(1-chloro-2-propyl) phosphate; tris(2-chloroisopropyl) phosphate^d^; phosphoric acid, tris(2-chloro-1-methyl) ether^e^ | TDCP; tris(1,3-dichloroisopropyl) phosphate; tris(1-chloromethyl-2-chloroethyl)phosphate; 2-propanol, 1,3-dichloro-, phosphate (3:1) | TCEP; trichlorethyl phosphate; phosphoric acid; tris(2-chloroethyl)ester; tri(2-chloroethyl) phosphate; ethanol, 2-chloro-, phosphate (3:1); tris(2-chloroethyl) orthophosphate
Registered trade name(s) | Disflamoll TB; Celluphos 4; Phosflex 4^b^; Skydrol LD-4^b^ | No data | Kronitex KP-140; KP 140; Phosflex T-bep | Celluflex TPP; Disflamoll TP; Phosflex TPP | Kronitex TCP^b^; Phosflex 179A; Disflamoll TKP; Lindol; Celluflex 179C | Hostaflam OP 820; Amgard TMCP; Fyrol PFC^d^; Antiblaze 80^f^ | Fyrol FR-2; Antiblaze 195^f^ | Antiblaze 100; Celluflex CEF; Disflamoll TCA; Fyrol CEF; Niax 3CF, Tolgard TCEP; Genomoll P; Hostaflam UP810; Levagard EP
Chemical formula | C_12_H_27_O_4_P | C_12_H_27_O_4_P | C_18_H_39_O_7_P | C_18_H_15_O_4_P | C_21_H_21_O_4_P | C_9_H_18_Cl_3_O_4_P | C_9_H_15_Cl_6_O_4_P | C_6_H_12_Cl_3_O_4_P
Chemical structure | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Identification numbers:
CAS registry | 126-73-8 | 126-71-6 | 78-51-3 | 115-86-6 | 1330-78-5 | 13674-84-5 | 13674-87-8 | 115-96-8
RTECS^c^ | TC7700000 | No data | KJ9800000 | TC8400000 | TD0175000 | TC9000000 | No data | KK2450000
EPA hazardous waste | No data | No data | No data | No data | No data | No data | No data | No data
EPA/OPP pesticide Code | No data | No data | No data | No data | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | No data | No data | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data | IMO 9.0 | UN 2574; IMO 6.1 | No data | No data | UN: 3082^g^
HSDB | 1678 | No data | 2564 | 2536 | 6774 | No data | 4364 | 2577
EINECS | 204-800-2 | 204-798-3 | 201-122-9 | 204-112-2 | 215-548-8 | 237-158-7 | 237-159-2 | 204-118-5
NCI | No data | No data | No data | No data | C61041 | No data | No data | C60128

a All information obtained from HSDB 2009, 2011 and ChemIDplus 2009, 2011, except where noted.

b IPCS 1990, 1991a, 2000b.

c RTECS 2009.

d Ashford 1994.

e Lewis 2000.

f Weil 2001.

g NIOSH 2007.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Selected Phosphate Ester Flame Retardants^a^

Property | Tributyl phosphate (TnBP) | Triisobutyl phosphate (TiBP) | Tris(2-butoxyethyl) phosphate (TBEP) | Triphenyl phosphate (TPP) | Tricresyl phosphate (TCP) | Tri-(2-chloroisopropyl) phosphate (TCPP) | Tris(1,3-dichloro-2-propyl) phosphate (TDCP) | Tris(2-chloroethyl) phosphate (TCEP)
Molecular weight | 266.31 | 266.31^c^ | 398.48 | 326.28 | 368.36 | 327.57 | 430.88 | 285.50
Physical description | Colorless to pale-yellow liquid | Clear, colorless, low viscosity liquid^c^ | Slightly yellow, oily liquid | Colorless, crystalline powder; white platelets, crystals from absolute alcohol-ligroin, prisms from alcohol, needles from ether-ligroin | Colorless liquid^f^; Oily flame resistant liquid^g^ | Colorless liquid^f^ | Viscous, clear liquid | Clear, transparent, Low viscosity liquid
Melting point | −80 °C | No data | −70 °C | 49–50 °C | −33 °C^h^ | −40 °C | 27 °C | −55 °C
Boiling point | 289 °C; decomposes^b^ | 264 °C^d^ | 215–228 °C at 4 mm Hg | 245 °C at 11 mm Hg | 265 °C at 10 mm Hg^g^ | >270 °C; gradually decomposes when heated over 200°C^f^ | 236–237 °C at 5 mm Hg | 330 °C at 1 atm
Density | 0.9727 g/cm^3^ at 25 °C | 0.9681 g/cm^3^ at 20 °C^d^ | 1.020 g/cm^3^ at 20 °C | 1.2055 g/cm^3^ at 50 °C | 1.162 g/cm^3^ at 25 °C | 1.29 g/cm^3^ at 25 °C^f^ | 1.48 g/cm^3^ at 25 °C | 1.425 g/cm^3^ at 20 °C
Odor | Odorless | Specific odor^c^ | Sweetish, butyl-like | Slightly aromatic odor resembling phenol | Odorless; very slightly aromatic^h^ | Mild odor^f^ | Mild odor | Slight odor
Solubility:
Water | 0.28 g/L at 25 °C | Very soluble in water^c^; 0.05% in water^c^ and 6.3% water in TnBP^c^ | 1.1 g/L at 25 °C | 0.0019 g/L at 25 °C | 0.00036 g/L at 25 °C | 1.2 g/L at 25 °C | 7 mg/L at 24 °C | 7.0 g/L (temperature not specified)
Organic solvent(s) | Soluble in diethyl ether, benzene, carbon disulfide; miscible with ethanol | Very soluble in benzene, ether, and ethanol^d^ | Soluble in most organic liquids; soluble in mineral oil; insoluble or limited solubility in glycerol, glycols, certain amines | Very soluble in carbon tetrachloride; soluble in alcohol, benzene, ether, chloroform and acetone; insoluble in petroleum | Miscible with all the common solvents and thinners | Soluble in most organic solvents; insoluble in water^f^ | Soluble in most organic solvents | Soluble in most organic solvents; soluble in carbon tetrachloride, alcohols, esters, ketones, and aromatic hydrocarbons; very slightly soluble in aliphatic hydrocarbons; insoluble in benzene
Other | Miscible with most solvents and diluents | No data | No data | Soluble in most lacquers, solvents thinners, and oils | Miscible with vegetable oil; Miscible with lindseed oil, china wood oil, castor oil^g^ | No data | No data | No data
Log K_ow_ | 4.00 | 3.60 (estimated)^e^ | 3.75 | 4.59 | 5.11 | 2.59 | 3.65 | 1.44
Vapor pressure | 1.13×10^−3^ mm Hg at 25 °C | 0.0128 mm Hg at 25 °C (estimated)^e^ | 0.03 mm Hg at 150 °C | 6.28×10^−6^ mm Hg at 25 °C | 6.00×10^−7^ mm . Hg at 25 °C (extrapolated)^i^ | 2.02×10^−5^ mm Hg at 25 °C | 5.2 ×10^−2^ mm Hg at 25 °C (estimated)^e^ | 6.125×10^−2^ mm Hg at 25 °C
Autoignition temperature | >482 °C^b^ | No data | No data | No data | No data | No data | No data | 1,115 °C
Flashpoint | 146 °C | 175 °C (Cleveland)^c^ | 223 °C | 220 °C | 257 °C^h^ | No data | 252 °C | 216 °C
Flammability limits in air | Combustible | No data | Combustible | Noncombustible | No data | No data | No data | Combustible
Conversion factors | 1 ppm=10.89 mg/m^3b^ | No data | No data | 1 ppm=13.32 mg/m^3^ | No data | No data | No data | 1 ppm=11.65 mg/m^3^
Explosive limits | No data | No data | No data | No data | No data | No data | No data | No data

a All information obtained from HSDB 2009, 2011 and ChemIDplus 2009, 2011, except where noted.

b NIOSH 2005a.

c LANXESS 2005.

d Lide 2008.

e EPA 2009h.

f Ashford 1994.

g O’Neil et al. 2006.

h IPCS 1990.

i Boethling and Cooper 1985.