# 9 REFERENCES

*Not cited in text

ACGIH. 2001. Documentation of the threshold limit values and biological exposure indices. Phenol. 7th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2005. Threshold limit values for chemical substances and physical agents and biological indices. Cincinnati, OH: American Conference of Government Industrial Hygienists.
Achilli G, Cellerino GP, d'Eril GM, 1995. Simultaneous determination of 27 phenols and herbicides in water by high-performance liquid chromatography with multi-electrode electrochemical detection. J Chromatogr 697:357–362.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Adinolfi M. 1985. The development of the human blood-csf-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology.
Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Agency for Toxic Substances and Disease Registry. 2006. Case studies in environmental medicine. Benzene toxicity. Atlanta, GA: Agency for Toxic Substances and Disease Registry. www.atsdr.cdc.gov. March 24, 2006.
Ahmed N, Hale K. 1994. A microassay for urinary phenol using capillary gas chromatography and optimised enzymic hydrolysis. Clin Chim Acta 230:201–208.7834870
Al-Harazin IM, Nakhla GF, Farooq S. 1991. Start-up of sequencing batch reactors for toxic wastewater treatment. J Environ Sci Health A 26:673–687.
Altman PK, Dittmer DS. 1974. Biological handbooks: Biology data book. Volume III, 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987-2008, 2041.
Amlacher E, Rudolph C. 1981. The thymidine incorporation inhibiting screening system (TSS) to test carcinogenic substances (a nuclear DNA synthesis suppressive short term test). Arch Geschwulstforsch 51:605–610.7337543
Amlathe S, Upadhyay S, Gupta VK. 1987. Spectrophotometric determination of trace amounts of phenol in wastewater and biological fluids. Analyst 112:1463–1465.3434826
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically-based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives. Aberdeen Proving Ground, MD: U.S. Army Chemical Research Development and Engineering Center.
APHA. 1998a. Method 5530c. Chloroform extraction method. In: Clesceri LS, Greenberg AE, Eaton AD, eds. Standard methods for the examination of water and wastewater. 20th. Washington, DC: American Public Health Association. American Water Works Association. Water Environmental Federation, 5–45 to 5–43.
APHA. 1998b. Method 6420B. Liquid-liquid extraction gas chromatographic method. In: Clesceri LS, Greenberg AE, Eaton AD, eds. Standard methods for the examination of water and wastewater. 20th. Washington, DC: American Public Health Association. American Water Works Association. Water Environmental Federation, 6–73 to 6–78.
Aranyi C, O'Shea WJ, Graham JA, 1986. The effects of inhalation of organic chemical air contaminants on murine lung host defenses. Fundam Appl Toxicol 6:713–720.3519345
Artiola-Fortuny J, Fuller WH. 1982. Adsorption of some monohydroxybenzene derivatives by soils. Soil Sci 133(1):18–26.
Atkinson R, Aschmann SM, Winer AM. 1987. Kinetics of the reactions of NO_3_ radicals with a series of aromatic compounds. Environ Sci Technol 21:1123–1126.
Axelsson G, Lutz C, Rylander R. 1984. Exposure to solvents and outcome of pregnancy in university laboratory employees. Br J Ind Med 41:303–312.
Baj Z, Majewska E, Zeman K, 1994. The effect of chronic exposure to formaldehyde, phenol and organic chlorohydrocarbons on peripheral blood cells and the immune system in humans. J Invest Allergol Clin Immunol 4:186–191.
Baker MD, Mayfield CI. 1980. Microbial and nonbiological decomposition of chlorophenols and phenol in soil. Water Air Soil Pollut 13:411–424.
Baker EL, Landrigan PJ, Bertozzi PE, 1978. Phenol poisoning due to contaminated drinking water. Arch Environ Health 33:89–94.646461
Baldwin MK, Selby MA, Bloomberg H. 1981. Measurement of phenol in urine by the method of Van Haaften and Sie: A critical appraisal. Analyst 106:763–767.7294359
Ballinger LN, Cross SE, Roberts MS. 1995. Availability and mean transit times of phenol and its metabolites in the isolated perfused rat liver: Normal and retrograde studies using tracer concentrations of phenol. J Pharm Pharmacol 47:949–956.8708991
Barale R, Marrazzini A, Betti C, 1990. Genotoxicity of two metabolites of benzene: Phenol and hydroquinone show strong synergistic effects in vivo. Mutat Res 244:15–20.2336068
Baranowska-Dutkiewicz B. 1981. Skin absorption of phenol from aqueous solutions in men. Int Arch Occup Environ Health 49:99–104.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
Behl CR, Linn EE, Flynn GL, 1983. Permeation of skin and eschar by antiseptics. I: Baseline studies with phenol. J Pharm Sci 72:391–397.6864477
Bentur Y, Shoshani O, Tabak A, 1998. Prolonged elimination of half-life of phenol after dermal exposure. Clin Toxicol 36(7):707–711.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Berman E, Schlicht M, Moser VC, 1995. A multidisciplinary approach to toxicological screening: I. Systemic toxicity. J Toxicol Environ Health 45:127–143.7783250
Beveridge T. 1997. Haze and cloud in apple juices. Crit Rev Food Sci Nutr 37:75–91.9067089
Beyrouty P. 1998. Final report: A 13-week neurotoxicity study of phenol administered in the drinking water to the rat, with TSCA notice of receipt of test data. Chemical Manufacturers Association. Submitted to U.S. Environmental Protection Agency under TSCA Section 4. OTS0559602.
Bieniek G. 1994. Concentrations of phenol, o-cresol, and 2,5-xylenol in the urine of workers employed in the distillation of the phenolic fraction of tar. Occup Environ Med 51:354–356.8199688
Bieniek G, Wilczok T. 1986. Separation and determination of phenol, α-naphthol, m- and p-, o-cresols and 2,5-xylenol and catechol in the urine after mixed exposure to phenol, naphthalene, cresols and xylenols. Br J Ind Med 43:570–571.3730312
Boatto G, Nieddu M, Carta A, 2004. Determination of phenol and o-cresol by GC/MS in a fatal poisoning case. Forensic Sci Int 139(2–3):191–194.15040915
Bois FY, Smith MT, Spear RC. 1991. Mechanisms of benzene carcinogenesis: Application of a physiological model of benzene pharmacokinetics and metabolism. Toxicol Lett 56:283–298.2035176
Boutwell RK, Bosch DK. 1959. The tumor-promoting action of phenol and related compounds for mouse skin. Cancer Res 19:413–424.13652126
Boyd SA. 1982. Adsorption of substituted phenols by soil. Soil Sci 134:337–343.
Boyd SA, Shelton DR, Berry D, 1983. Anaerobic biodegradation of phenolic compounds in digested sludge. Appl Environ Microbiol 46:50–54.6614908
Brandorff NP, Flyvhokm M-A, Beck ID, 1995. National survey on the use of chemicals in the working environment. Estimated exposure events. Occup Environ Med 52:454–463.7670620
Briggs GG. 1981. Theoretical and experimental relationships between soil adsorption, octanol-water partition coefficients, water solubilities, bioconcentration factors and the parachor. J Agric Food Chem 29:1050–1059.
Brown VK H, Box VL, Simpson BJ. 1975. Decontamination procedures for skin exposed to phenolic substances. Arch Environ Health 30:1–6.1109265
Bruce RM, Santodonato J, Neal MW. 1987. Summary review of the health effects associated with phenol. Toxicol Ind Health 3:535–568.3324392
Budavari S, O'Neil MJ, Smith A, , eds. 1989. Phenol. The Merck index, 11th ed. Rahway, NJ: Merck & Co., Inc., 1150.
Bulsiewicz H. 1977. The influence of phenol on chromosomes of mice (Mus musculus) in the process of spermatogenesis. Folia Morphol (Warsaw) 36:13–22.
Burchell B, Coughtrie MW H. 1997. Genetic and environmental factors associated with variation of human xenobiotic glucuronidation and sulfation. Environ Health Perspect 105:739–747.9255555
Buxton IL O. 2006. Pharmacokinetics and pharmacodynamics. The dynamics of drug absorption, distribution, action, and elimination. In: Brunton LL, Lazo JS, Parker KL, eds., Goldman & Gilman’s the pharmacological basis of therapeutics. 11^th^ ed. New York, NY: McGraw-Hill, 1–39.
Cal EP A. 2003. Consideration of chemicals known to the state to cause reproductive toxicity. Phenol. In: Staff presentations for developmental and reproductive toxicant identification committee meeting held on October 19, 2003. California Environmental Protection Agency, Office of Environmental Health Hazard Assessment. http://www.oehha.ca.gov/prop65/public_meetings/101603dartmeetmat.html. January 18, 2008.
Campbell N, Van Loon JA, Weinshilboum RM. 1987. Human liver phenol sulfotransferase: Assay conditions, biochemical properties and partial purification of isozymes of the thermostable form. Biochem Pharmacol 36:1435–1446.3472524
Canonica S, Jans U, Stemmler K, 1995. Transformation kinetics of phenols in water: Photosensitization by dissolved natural organic material and aromatic ketones. Environ Sci Technol 29:1822–1831.22176456
Capel ID, French MR, Millburn P, 1972. Fate of [^14^C]-phenol in various species. Xenobiotica 2:25–34.4211177
Cassidy MK, Houston JB. 1984. In vivo capacity of hepatic and extra hepatic enzymes to conjugate phenol. Drug Metab Dispos 12:619–624.6149914
Chapman DE, Namkung MJ, Juchau MR. 1994. Benzene and benzene metabolites as embryotoxic agents: Effects on cultured rat embryos. Toxicol Appl Pharmacol 128(1):129–137.8079346
Chen CS, Zoltek J Jr. 1995. Organic priority pollutants in wetland-treated leachates at a landfill in central Florida. Chemosphere 31:3455–3464.
Chen H, Eastmond DA. 1995a. Synergistic increase in chromosomal breakage within the euchromatin induced by an interaction of the benzene metabolites phenol and hydroquinone in mice. Carcinogenesis 16:1963–1969.7543378
Chen H, Eastmond DA. 1995b. Topoisomerase inhibition by phenolic metabolites: A potential mechanism for benzene's clastogenic effects. Carcinogenesis 16:2301–2307.7586126
Chowdhury JR, Novikoff PM, Chowdhury NR, 1985. Distribution of UDPglucuronosyltransferase in rat tissue. Proc Natl Acad Sci USA 82:2990–2994.3921970
Chung HY. 1999. Volatile components in fermented soybean (Glycine max) curds. J Agric Food Chem 47:26902697.
Ciranni R, Barale R, Marrazzini A, 1988. Benzene and the genotoxicity of its metabolites. I. Transplacental activity in mouse fetuses and in their dams. Mutat Res 208:61–67.3367930
Clark TP, Piskin R. 1977. Chemical quality and indicator parameters for monitoring landfill leachate in Illinois. Environ Geol 1:329–340.
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
CMA. 1998. Two-week (ten day) inhalation toxicity and two-week recovery study of phenol vapor in the rat. Chemical Manufacturers Association. Submitted to U.S. Environmental Protection Agency under TSCA Section 4. OTS0559328.
CMR. 2005. Phenol: Chemical Profile. Chemical Market Reporter, 34–35. May 23–29, 2005.
Coan ML, Baggs RB, Bosmann HB. 1982. Demonstration of direct toxicity of phenol on kidney. Res Commun Chem Pathol Pharmacol 36:229–239.7100628
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Contr Fed 56:898–908.
Conning DM, Hayes MJ. 1970. The dermal toxicity of phenol: An investigation of the most effective first-aid measures. Br J Ind Med 27:155–159.5428634
Constan AA, Yang RS H, Baker DC, 1995. A unique pattern of hepatocyte proliferation in F344 rats following long-term exposures to low levels of a chemical mixture of groundwater contaminants. Carcinogenesis 16:303–310.7859362
CPSC. 2005. Hazardous substances and articles: Administration and enforcement regulations. Substances named in the Federal Caustic Poison Act. Washington, DC: Consumer Product Safety Commission. Code of Federal Regulations. 15 CFR 1500.129. http://www.access.gpo.gov/nara/cfr/cfr-table-search.html#page1. March 08, 2006.
Crawford DW, Bonnevie NC, Wenning RJ. 1995. Sources of pollution and sediment contamination in Newark Bay, New Jersey. Ecotoxicol Environ Safety, 30:85–100.7540541
Crebelli R, Conti G, Carere A. 1987. On the mechanism of mitotic segregation induction in Aspergillus nidulans by benzene hydroxy metabolites. Mutagenesis 2:235–238.3325750
Cronin TD, Brauer RO. 1949. Death due to phenol contained in foille. JAMA 139:777–778.
Cronn DR, Charlson RJ, Knights RL, 1977. A survey of the molecular nature of primary and secondary components of particles in urban air by high-resolution mass spectrometry. Atmos Environ 11:929–937.
Dalin NM, Kristoffersson R. 1974. Physiological effects of a sublethal concentration of inhaled phenol on the rat. Ann Zool Fenn 11:193–199.
Darisimall. 2006. Sore throat lozenges and sprays. http://store.darisimall.com/sothlosp.html. July 27, 2006.
Davies MI, Lunte CE. 1996. Simultaneous microdialysis sampling from multiple sites in the liver for the study of phenol metabolism. Life Sci 59:1001–1013.8809214
Davis EM, Murray HE, Liehr JG, 1981. Basic microbial degradation and chemical byproducts of selected organic compounds. Water Res 15:1125–1127.
De Ceaurriz JC, Micillino JC, Bonnet P, 1981. Sensory irritation caused by various industrial airborne chemicals. Toxicol Lett (Amst) 9: 137–144.
Deichmann WB. 1944. Phenol studies. V. The distribution, detoxification, and excretion of phenol in the mammalian body. Arch Biocef 3:345–355.
Deichmann WB, Keplinger ML. 1981. Phenols and phenolic compounds. In: Clayton GD, Clayton FE, eds. Patty's industrial hygiene and toxicology, 3rd ed. New York, NY: John Wiley and Sons, Inc., 2567–2627.
Deichmann WB, Witherup S. 1944. Phenol studies. VI: The acute and comparative toxicity of phenol and o-, m-, and p-cresols for exp erimental animals. J Pharmacol Exp Ther 80:233–240.
Deichmann WB, Kitzmiller KV, Witherup BS. 1944. Phenol studies. VII. Chronic phenol poisoning, with special reference to the effects upon experimental animals of the inhalation of phenol vapor. Am J Clin Pathol 14:273–277.
Delfino JJ, Dube DJ. 1976. Persistent contamination of ground water by phenol. J Environ Sci Health A 11:345–355.
*Della Pietra G, Illiano G, Soscia M. 1967. Glycuronic acid and glycuronamide detoxicating activity. Biochem Pharmacol 16:1571–1573.6049424
Demerec M, Bertran G, Flint J. 1951. A survey of chemicals for mutagenic action on E. coli. American Naturalist 85:119–136.
Di Corcia A, Bellioni A, Madbouly MD, 1996. Trace determination of phenols in natural waters. Extraction by a new graphitized carbon black cartridge followed by liquid chromatography and reanalysis after ph enol derivatization. J Chromatogr 733:383–393.
Doan HM, Keith L, Shennan AT. 1979. Phenol and neonatal jaundice. Pediatrics 64:324–325.481977
DOE. 1997. Method OM100R: Semivolatile organic compounds in multimedia samples by capillary column ion trap MS. Idaho Falls, ID: U.S. Department of Energy, National Analytical Management Program. http://web1.er.usgs.gov/nemi/method_pdf/4795.pdf. April 18, 2006.
DOE. 1987. Uptake and fate of phenol aniline and quinoline in terrestrial plants. In: Gray RH, ed. Health and environmental research on complex organic mixtures. U.S. Department of Energy, 631–641.
Dosemeci M, Blair A, Stewart PA, 1991. Mortality among industrial workers exposed to phenol. Epidemiology 2:188–193.2054400
Douglas CC. 1972. Gas chromatographic determination of phenolic compounds in drug preparations: Collaborative study. J Assoc Off Anal Chem 55:610–612.5044745
*Ducis I, Norenberg L-OB, Norenberg MD. 1990. Effect of phenol and sodium octanoate on the astrocyte benzodiazepine receptor. Brain Res 514:349–351.2162713
Dumont JP, Adda J. 1978. Occurrence of sesquiterpenes in mountain cheese volatiles. J Agric Food Chem 26:364–367.
Durback-Morris LF, Scharman EJ. 1999. Accidental intranasal administration of phenol. Vet Hum Toxicol 41(3):157.10349706
Eastmond DA, Smith MT, Ruzo LO, 1986. Metabolic activation of phenol by human myeloperoxidase and horseradish peroxidase. Mol Pharmacol 30:674–679.3023815
Edwards RD, Jurvelin J, Saarela K, 2001. VOC concentrations measured in personal samples and residential indoor, outdoor and workplace microenvironments in EXPOLIS- Helsinki, Finland. Atmos Environ 35(27):4829–4841.
Edwards VT, Jones BC, Hutson DH. 1986. A comparison of the metabolic fate of phenol, phenyl glucoside and phenyl 6-O-malonyl-glucoside in the rat. Xenobiotica 16:801–807.3765660
Ehrlich GG, Goelitz DF, Godsy EM, 1982. Degradation of phenolic contaminants in ground water by anaerobic bacteria: St. Louis Park, MN. Ground Water 20:703–710.
Eichelberger JW, Kerns EH, Olynyk P, 1983. Precision and accuracy in the determination of organics in water by fused silica capillary column gas chromatography/mass spectrometry and packed column gas chromatography/mass spectrometry. Anal Chem 55:1471–1479.
Elder VA, Proctor BL, Hites RA. 1981. Organic compounds found near dump sites in Niagara Falls, NY. Environ Sci Technol 15:1237–1243.22299705
EPA. 1979a. Atmospheric reaction products of organic compounds. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA5601279001. PB301384.
EPA. 1979b. Microbial degradation of organochlorine compounds in estuarine waters and sediments. In: Proceedings Workshop: Microbial Degradation Pollution Marine Environment, 1978. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600979012.
EPA. 1979c. Source assessment: Manufacture of acetone and phenol from cumene. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600279019d. PB80150592.
EPA. 1980. Ambient water quality criteria document for phenol. Washington, DC: U.S. Environmental Protection Agency. EPA440580001A. PB81117772.
EPA. 1981a. Exposure and risk assessment for phenol (revised). Washington, DC: U.S. Environmental Protection Agency. PB85221695.
EPA. 1981b. Treatability manual. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600282001A, I.8. 1–1-1–5.
EPA. 1982. Test methods. Methods for organic chemical analysis of municipal and industrial wastewater. Method No. 604 and 625. Cincinnati, OH: U.S. Environmental Protection Agency.
EPA. 1986a. Reference values for risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. Environmental Criteria and Assessment Office, Office of Health and Environmental Assessment.
EPA. 1986b. Method 8250: Gas chromatography/mass spectrometry for semivolatile organics: Packed column technique. Test methods for evaluating solid waste. SW-846. 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986c. Method 8270: Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique. Test methods for evaluating solid waste. SW-846. 3rd ed. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1987. Health and environmental effects profile for phenol. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1994a. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. Office of Research and Development. EPA6008900066F.
EPA. 1994b. Semivolatile organic compounds by gas chromatography/mass spectrometry. Method 8250A. In: Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998. Method 8070D: Semivolatile organic compounds by GC/MS. Draft update IVA of SW-846 on-line. U.S. Environmental Protection Agency, Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8270d.pdf. April 18, 2006
EPA. 1999. Evaluation and application of methods for estimating children’s exposure to persistent organic pollutants in multiple media. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. PB99134942.
EPA. 2000a. Method 528: Determination of phenols in drinking water by solid phase extraction and capillary column gas chromatography/mass spectrometry (GC/MS) Methods for t he determination of organic and inorganic compounds in drinking water, Volume 1. Washington, DC: U.S. Environmental Protection Agency. EPA815R00014. http://nepis.epa.gov/pubtitleOW.htm. April 18, 2006.
EPA. 2000b. Method 8041A: Phenols in aqueous and non-aqueous samples by capillary GC/FID or GC/ECD and single or dual columns. Draft update IVB of SW-846 on-line. U.S. Environmental Protection Agency, Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8041a.pdf. April 18, 2006.
EPA. 2000c. Benchmark dose technical guidance document. Washington, DC: U.S. Environmental Protection Agency. EPA630R00001.
EPA. 2001a. Method 604: Phenols. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 136, Appendix A. http://web1.er.usgs.gov/nemi/method_pdf/4789.pdf. April 18, 2006.
EPA. 2001b. Method 1625: Semivolatile organic compounds by isotope dilution GCMS. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 136, Appendix A. http://web1.er.usgs.gov/nemi/method_pdf/4686.pdf. April 18, 2006.
EPA. 2001c. Method 635: Base/neutrals and acids. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A. http://web1.er.usgs.gov/nemi/method_pdf/4714.pdf. April 20, 2006.
EPA. 2002. Toxicological review of phenol. In support of summary information on the Integrated Risk Information System (IRIS). Washington, DC: U.S. Environmental Protection Agency. EPA635R02006.
EPA. 2003. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F03016. http://epa.gov/safewater/mcl.html. March 07, 2006.
EPA. 2004. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. March 07, 2006.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006a. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://epa.gov/oppt/aegl/chemlist.htm. March 22, 2006.
EPA. 2006b. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cf r116.4.pdf. January 8, 2008.
EPA. 2006c. Effluent guidelines and standards. Toxic pollutants. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15. http://www.epa.gov/epacfr40/chapt-1.info/chi-toc.htm. March 08, 2006.
EPA. 2006d. Hazardous air pollutants. Clean Air Act. Washington, DC: U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. March 07, 2006.
EPA. 2006e. Identification and listing of hazardous waste. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.epa.gov/epacfr40/chapt-1.info/chi-toc.htm. March 07, 2006.
EPA. 2006f. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 8, 2008.
EPA. 2006g. Table 117.3. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cf r117.3.pdf. January 08, 2008.
EPA. 2006h. Designation of hazardous substances. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cf r302.4.pdf. January 08, 2008.
EPA. 2006i. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/epacfr40/chapt-1.info/chi-toc.htm. March 08, 2006.
EPA. 2006j. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr372.65.pdf. January 08, 2008.
EPA. 2006k. Tolerances and exemptions from tolerances for pesticide chemicals in food. Aluminum sulfate. Phenol. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.920. http://www.epa.gov/epacfr40/chapt-1.info/chi-toc.htm. March 08, 2006.
EPA. 2006l. Tolerances and exemptions from tolerances for pesticide chemicals in food. Phenol. Aluminum oxide. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.930. http//www.epa.gov/epacfr40/chapt-1. March 08, 2006.
EPA. 2006m. Water quality standards. Toxics criteria for those states not complying with Clean Water Act Section 303(c)(2)(B). Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 131.36. http://www.epa.gov/epacfr40/chapt-1.info/chi-toc.htm. March 08, 2006.
EPA. 2007. Method 8041A. Phenols by gas chromatography. Test methods for evaluation solid waste. U.S. Environmental Protection Agency. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8041a.pdf. July 31, 2008.
Erexson GL, Wilmer JL, Kligerman AD. 1985. Sister chromatid exchange induction in human lymphocytes exposed to benzene and its metabolites in vitro. Cancer Res 45:2471–2477.3986787
FDA. 2005. Beverages. Bottled water. Washington, DC: U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://a257.g.akamaitech.net/7/257/2422/01apr20051500/edocket.access.gpo.gov/cfr_2005/aprqtr/pdf/21cfr165.110.pdf. January 08, 2008.
FDA. 2006. Everything added to food in the United States. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/eafus.html. April 11, 2006.
FEDRIP. 2006. Phenol. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Fielding M, Gibson TM, McLoughlin K, 1981. Organic micropollutants in drinking water. TR-159. Medmenham, England. Water Research Center.
Flickinger CW. 1976. The benzenediols: Catechol, resorcinol and hydroquinone. A review of the industrial toxicology and current industrial exposure limits. Am Ind Hyg Assoc J 37:596–606.983950
Florin I, Rutberg L, Curvall M, 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames' test. Toxicology 18:219–232.
Fomon SJ. 1966. Body composition of the infant. Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Forum for Scientific Excellence, Inc. 1990. Index of hazardous contents of commercial products in schools and colleges. Philadelphia, PA: JB Lippincott Co., 97, 109, 110, 145, 179.
Foxall PJ D, Bending MR, Gartland KI, 1989. Acute renal failure following accidental cutaneous absorption of phenol: Application of NMR urinalysis to monitor the disease process. Human Toxicol 9:491–496.
Freitag D, Lay JP, Korte F. 1984. Environmental hazard - Test results as related to structures and transplantation into the environment. In: Kaiser KLE, ed. Quantitative Structure Activity Relationships Environmental Toxicology Proceedings Workshop. Boston, MA: D. Reidel Publishing Co., 111–136.
French MR, Bababunmi EA, Golding RR 1974. The conjugation of phenol, benzoic acid, 1-naphthylacetic acid and sulfadimethoxine in the lion, civet, and genet. FEBS Lett 46:134–137.4418427
Fuhro R, Fromm D. 1978. Effects of compounds chemically related to salicylate on isolated antral mucosa of rabbits. Gastroenterology 75:661–667.710834
Gaffney JS, Streit GE, Spall WD, 1987. Beyond acid rain: Do soluble oxidants and organic toxins interact with SO2 and NOX to increase ecosystem effects? Environ Sci Technol 21:519–524.19994967
Gardner W, Cooke EI, Cooke RW I. 1978. Handbook of chemical synonyms and trade names. Boca Raton, FL: CRC Press, 150, 554.
Ghantous H, Danielsson BR. 1986. Placental transfer and distribution of toluene, xylene and benzene, and their m etabolites during gestation in mice. Biol Res Pregnancy Perinatol 7:98–105.3778990
Gingell R, O’Donoghue JO, Staab RJ, 2001. Phenol and phenolics. In: Bingham E, Cohrssen B, Powell Ch, eds. Patty’s toxicology. 5th ed. New York, NY: John Wiley & Sons, 383–398.
Giwerceman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gocke E, King MT, Eckhardt K, 1981. Mutagenicity of cosmetics ingredients licensed by the European communities. Mutat Res 90:91–109.6799819
Goerlitz DF, Troutman DE, Gody EM, 1985. Migration of wood-preserving chemical in contaminated groundwater in a sand aquifer at Pensacola, Florida. Environ Sci Technol 19:955–961.
Goldfrank LR, Flomenbaum NE, Lewin NA, 2002. Phenol. In: Goldfrank’s toxicologic emergencies. 7th ed. New York, NY: McGraw-Hill, 1283–1284.
Goncharuk VV, Milyukin MV. 1999. Evaluation of contamination level of Dnieper River Basin by organic and inorganic toxicants. In: Baveye PH, Block JC, Goncharuk VV eds. Bioavailability of organic xenobiotics in the environment. Netherlands: Kluwer Academic Publishers, 35–56.
Gossett RW, Brown DA, Young DR. 1983. Predicting the bioaccumulation of organic compounds in marine organisms using octanol/water partition coefficients. Marine Pollut Bull 14:387–392.
*Gould JP, Weber WJ Jr. 1976. Oxidation of phenols by ozone. J Water Pollut Control Fed 48:47–60.
Graedel TE. 1978. Chemical compounds in the atmosphere. New York, NY Academic Press, 256.
Griffiths GJ. 1973. Fatal acute poisoning by intradermal absorption of phenol. Med Sci Law 13:46–48.4721838
Gross BG. 1984. Cardiac arrhythmias during phenol face peeling. Plastic Reconst Surg 73:590–594.
Guerin MR, Jenkins RA, Tomkins BA. 1992. The chemical nature of environmental tobacco smoke: Composition and measurement. Chelsea, MI: Lewis Publishers, Inc., 24, 27, 39.
Gut I, Nedelcheva V, Soucek P, 1996. Cytochromes P450 in benzene metabolism and involvement of their m etabolites and reactive oxygen species in toxicity. Environ Health Perspect 104:1211–1218.9118895
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for r isk assessment. Washington, DC: International Life Sciences Institute Press, 1–285.
Haddad LM, Shannon MW, Winchester JF. 1998. Phenol and related agents. In: Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA: WB Saunders Company, 956–960.
Haider K, Jagnow G, Kohnen R, 1974. [Degradation of chlorinated benzol, phenol and cyclohexane derivatives by soil bacteria that utilize benzol and phenol under aerobic conditions.] Arch Microbiol 96:183–200. (German)4134769
Handson PD, Hanrahan PD. 1983. A rapid gas chromatographic method for the determination of free phenol in blood. J Agric Food Chem 31:447–448.6853868
Hawley GG. 1981. The condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold Co, 796.
Haworth S, Lawler T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Suppl 1:3–142.
Hawthorne SB, Sievers RE. 1984. Emission of org anic air po llutants from shale oil wastewaters. Environ Sci Technol 18:483–490.22247953
HazDat. 2006. Phenol. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. April 06, 2006.
Healy JB, Young LY. 1978. Catechol and phenol degradation by a methanogenic population of bacteria. Food Microbiol Toxicol 35:216–218.
Heaton GD, Renwick AG. 1991. The effects of high dietary concentrations of sodium saccharin on in vivo metabolism of xenobiotics in rats. Food Chem Toxicol 29(5):305–312.1905673
Heikkila PR, Hameila M, Pyy L, 1987. Exposure to creosote in the impregnation and handling of impregnated wood. Scand J Work Environ Health 13:431–437.3433045
Heller VG, Pursell L. 1938. Phenol-contaminated waters and their physiological action. J Pharmacol Exp Ther 63:99–107.
Hendrickson HP, Sahafayan M, Bell MA, 1994. Relationship of flavonoid oxidation potential and effect on rat hepatic microsomal metabolism of benzene and phenol. J Pharm Biomed Anal 12:335–341.8031932
Henschler R, Glatt HR. 1995. Induction of cytochrome P4501A1 in haemopoietic stem cells by hydroxylated metabolites of benzene. Toxicol In Vitro 9:453–457.20650112
Hernberg S, Kurppa K, Ojajārvi J, 1983. Congenital malformations and occupational exposure to disinfectants: A case-referent study. Scan J Work Environ Health 9:55.
Hinkel VG K, Kintzel HW. 1968. Phenolvergiftungen bei neugeborenen durch kutane resorption. Dtsch Gesundheitsw 23:2420–2422.5716265
Hiser MF, Kropscott BE, McGuirk RJ, 1994. Pharmacokinetics, metabolism and distribution of 14C-Phenol in Fischer 344 rats after oral gavage, drinking water and inhalation exposure. Dow Chemical Company. Submitted to U.S. Environmental Protection Agency under TSCA Section 8D. Study ID: K-002727–022. OTS0557473.
Ho C, Lee KN, Jin QZ. 1983. Isolation and identification of volatile flavor compounds in fried bacon. J Agric Food Chem 31:336–342.
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoff RM, Chan K. 1987. Measurement of polycyclic aromatic hydrocarbons in the air along the Niagara River. Environ Sci Technol 21:556–561.19994975
Hoffman GM, Dunn BJ, Morris CR, 2001. Two-week (ten-day) inhalation toxicity and two-week recovery study of phenol vapor in the rat. Int J Toxicol 20:45–52.11288933
Hoffmann MJ, Ji S, Hedli CC, 1999. Metabolism of [^14^C]phenol in isolated perfused mouse liver. Toxicol Sci 49:40–47.10367340
Holland AJ, Youssef M. 1978. A complication of subarachnoid phenol blockade. Anaesthesia 34:260–262.
Horch R, Spilker G, Stark GB. 1994. Phenol burns and intoxications. Burns 20:45–50.8148075
Hoshika Y, Nihei Y, Muto G. 1981. Pattern display for characterization of trace amounts of odorants discharged from nine odor sources. Analyst (London) 106:1187–1202.
Hotchkiss SA M, Hewitt P, Caldwell J. 1992. Percutaneous absorption of nicotinic acid, phenol, benzoic acid and triclopyr butoxyethyl ester through rat and human skin in vitro: Further validation of an in vitro model by comparison with in vivo data. Food Chem Toxicol 30:891–899.1427512
HSDB. 2008. Phenol. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. July 31, 2008.
Hsieh GC, Sharma RP, Parker RD R, 1992. Immunological and neurobiochemical alterations induced by repeated oral exposure of phenol in mice. Eur J Pharmacol 228:107–114.1446716
Hu JY, Aizawa T. 2003. Quantitative structure-activity relationships for estrogen receptor binding affinity of phenolic chemicals. Water Res 37(6):1213–1222.12598185
Huang Z, Zhou W, Zhou C, 2003. Determination of semivolatile compounds in drinking water by tandem mass spectrometric detection. Bull Environ Contam Toxicol 71(5):1026–1033.14705665
Hughes MF, Hall LL. 1995. Disposition of phenol in rat after oral, dermal, intravenous, and intratracheal administration. Xenobiotica 25:873–883.8779227
Humphrey MJ, Filer CW, Jeffery DJ, 1980. The availability of carfecillin and its phenol moiety in rat and dog. Xenobiotica 10:771–778.7456492
Hunter DM, Timerding BL, Leonard RB, 1992. Effects of isopropyl alcohol, ethanol, and polyethylene glycol/industrial methylated spirits in the treatment of acute phenol burns. Ann Emerg Med 21:1303–1307.1416322
IARC. 1986. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 38. Tobacco smoking. Lyon, France: World Health Organization, International Agency for Research on Cancer, 104–105.
IARC. 1989. Phenol In: IARC Monographs on the evaluation of carcinogenic risk of chemicals to humans, Vol 47. Some organic solvents, resin monomers and related compounds, pigments and occupational exposures in paint manufacturing and painting. Lyon, France: World Health Organization, International Agency for Research on Cancer, 263–287.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www.cie.iarc.fr/monoeval/crthall.html. March 08, 2006.
Inoue H, Yokota H, Taniyama H, 1999. 1-Naphthol β-D-glucuronide formed intraluminaly in rat small intestine mucosa and absorbed into the colon. Life Sci 65(15):1579–1588.10574224
IRIS. 2006. Phenol. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. March 8, 2006.
Itoh M. 1995. The role of brain acetylcholine in phenol-induced tremor in mice. Arch Oral Biol 40:365–372.7639639
Iwasaki K, Shiraga T, Takeshita K, 1993. Perinatal development of amine, alcohol and phenol sulfoconjugations in the rat. Res Commun Chem Pathol Pharmacol 81:183–190.8210697
Jansson T, Curvall M, Hedin A, 1986. In vitro studies of biological effects of cigarette smoke condensate. II. Induction of sister chromatid exchanges in human lymphocytes by weakly acidic, semivolatile constituents. Mutat Res 169:129–139.3951466
Jarvis SN, Straube RC, Williams AL J, 1985. Illness associated with contamination of drinking water supplies with phenol. Br Med J 290:1800–1802.3924263
Jay K, Stieglitz L. 1995. Identification and quantification of volatile organic components in emissions of waste incineration plants. Chemosphere 30:1249–1260.
Johansen SS, Hansen AB, Mosboek H, 1997. Identification of heteroaromatic and other organic compounds in ground water at creosote-contaminated sites in Denmark. Ground Water Monit Remed 7:106–115.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190:3–16.6769537
Jungclaus GA, Lopez-Avila V, Hites RA. 1978. Organic compounds in an industrial waste water: A case study of their environmental impact. Environ Sci Technol 12:88–96.
Kaiser HE. 1967. Cancer-promoting effects of phenols in tea. Cancer 20:614–616.6024273
Kamijo Y, Soma K, Fukuda M, 1999. Rabbit syndrome following phenol ingestion. Clin Toxicol 37:509–511.
Kao J, Bridges JW, Faulkner JK. 1979. Metabolism of [^14^C]phenol by sheep, pig, rat. Xenobiotica 9:141–147.473790
Kauppinen TP, Partanen TJ, Nurminen MM. 1986. Respiratory cancers and chemical exposures in the wood industry: A nested case-control study. Br J Ind Med 43:84–90.3947573
Kavlock RJ. 1990. Structure-activity relationships in the developmental toxicity of substituted phenols: In vivo effects. Teratology 41: 43–59.2305374
Kawamoto T, Koga M, Oyama T, 1996. Habitual and genetic factors that affect urinary background levels of biomarkers for organic solvent exposure. Arch Environ Contam Toxicol 30:114–120.8579380
Keith LH. 1976. Identification of organic compounds in unbleached treated Kraft paper mill wastewaters. Environ Sci Technol 10:555–564.
Kenyon EM, Seeley ME, Janszen D, 1995. Dose-, route-, and sex-dependent urinary excretion of phenol metabolites in B6C3F_1_ mice. J Toxicol Environ Health 44:219–233.7853423
Kim D-H, Lee S-K, Chun B-Y, 1994. Illness associated with contamination of drinking water supplies with phenol. J Korean Med Sci 9:218–223.7993588
Kim HJ, Cho JH, Klaassen CD. 1995. Depletion of hepatic 3'-phosphoadenosine 5'-phosphosulfate (PAPS) an d sulfate in rats by xenobiotics that are sulfated. J Pharmacol Exp Ther 275:654–658.7473151
Kincannon DF, Stover EL, Nichols V, 1983. Removal mechanisms for toxic priority pollutants. J Water Pollut Control Fed 55:157–163.
Kobayashi K, Akitake H, Manadge K. 1979. Relation between toxicity and accumulation of various chlorophenols in goldfish. Bull Jap Soc Sci Fish 45:173–175.
Kolachana P, Subrahmanyam VV, Meyer KB, 1993. Benzene and its phenolic metabolites produce oxidative DNA damage in HL60 cells in vitro and in the bone marrow in vivo. Cancer Res 53(5):1023–1026.8439949
Kolpin DW, Furlong ET, Meyer MT, 2002. Pharmaceuticals, hormones, and other organic wastewater contaminants in US streams, 1999–2000: A national reconnaissance. Environ Sci Technol 36:1202–1211.11944670
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
Konasewich D, Traversy W, Zar H. 1978. Status report on organic and heavy metal contaminants in the Lake Erie, Michigan, Huron and Superior Basins. Windsor, Ontario: International Joint Commission Great Lakes Water Quality Board, 161.
Koop DR, Laethem CL, Schnier GG. 1989. Identification of ethanol-inducible P450 isozyme 3a (P450IIE1) as a benzene and phenol hydroxylase. Toxicol Appl Pharmacol 98:278–288.2711391
Koster H, Halsema I, Scholtens E, 1981. Dose-dependent shifts in the sulfation and glucuronidation of phenolic compounds in the rat in vivo and in isolated hepatocytes. The role of saturation of phenolsulfotransferase. Biochem Pharmacol 30:2569–2575.6946775
Kostiainen R. 1995. Volatile organic compounds in the indoor air of normal and sick houses. Atmos Environ 29:693–702.
Kothare PA, Zimmerman CL. 2002. Intestinal metabolism: The role of enzyme localization in phenol metabolite kinetics. Drug Metab Dispos 30(5):586–594.11950792
Kot-Wasik A, Kartanowicz R, Dabrowski D, 2004. Determination of chlorophenols and phenoxyacid herbicides in the Gulf of Gdansk, southern Baltic Sea. Bull Environ Contam Toxicol 73:511–518.15386173
Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes W, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd.
Krishnan K, Andersen M E, Clewell HJ III, 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RS A, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554.
Kuwata K, Uebori M, Yamazaki Y. 1980. Determination of phenol in polluted air as p-nitrobenzeneazophenol derivative by reversed phase high performance liquid chromatography. Anal Chem 52:857–860.
Langford CP, Bartlett R, Haddad LM. 1998. Phenol and related agents. In: Haddad LM, Shannon MW, Winchester JF, eds. Clinical management of poisoning and drug overdose. Philadelphia, PA: Saunders, 956–960.
Lebedev AT, Poliakova OV, Karakhanova NK, 1998. The contamination of birds with organic pollutants in the Lake Baikal region. Sci Total Environ 212:153–162.9573629
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Ped Clin North America 44:55–77.
Legathe A, Hoener B-A, Tozer TN. 1994. Pharmacokinetic interaction between benzene metabolites, phenol and hydroquinone, in B6C3F_1_ mice. Toxicol Appl Pharmacol 124:131–138.8291054
Leuenberger C, Ligocki MP, Pankow JF. 1985. Trace organic compounds in rain. 4. Identities, concentrations and scavenging mechanisms for phenols in urban air and rain. Environ Sci Technol 19:1053–1058.22288749
Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. I. New York, NY: Stockton Press, 153–164.
Lewin JF, Cleary WT. 1982. An accidental death caused by the absorption of phenol through skin. A case report. Forensic Sci Int 19:177–179.7068071
Lewis RJ. 2000. Sax’s dangerous properties of industrial materials. 10th ed. New York, NY: John Wiley & Sons, Inc., 2884–2885.
Lewis RJ. 2001. Hawley's condensed chemical dictionary. 14th ed. New York, NY: John Wiley & Sons, Inc., 857.
Li Y, Qu M, Sun L, 2005. Genotoxicity study of phenol and o-cresol using the micronucleus test and the comet assay. Toxicol Environ Chem 87(1–4):365–372.
Liao TF, Oehme FW. 1981. Tissue distribution and plasma protein binding of [^14^C] phenol in rats. Toxicol Appl Pharmacol 57:220–225.7222038
Lide DR. 2005. CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, 3–422.
Lide DR, Milne GWA. 1994. Phenol. In: Handbook of data on organic compounds. Boca Raton, FL: CRC Press, 3990.
Ling WH, Hanninen O. 1991. Shifting from a conventional diet to an uncooked vegan diet reversibly alters fecal hydrolytic activities in humans. J Nutr 122:924–930.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lo Dico C, Caplan YH, Levine B, 1989. Phenol: Tissue distribution in a fatality. J Forensic Sci 34:1013–1015.2760581
Lopes TJ, Furlong ET. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States, 1992–1995. Environ Sci Technol 20:727–737.
Lopez-Avila V, Northcutt R, Onstot J. 1983. Determination of 51 priority organic compounds after extraction from standard reference materials. Anal Chem 55:881–889.
Ludzack FJ, Ettinger MB. 1960. Chemical structures resistant to aerobic biochemical stabilization. J Water Pollut Control Fed 32:1173–1200.
Lüttke J, Levsen K, Acker K, 1999. Phenols and nitrated phenols in clouds at Mount Brocken. Int J Environ Anal Chem 74:69–89.
Lunte SM, Kissinger PT. 1983. Detection and identification of sulfhydryl conjugates of p-benzoquinone in microsomal incubations of benzene and phenol. Chem-Biol Interact 47:195–212.6652808
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of chemical property estimation methods. Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Co., 15–9 to 15–31.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McDonald JD, Zielinska B, Jujita EM, 2000. Fine particle and gaseous emission rates from residential wood combustion. Environ Sci Technol 34:2080–2091.
McFadden SA. 1996. Phenotypic variation in xenobiotic metabolism and adverse environmental response: Focus on sulfur-dependent detoxification pathways. Toxicology 111:43–65.8711748
*Medinsky MA. 1995. The application of physiologically based pharmacokinetic/pharmacodynamic (PBPK/PD) modeling to understanding the mechanism of action of hazardous substances. Toxicol Lett 79:185–191.7570655
Medinsky MA, Kenyon EM, Schlosser PM. 1995. Benzene: A case study in parent chemical and metabolite interactions. Toxicology 105:225–233.8571360
Mehta R, Hirom PC, Millburn P. 1978. The influence of dose on the pattern of conjugation of phenol and 1-naphthol in nonhuman primates. Xenobiotica 8:445–452.98922
Merliss RR. 1972. Phenol marasmus. Occup Med 14:55–56.
Migaszewski ZM. 1999. Determining organic compound ratios in soils and vegetation of the Holy Cross Mountains, Poland. Water Air Soil Pollut 111(1–4):123–138.
Mill T, Mabey W. 1985. Photochemical transformations. In: Neely WB, Blau GE, eds. Environmental exposure from chemicals. Vol. 1. Boca Raton, FL: CRC Press, 175–216.
Miller BM, Pujadas E, Gocke E. 1995. Evaluation of the micronucleus test in vitro using Chinese hamster cells: Results of four chemicals weakly positive in the in vivo micronucleus test. Environ Mol Mutagen 26:240–247.7588650
Miller JJ, Powell GM, Olavesen AH, 1976. The toxicity of dimethoxyphenol and related compounds in the cat. Toxicol Appl Pharmacol 3:47–57.
Miyagawa M, Takasawa H, Sugiyama A, 1995. The in vivo-in vitro replicative DNA synthesis (RDS) test with hepatocytes prepared from male B6C3F1 mice as an early prediction assay for putative nongenotoxic (Ames-negative) m ouse hepatocarcinogens. Mutat Res 343:157–183.7791810
Monteiro-Riviere NA, Inmann AO, Jackson H, 2001. Efficacy of topical phenol decontamination strategies on severity of acute phenol chemical burns and dermal absorption: In vitro and in vivo studies. Toxicol. Ind. Health 17(4):95–104.12479505
Moreira dos Santos CY, de Almeida Azevedo D, Radler de Aquino Neto F. 2004. Atmospheric distribution of organic compounds from urban areas near a coal-fired power station. Atmos Environ 38(9):1247–1257.
*Morgan RJ, Steller PH. 1994. Acute paraplegia following intrathecal phenol block in the presence of occult epidural malignancy. Anaesthesia 49:142–144.8129124
Morimoto K, Wolff S. 1980. Increase of sister chromatid exchanges and perturbations of cell division kinetics in human lymphocytes by benzene metabolites. Cancer Res 40:118–1193.
Morimoto K, Wolff S, Koizumi A. 1983. Induction of sister-chromatid exchanges in human lymphocytes by microsomal activation of benzene metabolites. Mutat Res 119:355–360.6828070
Morrison JE, Matthews D, Washington R, 1991. Phenol motor point blocks in children: Plasma concentrations and cardiac dysrhythmias. Anesthesiology 75:359–362.1859024
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
Moser VC, Cheek BM, MacPhail RC. 1995. A multidisciplinary approach to toxicological screening: III. Neurobehavioral toxicity. J Toxicol Environ Health 45:173–210.7783252
Mulder GJ, Scholtens E. 1977. Phenol sulphotransferase and uridine diphosphate glucuronyltransferase from rat liver in vivo and in vitro. Biochem J 165:553–559.411489
Muraleedharan TR, Radojevic M, Waugh A, 2000. Chemical characterization of the haze in Brunei Darussalam during the 1998 episode. Atmos Environ 34(17):2725–2731.
Murphy JC, Osterberg RE, Seabaugh VM, 1982. Ocular irritancy responses to various pHs of acids and bases with and without irrigation. Toxicology 23:281–291.6981867
Murray AR, Kisin E, Castranova V, 2007. Phenol-induced in vivo oxidative stress in skin: Evidence for enhanced free radical generation, thiol oxidation, and antioxidant depletion. Chem Res Toxicol 20(12):1769–1777.17922553
*Musto JD, Sane JN, Warner VD. 1977. Quantitative determination of phenol by high-pressure liquid chromatography. J Pharm Sci 66:1201–1202.894511
Nagel R, Adler HI, Rao TK. 1982. Induction of filamentation by mutagens and carcinogens in a ion-mutant of Escherichia coli. Mutat Res 105:309–312.6755237
*Nanbo T. 1993. Influence of dietary lipids on glucuronidation and sulfation of phenol and its para substituent in the rat. Biol Pharm Bull 16:518–520.8364501
NARA. 2006. Phenol. Electronic Code of Federal Regulations. Washington, DC: National Archives and Records Administration. http://www.access.gpo.gov/nara/cfr/cfr-table-search.html. March 20, 2006.
Narotsky MG, Kavlock RJ. 1995. A multidisciplinary approach to toxicological screening: II. Developmental toxicity. J Toxicol Environ Health 45:145–171.7783251
NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
Nazaroff WM, Singer BC. 2004. Inhalation of hazardous air pollutants from environmental tobacco smoke in U.S. residences. J Expo Anal Environ Epidemiol 14:871–877.
NCI. 1980. Bioassay of phenol for possible carcinogenicity. Bethesda, MD: U.S. Department of Health and Human Services. National Cancer Institute. NCI-CG-TR-203.
NCI. 1998. Cigars. Health effects and trends. Smoking and tobacco control monograph 9. Bethesda, MD: U.S. Department of Health and Human Services. National Cancer Institute. NIH Pub. No. 98–4302.
Needham LL, Head SL, Cline RE. 1984. Determination of phenols and cresols in urine by gas chromatography. Anal Lett 17:1555–1565.
Nicola RM, Branchflower R, Pierce D. 1987. Chemical contaminants in bottomfish. J Environ Health 49:342–347.
Nieminen E, Heikkila P. 1986. Simultaneous determination of phenol, cresols and xylenols in workplace air, using a polystyrene-divinylbenzene column and electrochemical detection. J Chromatogr 360:271–278.3733946
Nilsson A, Lagesson V, Bornehag C-G, 2005. Quantitative determination of volatile organic compounds in indoor dust using gas chromatography-UV spectrometry. Environ Int 31:1141–1148.15936080
NIOSH. 1983. Health hazard evaluation report No. HETA 82–053-1263. Bay Area Hospital, Coos Bay, Oregon. Cincinnati, OH: National Institute for Occupational Safety and Health. PB84210525.
NIOSH. 1990. Phenol. National occupational exposure survey 1981–1983. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control. National Institute for Occupational Safety and Health. http://www.cdc.gov/noes/noes1/55460sic.html. July 31, 2008.
NIOSH. 1994b. Method 2546. Cresol (all isomers) and phenol. NIOSH manual of analytical methods. 4th ed. National Institute of Occupational Safety and Health. (NMAM). 4th ed. http://www.cdc.gov/niosh/nmam/pdfs/2546.pdf. July 31, 2008.
NIOSH. 1994a. Method 8305: Phenol and p-cresol in urine. NIOSH manual of analytical methods (NMAM). 4th ed. National Institute of Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/8305.pdf. May 25, 2006.
NIOSH. 1996. Method 2549. Volatile organics compounds (screening) NIOSH manual for analytical methods(NMAM). 4th ed. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/2549.pdf. July 31, 2008.
NIOSH. 2005. Phenol. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. March 08, 2006.
Nishihara T, Nishikawa J, Kanayama T, 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci.46(4):282–298.
Nomoto Y, Fujita T, Kitani Y. 1987. Serum and urine levels of phenol following phenol blocks. Can J Anaesth 34(3):307–310.3581403
NRC. 1993. Pesticides in the diets of infants and children. National Research Council, Washington DC: National Academy Press.
NTP. 1983a. Teratologic evaluation of phenol (CAS No. 108–95-2) in CD-1 rats. National Toxicology Program. Research Triangle Park, NC: Research Triangle Institute.
NTP. 1983b. Teratologic evaluation of phenol (CAS No. 108–95-2) in CD mice. Laboratory study: September 18, 1980 to January 12, 1981. National Toxicology Program. Research Triangle Park, NC: Research Triangle Institute.
NTP. 2005. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. January 11, 2008.
O'Grodnick JS, Dupre GD, Gulizia BJ, 1983. Determination of benzene, phenol, catechol and hydroquinone in whole blood of rats and mice. J Chromatog Sci 21:289–292.
Ohtsuji H, Ikeda M. 1972. Quantitative relation between atmospheric phenol vapor and phenol in the urine of workers in Bakelite factories. Br J Ind Med 29:70–73.5060248
O’Neil MJ. 2001. Phenol. In: Merck index: An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station, NJ: Merck Research Laboratories, 1299–1300.
OSHA. 2005a. Air contaminants. Occupational safety and health standards for shipyard employment. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. March 08, 2006.
OSHA. 2005b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. March 08, 2006.
OSHA. 2005c. Limits for air contaminants. Occupational safety and health standards. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. March 06, 2006.
OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
*OTII. 2006. Phenol imports and exports. Washington, DC: U.S. Department of Commerce, Office of Trade and Industry Information, International Trade Administration. http://www.ita.doc.gov/td/industry/otea/trade-detail/index.html. July 14, 2006.
Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner, ed. Human development. Philadelphia, PA: Saunders, 222–238.
Painter RB, Howard R. 1982. The HeLa DNA-synthesis inhibition test as a rapid screen for mutagenic carcinogens. Mutat Res 92:427–437.7088012
Parkhurst BR, Bradshaw AS, Forte JL, 1979. An evaluation of the acute toxicity to aquatic biota of a coal conversion effluent and its major components. Bull Environ Contam Toxicol 23:349–356.519041
Paschin YV, Bahitova LM. 1982. Mutagenicity of benzo[a]pyrene and the antioxidant phenol at the HGPRT locus of V79 Chinese hamster cells. Mutat Res 104:389–393.6287251
Pashin YV, Bakhitova LM, Bentkhen TI. 1987. Dependence of antimutagenic activity of simple phenols on the number of hydroxyl groups. Bull Exp Biol Med 102(2):1121–1123.
Paterson B, Cowie CE, Jackson PE. 1996. Determination of phenols in environmental waters using liquid chromatography with electrochemical detection. J Chromatogr 731:95–102.
Patrick E, Maibach HI, Burkhalter A. 1985. Mechanisms of chemically induced skin irritation. I. Studies of time course, dose response, and components of inflammation in the laboratory mouse. Toxicol Appl Pharmacol 81:476–490.4082196
PDR. 2005. Physicians' desk reference. Montvale, NJ: Thomson PDR, 2693.
Pellack-Walker P, Blumer JL. 1986. DNA damage in L5178YS cells following exposure to benzene metabolites. Mol Pharmacol 39:42–47.
Perkins MA, Osborne R, Johnson GR. 1996. Development of an in vitro method for skin corrosion testing. Fundam Appl Toxicol 31:9–18.8998958
Petrasek AC, Kugelman IJ, Austern BM, 1983. Fate of toxic organic compounds in wastewater treatment plants. J Water Pollut Control Fed 55:1286–1296.
Pfeffer FM. 1979. The 1977 screening survey for measurement of organic priority pollutants in petroleum refinery wastewaters. ASTM Spec Tech Publ 686:181–190.
Pierrehumbert G, Pierre-Oliver D, Tardif R, 2002. Impact of human variability on the biological monitoring of exposure to toluene, phenol, lead, and mercury: II. Compartmental based toxicokinetic modelling. Toxicol Lett 134:165–175.12191875
Piotrowski JK. 1971. Evaluation of exposure to phenol: Absorption of phenol vapor in the lungs through the skin and excretion of phenol in urine. Br J Ind Med 28:172–178.5572685
Plumb RH Jr. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. Ground Water Monit Rev 7:94–100.
Poirier MC, DeCicco BT, Lieberman MW. 1975. Nonspecific inhibition of DNA repair synthesis by tumor promotors in human diploid fibroblasts damage with N-acetoxy-2-acetylaminofluorene. Cancer Res 35:1392–1397.1131814
Poliakova OV, Lebedev AT, Hanninen O. 2000. Organic pollutants in snow of urban and rural Russia and Finland. Toxicol Environ Chem 75:181–194.
Pool PL, Lin PZ. 1982. Mutagenicity testing in the Salmonella typhimurium assay of phenolic compounds and phenolic fractions obtained from smokehouse smoke condensates. Food Chem Toxicol 29:383–391.
Popp W, Rauscher D, Muller G, 1994. Concentrations of benzene in blood and S-phenylmercapturic acid and t,t-muconic acid in urine in car m echanics. Int Arch Occup Environ Health 66:1–6.7523309
Post G, Snyder R, Kalf GF. 1986. Metabolism of benzene and phenol in macrophages in vitro and the inhibition of RNA synthesis by benzene metabolites. Cell Biol Toxicol 2:231–246.2477122
Powell GM, Miller JJ, Olavesen AH, 1974. Liver as major organ of phenol detoxification. Nature (London) 252:234–235.4423505
Powley MW, Carlson GP. 2001. Cytochrome P450 isozymes involved in the metabolism of phenol, a benzene metabolite. Toxicol Lett 125:117–123.11701230
Powlowski J, Shingler V. 1994. Genetics and biochemistry of phenol degradation by Pseudomonas sp. CF600. Biodegradation 5:219–236.7765834
Pullin TG, Pinkerton MN, Johnson RV, 1978. Decontamination of the skin of swine following phenol exposure: A comparison of the relative efficacy of water versus polyethylene glycol/industrial methylated spirits. Toxicol Appl Pharmacol 43:199–206.625760
Quebbemann AJ, Anders MW. 1973. Renal tubular conjugation and excretion of phenol and p-nitrophenol in the chicken: Differing mechanisms of renal transfer. J Pharmacol Exp Ther 184:695–708.4687232
Quint U, Muller RT, Muller G. 1998. Characteristics of phenol: Instillation in intralesional tumor excision of shondroblastoma, osteoclastoma and enchondroma. Arch Orthop Trauma Surg 117:43–46.9457335
Ramakrishna BS, Roberts-Thomson IC, Pannall PR, 1991. Impaired sulphation of phenol by the colonic mucosa in quiescent and active ulcerative colitis. Gut 32:46–49.1991638
Ramli JB, Wheldrake JF. 1981. Phenol conjugation in the desert hopping mouse, Notomys alexis. Comp Biochem Physiol 69C:379–381.
Reddy MV, Bleicher WT, Blackburn GR, 1990. DNA adduction by phenol, hydroquinone, or benzoquinone in vitro but not in vivo: Nuclease P1-enhanced ^32^P-postlabeling of adducts as labeled nucleoside bisphosphates, dinucleotides and nucleoside monophosphates. Carcinogenesis 11:1349–1357.2387021
Rick DL, Licht CF, McCarty LP. 1982. Determination of phenol and pentachlorophenol in plasma and urine samples by gas liquid chromatography. J Anal Toxicol 6:297–300.7162140
Roemer E, Stabbert R, Rustemeier K, 2004. Chemical composition, cytotoxicity and mutagenicity of smoke from U.S. commercial and reference cigarettes smoked under two sets of machine smoking conditions. Toxicology 195:31–52.14698566
Rogers SC F, Burrows D, Neill D. 1978. Percutaneous absorption of phenol and methyl alcohol in magenta paint. Br J Dermatol 98:559–560.148899
Rothman N, Bechtold WE, Yin S-N, 1998. Urinary excretion of phenol, catechol, hydroquinone, and muconic acid by workers occupationally exposed to benzene. Occup Environ Med 55:705–711.9930093
Rubin HE, Alexander M. 1983. Effect of nutrients on the rates of mineralization of trace concentrations of phenol and p-nitrophenol. Environ Sci Technol 17:104–107.22295962
Ryan BM, Selby R, Gingell R, 2001. Two-generation reproduction study and immunotoxicity screen in rats dosed with phenol via the drinking water. Int J Toxicol 20:121–142.11488554
Sabourin PJ, Bechtold WE, Griffith WC, 1989. Effect of exposure concentration, exposure rate, and route of administration on metabolism of benzene by F344 rats and B6C3F1 mice. Toxicol Appl Pharmacol 99:421–444.2749731
Sabourin PJ, Chen BT, Lucier G, 1987. Effect of dose on the absorption and excretion of [^14^C]benzene administered orally or by inhalation in rats and mice. Toxicol Appl Pharmacol 87:325–336.3824388
Sacan MT, Balcioglu IA. 1996. Prediction of the soil sorption coefficient of organic pollutants by the characteristic root index model. Chemosphere 32(10):1993–2001.
Salaman MH, Glendenning OM. 1957. Tumor promotion in mouse skin by sclerosing agents. Br J Cancer 11:434–444.13499793
Sawahata T, Neal RA. 1983. Biotransformation of phenol to hydroquinone and catechol by rat liver microsomes. Mol Pharmacol 23:453–460.6835203
Schaltenbrand WE, Coburn SP. 1985. Determination of phenol and p-cresol in urine. Clin Chem 31:2042–2043.4064298
Schauer JJ, Kleeman MJ, Cass GR, 2001. Measurement of emissions from air pollution sources. 3. C_1_–C_29_ organic compounds from fireplace combustion of wood. Environ Sci Technol 35:1716–1728.11355184
Schlosser PM, Bond JA, Medinsky MA. 1993. Benzene and phenol metabolism by m ouse and rat liver microsomes. Carcinogenesis 14:2477–2486.8269615
Schmidt SH, Hellström S. 1993. Phenol anesthesia of the tympanic membrane in purulent otitis media A structural analysis in the rat. Eur Arch Otorhinolaryngol 249:470–472.8442942
Schmidt SH, Anniko M, Hellström S. 1990. Electrophysiological effects of the clinically used local anesthetics lidocaine, lidocaine-prilocaine and phenol on the raťs inner ear. Eur Arch Otorhinolaryngol 248:87–94.2282220
Schwartz CS, Snyder R, Kalf GF. 1985. The inhibition of mitochondrial DNA replication in vitro by the metabolites of benzene, hydroquinone and p-benzoquinone. Chem-Biol Interact 53:327–350.4006011
Scott DO, Lunte CE. 1993. In vivo microdialysis sampling in the bile, blood, and liver of rats to study the disposition of phenol. Pharmaceutical Res 10:335–342.
Scott HD, Wolf DC, Lavy TL. 1983. Adsorption and degradation of phenol at low concentrations in soil. J Environ Qual 12:91–95.
Scully FE Jr, Hoigne JR. 1987. Rate constants for reactions of singlet oxygen with phenols and other compounds in water. Chemosphere 16:681–694.
Seaton MJ, Schlosser PM, Medinsky MA. 1995. In vitro conjugation of benzene metabolites by human liver: Potential influence of interindividual variability on benzene toxicity. Carcinogenesis 16:1519–1527.7614685
Semple KT, Cain RB. 1996. Biodegradation of phenols by the alga Ochromonas danica. Appl Environ Microbiol 62:1265–1273.8919787
Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Greiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shafer KH, Cooke M, Deroos F, 1981. WCOT capillary GC/FT-IR and GC/MS for identifying toxic organic pollutants. Appl Spectrosc 35:469–472.
Shamy MY, El Gazzar RM, El Sayed MA, 1994. Study of some biochemical changes among workers occupationally exposed to phenol, alone or in combination with other organic solvents. Ind Health 32:207–214.7591850
Shelby MD, Witt KL. 1995. Comparison of results from mouse bone marrow chromosomes aberration and micronucleous tests. Environ Mol Mutagen 25(4):302–313.7607185
Sheldon LS, Hites RA. 1978. Organic compounds in the Delaware River. Environ Sci Technol 12:1188–1194.
Sheldon LS, Hites RA. 1979. Sources and movement of organic chemicals in the Delaware River. Environ Sci Technol 13:574–579.
Shiu WY, Ma KC, Varhanickova AD, 1994. Chlorophenols and alkylphenols: A review and correlation of env ironmentally relevant properties and fate in an evaluative environment. Chemosphere 29:1155–1224.
Sithole BB, Williams DT, Lastoria C, 1986. Determination of halogenated phenols in raw and potable water by selected ion gas chromatography-mass spectrometry. J Assoc Off Anal Chem 69:466–473.3722095
Skare JA, Schrotel KR. 1984. Alkaline elution of rat testicular DNA: Detection of DNA strand breaks after in vivo treatment with chemical mutagens. Mutat Res 130:283–294.6431278
Skowronski GA, Kadry AM, Turkall RM, 1994. Soil decreases the dermal penetration of phenol in male pig in vitro. J Toxicol Environ Health 41:467–479.8145286
Smart RC, Zannoni VG. 1984. DT-Diaphorase and peroxidase influence the covalent binding of the metabolites of phenol, the major metabolite of benzene. Mol Pharmacol 26:105–111.6749127
Snyder R, Chepiga T, Yang CS, 1993. Benzene metabolism by reconstituted cytochromes P450 2B1 and 2E1 and its modulation by cytochrome b(5), microsomal epoxide hydrolase, and glutathione transferases: Evidence for an important role of microsomal epoxide hydrolase in the formation of hydroquinone. Toxicol Appl Pharmacol 122(2):172–181.8211999
Soares ER, Tift JP. 1982. Phenol poisoning: Three fatal cases. J Forensic Sci 27(3):729–731.7119722
Southworth GR, Keller JL. 1986. Hydrophobic sorption of polar organics by low organic carbon soils. Water Air Soil Pollut 28:239–248.
Spiller HA, Quandrani-Kushner DA, Cleveland P. 1993. A five year evaluation of acute exposures to phenol disinfectant (26%). J Toxicol Clin Toxicol 31:307–313.8492343
Sporns P. 1981. High pressure liquid chromatographic determination of phenol in honey. J Assoc Off Anal Chem 64:337–340.7228827
SRI. 2006. Phenol. 2005 Directory of chemical producers. Menlo Park, CA: SRI Consulting, 785.
Stajduhar-Caric Z. 1968. Acute phenol poisoning. Singular findings in a lethal case. J Forensic Med 15:41–42.5662696
Steele RH, Wilhelm DL. 1966. The inflammatory reaction in chemical injury. I. Increased vascular permeability and erythema induced by various chemicals. Br J Exp Pathol 47:612–623.5954087
Stommel P, Muller G, Stucker W 1989. Determination of S-phenylmercapturic acid in the urine-An improvement in the biological monitoring of benzene exposure. Carcinogenesis 10:279–282.2912579
Stover EL, Kincannon DF. 1983. Biological treatability of specific organic compounds found in chemical industry wastewaters. J Water Pollut Control Fed 55:97–109.
Stubin AI, Brosnan TM, Porter KD, 1996. Organic priority pollutants in New York City municipal wastewaters: 1989–1993. Water Environ Res 68:1037–1044.
Stuermer DH, Ng DJ, Morris CJ. 1982. Organic contaminants in groundwater near an underground coal gasification site in northeastern Wyoming. Environ Sci Technol 16:582–587.22284199
Sturtevant FM. 1952. Studies on the mutagenicity of phenol in Drosophila melanogaster. J Hered 43:217–220.
Subrahmanyam VV, O'Brien PJ. 1985. Phenol oxidation products, formed by a peroxidase reaction, that bind to DNA. Xenobiotica 15:873–885.4072251
Subrahmanyam VV, Doane-Setzer P, Steinmetz KL, 1990a. Phenol-induced stimulation of hydroquinone bioactivation in mouse bone marrow in vivo: Possible implications in benzene myelotoxicity. Toxicology 62:107–116.2343455
*Subrahmanyam VV, Kolachana P, Smith MT. 1990b. Effect of phenol and catechol on the kinetics of human myeloperoxidase-dependent hydroquinone metabolism. Adv Exp Med Biol 283:377–381.
Subrahmanyam VV, Kolachana P, Smith MT. 1991. Hydroxylation of phenol to hydroquinone catalyzed by a human myeloperoxidase-superoxide complex: Possible implications in benzene-induced myelotoxicity. Free Radic Res Commun 15:285–296.1666626
*Subrahmanyam VV, McGirr LG, O'Brien PJ. 1990c. Peroxidase/hydrogen peroxide–or bone marrow homogenate/hydrogen peroxide–mediated activation of phenol and binding to protein. Xenobiotica 20:1369–1378.2075753
Sunesson AL, Gullberg J, Blomquist G. 2001. Airborne chemical compounds on dairy farms. J Environ Monit 3(2):210–216.11354733
Suppiah A, Perry EP. 2005. Jaundice as a presentation of phenol induced hepatotoxocity following injection scherotherapy for haemorrhoids. Surgeon 3(1):43–44.15789794
Suzuki T, Kisara K. 1985. Enhancement of phenol-induced tremor caused by central monoamine depletion. Pharmacol Biochem Behav 22:153–155.3975240
Sze C-C, Shi C-Y, Ong C-N. 1996. Cytotoxicity and DNA strand breaks induced by benzene and its metabolites in Chinese hamster ov ary cells. J Appl Toxicol 16:259–264.8818868
Tanaka S, Choe N, Kita T, 1998. Distribution of phenol in a fatal poisoning case determined by gas chromatography/mass spectrometry. J Forensic Sci 43(5):1086–1088.9729832
Tang J, Jin QZ, Shen GH, 1983. Isolation and identification of volatile compounds from fried chicken. J Agric Food Chem 31:1287–1292.
Tesarova E, Packova V. 1983. Gas and high performance liquid chromatography of phenols. Chromatographia 17:269–284.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thurman C. 1982. Phenol. In: Kirk-Othmer encyclopedia of chemical technology, 3rd ed., Vol 17. New York, NY: John Wiley and Sons, 373–384.
Thurman EM. 1985. Organic geochemistry of natural waters. Boston, MA: Martinus Nijhoff/Dr. W. Junk Publishers, 143–146.
Tomkins BA, Jenkins RA, Griest WH, 1984. Liquid chromatographic determination of phenol and cresols in total particulate matter of cigarette smoke. J Assoc Off Anal Chem 67:919–923.6501155
Tremaine LM, Diamond GL, Quebbemann AJ. 1984. In vivo quantification of renal glucuronide and sulfate conjugation of 1-naphthol and p-nitrophenol in the rat. Biochem Pharmacol 33:419–427.6704161
TRI05. 2007. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. December 22, 2007.
Truppman ES, Ellenby JD. 1979. Major electrocardiographic changes during chemical face peeling. Plast Reconstr Surg 63:44–48.432323
Tsutsui T, Hayashi N, Maizumi H, 1997. Benzene-, catechol-, hydroquinone- and phenol-induced cell transformation, gene mutations, chromosome aberrations, aneuploidy, sister chromatid exchanges and unscheduled DNA synthesis in Syrian hamster embryo cells. Mutat Res 373(1):113–123.9015160
U.S. Air Force. 1961. Tolerance criteria for continuous inhalation exposure to toxic material. I. Effects on animals of 90-day exposure to phenol, CCl_4_ and a mixture of indole, skatole, H_2_S and methyl mercaptan. Wright-Patterson Air Force Base, OH: U.S. Air Force systems command, Aeronautical Systems Division, ASD technical report 61–519(I).
USGS. 1995. Method O-5130–95: Determination of semivolatile organic compounds in bottom sediment by solvent extraction, gel permeation chromatographic fractionation, and capillary-column gas chromatography/mass spectrometry. U.S. Geological Survey. http://pubs.er.usgs.gov/usgspubs/ofr/ofr95719. April 18, 2006.
USGS. 2002. Method O-1433–01: Pesticides and degradates, filtered water, gas chromatography/mass spectrometry. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory--Determination of wastewater compounds by polystyrene-divinylbenzene solid-phase extraction and capillary-column gas chromatography/mass spectrometry. U.S. Geological Survey.
USITC. 2008. Phenol (hydroxybenzene) and its salts. United States International Trade Commission. http://dataweb.usitc.gov/. July 24, 2008.
Van Duuren BL, Goldschmidt BM. 1976. Cocarcinogenic and tumor promoting agents in tobacco carcinogenesis. J Natl Cancer Inst 56:1237–1242.994224
Van Duuren BL, Blazej T, Goldschmidt BM, 1971. Cocarcinogenesis studies on mouse skin and inhibition of tumor induction. J Natl Cancer Inst 46:1039–1044.5157842
Van Duuren BL, Katz C, Goldschmidt BM. 1973. Cocarcinogenic agents in tobacco carcinogenesis. J Natl Cancer Inst 51:703–705.4765384
Van Roosmalen PB, Purdham J, Drummond I. 1981. An improved method for the determination of phenol in the urine of workers exposed to benzene or phenol. Int Arch Occup Environ Health 48:159–163.7263078
Van Rossum P, Webb RG. 1978. Isolation of organic water pollutants by XAD resins and carbon. J Chromatogr 150:381–392.
Vernot EH, MacEwen JD, Haun CC, 1977. Acute toxicity and skin corrosion data for some organic and inorganic compounds and aqueous solutions. Toxicol Appl Pharmacol 42:417–424.595018
Viccellio P. 1998. Phenols. In: Emergency toxicology. 2nd ed. Philadelphia, PA: Lippincott-Raven Publishers, 355–362.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
von Oettingen WF, Sharpless NE. 1946. The toxicity and toxic manifestations of 2,2-bis(p-chlorophenyl)-1,1,1-trichloroethane (DDT) as influenced by chemical changes in the molecule. J Pharmacol Exp Ther 88:400–413.20279276
Wallace J. 1996. Phenol. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical toxicology. 4^th^ ed. New York, NY: John Wiley & Sons, 592–602.
Wallace JC, Basu I, Hites RA. 1996. Sampling and analysis artifacts caused by elevated indoor air polychlorinated biphenyl concentrations. Environ Sci Technol 30:2730–2734.
*Wallin H, Morgenstern R. 1990. Activation of microsomal glutathione transferase activity by reactive intermediates formed during the metabolism of phenol. Chem-Biol Interact 75:185–199.2369785
Warner MA, Harper JV. 1985. Cardiac dysrhythmias associated with chemical peeling with phenol. Anesthesiology 62:366–367.2579602
Waxman DJ, Dannan GA, Guengerich FP. 1985. Regulation of rat hepatic cytochrome P-450: Age-dependent expression, hormonal imprinting, and xenobiotic inducibility of sex-specific isoenzymes. Biochemistry 24:4409–4417.4052406
Weitering JG, Kriggsheld KR, Mulder GJ. 1979. The availability of inorganic sulfate as a rate limiting factor in the sulfate conjugation of xenobiotics in the rat. Biochem Pharmacol 28:757–762.454475
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32a:10–18.
Wexler MR, Halon DA, Teitelbaum A, 1984. The prevention of cardiac arrhythmias produced in an animal model by the topical application of a phenol preparation in common use for face peeling. Plast Reconstr Surg 73:595–598.6709741
Wheldrake JF, Baudinette RV, Hewitt S. 1978. The metabolism of phenol in desert rodent Notomys alexis. Comp Biochem Physiol 61C:103–107.
WHO. 1994. Phenol. Environmental health criteria 161. Geneva, Switzerland: United Nations Environment Programme. International Labour Organisation. World Health Organization.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/activities/20050223_4. March 08, 2006.
WHO. 2004. Guidelines for drinking water qualities. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise, volume II, The elements part A. New York, NY: Academic Press.
Wilcosky TC, Tyroler HA. 1983. Mortality from heart disease among workers exposed to solvents. J Occup Med 25:879–885.6655522
Wood K. 1978. The use of phenol as a neurolytic agent: A review. Pain 5:205–229.581515
Wynder E, Hoffmann D. 1961. A study of tobacco carcinogenesis. VIII. The role of acidic fractions as promoters. Cancer 14:1306–1315.14008628
Xing B, McGill WB, Dudas MJ. 1994. Sorption of phenol by selected polymers: Isotherms, energetics, and polarity. Environ Sci Technol 28:466–473.22165882
York RG. 1997. Oral (gavage) developmental toxicity study of phenol in rats. Proctor & Gamble Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0573686.
Young DR, Gossett RW, Baird RB, 1983. Wastewater inputs and marine bioaccumulation of priority pollutants organics off southern California. In: Water chlorination: Environmental impacts and health effects. 4:871–884.
Yrjanheikki E. 1978. A new method of personnel sampling and analyzing of phenol. Am Ind Hyg Assoc J 39:326–330.645561
Zamponi GW, Ing D, French RJ. 1994. Arrhythmias during phenol therapies: A specific action on cardiac sodium channels? Circulation 89:914.
Zhao F, Mayura K, Hutchinson RW, 1995. Developmental toxicity and structure-activity relationships of chlorophenols using human embryonic palatal mesenchymal cells. Toxicol Lett 78:35–42.7604397
Zhu J, Newhook R, Marro L, 2005. Selected volatile organic compounds in residential air in the city of Ottawa, Canada. Environ Sci Technol 39(11):3964–3971.15984771
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372