# 8 REGULATIONS AND ADVISORIES

International and national regulations and guidelines pertinent to human exposure to phenol are summarized in Table 8-1.

ATSDR has derived an acute-duration oral MRL of 1.0 mg/kg/day based on a BMDL of 125 mg/kg/day for changes in body weight gain in pregnant rats exposed to phenol by gavage using divided dosing during GDs 6–15 (York 1997). An uncertainty factor of 100 was used (10 for animal to human extrapolation and 10 for human variability).

EPA (IRIS 2006) derived an oral reference dose (RfD) of 0.3 mg/kg/day for phenol based on a BMDL of 93 mg/kg/day for decreased maternal weight gain observed in Sprague-Dawley rats dosed with phenol during gestation (York 1997).

The IARC classification for phenol is Group 3, not classifiable with regard to its carcinogenicity to humans (IARC 2004). The EPA cancer classification for phenol is D, not classifiable as to human carcinogenicity (IRIS 2006). The National Toxicology Program has not classified phenol for human carcinogenicity (NTP 2005). The American Conference of Governmental Industrial Hygienists (ACGIH) has classified phenol as an A4 carcinogen (not classifiable as a human carcinogen) (ACGIH 2005).

OSHA has required employers of workers who are occupationally exposed to phenol to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PELs) (OSHA 2005a). The employer must use engineering and work practice controls to reduce exposures to or be low an 8-hour time-weighted average (TWA) of 5 ppm for phenol (OSHA 2005a). ACGIH (2005) and NIOSH (2005) also recommend a TWA exposure limit of 5 ppm for occupational exposure.

Phenol is regulated by the Clean Water Effluent Guidelines for the following industrial point sources: electroplating, organic chemicals, steam electric, asbestos, timber products processing, metal finishing, paving and roofing, paint formulating, ink formulating, gum and wood, carbon black, metal molding and casting, aluminum forming, and electrical and electronic components; see the electronic Code of Federal Regulations for a complete listing (NARA 2006).

Table 8-1 Regulations and Guidelines Applicable to Phenol

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 3^a^ | IARC 2004
WHO | Air quality guidelines | No data | WHO 2000
| Drinking water quality guidelines | No data | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA)^b^ | 5 ppm | ACGIH 2005
EPA | AEGL-1^c,d^ | | EPA 2006a
| 10 minutes | 19 ppm
| 30 minutes | 19 ppm
| 60 minutes | 15 ppm
| 4 hours | 9.5 ppm
| 8 hours | 6.3 ppm
| AEGL-2^c,d^
| 10 minutes | 29 ppm
| 30 minutes | 29 ppm
| 60 minutes | 23 ppm
| 4 hours | 15 ppm
| 8 hours | 12 ppm
| AEGL-3^c,d^ | Not recommended due to insufficient data
| Hazardous air pollutant | Yes | EPA 2006d 42 USC 7412
NIOSH | REL (10-hour TWA)^e^ | 5 ppm | NIOSH 2005
| Ceiling limit (15-minute TWA) | 15.6 ppm
| IDLH | 250 ppm
OSHA | PEL (8-hour TWA) for general industry^f^ | 5 ppm | OSHA 2005c 29 CFR 1910.1000
| PEL (8-hour TWA) for construction industry^f^ | 5 ppm | OSHA 2005b 29 CFR 1926.55, Appendix A
| PEL (8-hour TWA) for shipyard industry^f^ | 5 ppm | OSHA 2005a 29 CFR 1915.1000
b. Water
EPA | Designated as a hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2006b 40 CFR 116.4
| Designated as a toxic pollutant in accordance with Section 307(a)(1) of the Federal Water Pollution Control Act | Yes | EPA 2006c 40 CFR 401.15
EPA | Drinking water standards and health advisories | | EPA 2004
| 1-day health advisory for a 10-kg child | 6 mg/L
| 10-day health advisory for a 10-kg child | 6 mg/L
| DWEL | 11 mg/L
| Lifetime | 2 mg/L
| National primary drinking water standards | No data | EPA 2003
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 1,000 pounds | EPA 2006g 40 CFR 117.3
| Toxics criteria for those states not complying with Clean Water Act Section 303(c)(2)(B) for human health (10^−6^ risk for carcinogens) for consumption of: | | EPA 2006m 40 CFR 131.36
| Water + organism | 21 mg/L
| Organism only | 4,600 mg/L
| Water quality criteria for human health consumption of: | | EPA 2006f
| Water + organism | 21 mg/L
| Organism only | 1,700 mg/L
c. Food
EPA | Exemptions from the requirement of a tolerance as an inert ingredient (as a solvent) when used pre-harvest | Yes | EPA 2006k 40 CFR 180.920
| Exemptions from the requirement of a tolerance as an inert ingredients (as a solvent) when applied to animals | Yes | EPA 2006l 40 CFR 180.930
FDA | Bottled drinking water | 0.001 mg/L | FDA 2005
| Included on the “Everything Added to Foods in the United States” List | Yes | FDA 2006
d. Other
ACGIH | Carcinogenicity classification | A4^g^ | ACGIH 2005
| Biological exposure indices (end of shift) for total phenol in urine | 250 mg/g creatinine
CPSC | Substance named in the Federal Caustic Poison Act; phenol and any preparation containing phenol in a concentration | ≤5% | CPSC 2005
EPA | Carcinogenicity classification | Group D^h^ | IRIS 2006
| Oral slope factor | Not applicable
| Inhalation unit risk | Not applicable
| RfC | Not applicable^i^ | IRIS 2006
| RfD | 0.3 mg/kg/day
| Identification and listing of hazardous waste; hazardous waste number | U188 | EPA 2006e 40 CFR 261, Appendix VIII
| Superfund, emergency planning, and community right-to-know
| Designated CERCLA hazardous substance | Yes | EPA 2006h 40 CFR 302.4
| Reportable quantity | 1,000 pounds
| Effective date of toxic chemical release reporting | 01/01/87 | EPA 2006j 40 CFR 372.65
| Extremely hazardous substances and their threshold planning quantities | 500/10,000 pounds | EPA 2006i 40 CFR 355, Appendix A
NTP | Carcinogenicity classification | No data | NTP 2005

a Group 3: not classifiable as to carcinogenicity to humans

b Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors, liquids, or solids.

c AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects. AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape. AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death.

d Level of distinct odor awareness = 0.25 ppm

e Skin designation: indicates the potential for dermal absorption; skin exposure should be prevented as necessary through the use of good work practices, gloves, coveralls, goggles, and other appropriate equipment.

f Skin designation

g A4: not classifiable as a human carcinogen

h Group D: not classifiable as to human carcinogenicity

i Not applicable: no adequate inhalation exposure studies exist from which an inhalation RfC may be derived. A route-to-route extrapolation is not appropriate, because phenol can be a direct contact irritant, and so portal-of-entry effects are a potential concern.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = Acute Exposure Guideline Level; CERCLA = Comprehensive Environmetnal Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; CPSC = Consumer Product Safety Commission; DWEL = drinking water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization

EPA regulates phenol under the Clean Water Act (CWA) and the Clean Air Act (CAA) and has designated it as a hazardous substance and a hazardous air pollutant (HAP) (EPA 2006b, 2006c). Phenol is on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986" (EPA 2006j) and has been assigned a reportable quantity (RQ) limit of 1,000 pounds (EPA 2006h). The RQ represents the amount of a designated hazardous substance which, when released to the environment, must be reported to the appropriate authority. Phenol is also considered to be an extremely hazardous substance (EPA 2006i).