# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of phenol is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of phenol is located in Table 4-2.

Table 4-1 Chemical Identity of Phenol

Characteristic | Information | Reference
Chemical name | Phenol | Lide 2005
Synonym(s) | Benzenol, hydroxylbenzene, monophenol, oxybenzene, phenyl alcohol, phenyl hydrate, phenyl hydroxide, phenylic acid, phenylic alcohol | Lewis 2000
Registered trade name(s) | Carbolic acid, phenic acid, phenic alcohol | Gardner et al. 1978
Chemical formula | C_6_H_6_O | Lide 2005
Chemical structure | [image] | Budavari et al. 1989
Identification numbers:
CAS registry | 108-95-2 | HSDB 2008
NIOSH RTECS | SJ3325000 | RTECS 2006
EPA hazardous waste | U188 | EPA 1998; HSDB 2008
DOT/UN/NA/IMCO shipping | UN 1671 (solid) | HSDB 2008
| UN 2312 (molten)
| UN 2821 (solution)
| IMO 6.1 (solid, molten, solution)
HSDB | 113 | HSDB 2008
NCI | C50124 | Lewis 2000

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS=Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Phenol

Property | Information | Reference
Molecular weight | 94.111 | Lide 2005
Color | Colorless to light pink | HSDB 2008
Physical state | Crystalline solid liquid (w/ 8% H_2_O)
Melting point | 40.89 °C | Lide 2005
Boiling point | 181.87 °C | Lide 2005
Density at 20 °C/4 °C | 1.0545 at 45 °C/4 °C | Lide 2005
Vapor density | 3.24 | Lewis 2000
Odor | Distinct aromatic, somewhat sickening, sweet and acrid odor | HSDB 2008
Odor threshold:
Water | 7.9 ppm (w/v) | Amoore and Hautala 1983
| 1 ppm (w/v) | Baker et al. 1978
Air | 0.040 ppm (v/v) | Amoore and Hautala 1983
Solubility:
Water at 25 °C | 8.28×10^4^ mg/L | Southworth and Keller 1986
Organic solvent(s) | Soluble in water and ethanol, very soluble in ether, miscible with acetone and benzene | Lide 2005
Partition coefficients:
Log K_ow_ | 1.46 | HSDB 2008
Log K_oc_ | 1.21–1.96 | Artiola-Fortuny and Fuller 1982; Boyd 1982; Briggs 1981; Sacan and Balcioglu 1996; Scott et al. 1983
Vapor pressure at 25 °C | 0.35 mmHg | HSDB 2008
Henry’s law constant | 3.0×10^7^ atms m^3^-mol | Gaffney et al. 1987
Autoignition temperature | 715 °C | Lewis 2000
Flashpoint, open cup | 85 °C | HSDB 2008
Flashpoint, closed cup | 79 °C | HSDB 2008
Flammability limits (in air, by % v) | 1.7–8.6% | HSDB 2008
Conversion factors:
ppm (v/v) to mg/m^3^ in air (25 °C) | ppm (v/v)×3.92=mg/m^3^
mg/m^3^ to ppm (v/v) in air (25 °C) | mg/m^3^×0.225=ppm (v/v)

atm = atmosphere; v = volume; w = weight