# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Phenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Phenol
CAS Numbers: | 108-95-2
Date: | July 2008
Profile Status: | Draft 3 Post-Public
Route: | [ ] Inhalation [x] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 13
Species: | Rat

[underlined: Minimal Risk Level]: 1 [x] mg/kg/day [ ] ppm

[underlined: Reference]: York. 1997. Oral (gavage) developmental toxicity study of phenol in rats. Procter & Gamble Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0573686.

[underlined: Experimental design]: Groups of pregnant Sprague-Dawley rats (25/dose group) were dosed 3 times daily with 0, 20, 40, or 120 mg phenol/kg (total daily doses of 0, 60, 120, and 360 mg/kg) by gavage in water on gestation days (GDs) 6–15; the dosing volume was 10 mL/kg. Maternal end points evaluated included clinical signs, body weight, and food consumption. Dams were also observed for abortions and premature deliveries. Dams were sacrificed on GD 20 and a gross necropsy was conducted. The uterus was examined for pregnancy, number and distribution of implantations, live and dead fetuses, and early and late resorptions. Fetuses were weighed and examined for sex and gross external alterations. Half of the fetuses were examined for soft tissue alterations and the remaining fetuses were examined for skeletal alterations.

[underlined: Effect noted in study and corresponding doses]: One dam in the 360 mg/kg/day group died on GD 11 and the death was attributed to phenol treatment. Clinical signs considered treatment-related included excess salivation and tachypnea in rats exposed to 360 mg/kg/day. Gross necropsy of the dams did not reveal any treatment-related alterations. In the 120 mg/kg/day group, maternal body weight gain was significantly reduced for GDs 6–16 (11%) and for GDs 12–16 (19%), whereas in the 360 mg/kg/day group, body weight gain was reduced 38% for gestation days 6–16. Maternal final body weight in the 360 mg/kg/day group was reduced, but <10% relative to controls. Food consumption was reduced in the 360 mg/kg/day group by 16% for GDs 6–20 and by 15% for GDs 0–20; in the 120 mg/kg/day group, food consumption for GDs 6–16 was reduced 11%. Fetal body weight at the 360 mg/kg/day level was reduced 5–7% relative to controls. There was a significant decrease in ossification sites on the hindlimb metatarsals in the 360 mg/kg/day group. At the 120 and 360 mg/kg/day dose levels, there were increases in litters with fetuses with "any alteration" and with "any variation", but neither reached statistical significance and there were no clear dose-response relationships. There were no significant effects on corpora lutea, implantations, litter sizes, live fetuses, early and late resorptions, and percent resorbed conceptuses. Based on decreased fetal body weight and delayed ossification, the dose of 360 mg/kg/day is a LOAEL for developmental effects; the NOAEL is 120 mg/kg/day. Based on decreased weight gain during gestation, the dose of 120 mg/kg/day is a LOAEL for decreased maternal body weight gain; the NOAEL is 60 mg/kg/day.

Data from York (1997) were analyzed using the BMD approach for MRL derivation. BMD models in the EPA Benchmark Dose Software (BMDS version 2.0) (linear, polynomial, power, and Hill models) were fit to the maternal body weight gain data to determine potential points of departure for the MRL. The linear model with homogeneous variance, which is the simplest model and the model that provided the best fit for the data, was selected. In the absence of a clear criteria as to what level of change in weight gain during pregnancy should be considered adverse, the benchmark response (BMR) was defined as a change in mean body weight gain equal to one standard deviation from the control mean (EPA 2000c). The corresponding BMD was 152 mg/kg/day; the corresponding benchmark dose limit (BMDL) was 125 mg/kg/day. Applying an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability) to the BMDL results in an acute-duration oral MRL of 1 mg/kg/day.

[underlined: Dose and end point used for MRL derivation]: BMDL of 125 mg/kg/day for decreased maternal weight gain.

[ ] NOAEL [ ] LOAEL [x] BMDL

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In another developmental study, rats were gavaged with phenol in doses of 0, 30, 60, and 120 mg/kg/day in a dosing volume of 5 mL/kg during GDs 6–15 (NTP 1983a). There was no maternal toxicity, but mean fetal body weight at this dose level was approximately 7% lower than controls. However, since historical control data showed that the concurrent control fetal weight for the CD rat was much higher (22%) than the historical control weight and a larger litter size in the high-dose group may have contributed to the smaller fetal weight in the high-dose group, the dose of 120 mg/kg/day can be considered an equivocal LOAEL for developmental effects; the NOAEL was 60 mg/kg/day and supports the NOAEL of 60 mg/kg/day identified in the York (1997) study.

As discussed in Section 2.3, effects of phenol administered to animals by oral gavage are different than those observed in drinking water studies. Phenol administered by gavage is much more toxic than administered in the drinking water and this is related to the pharmacokinetics of phenol. Furthermore, it has been shown that the volume of administration is important; the smaller the volume, the greater the toxicity of a given amount of phenol (NTP 1983a). Studies have shown that the toxicity of phenol is correlated with peak blood concentration rather than with total dose, such as the area under the phenol blood concentration curve (AUC) (Hiser et al. 1994). In general, NOAELs in oral gavage studies were 5–10 times lower than in drinking water studies. The York (1997) study was considered an appropriate study for MRL derivation because it used a divided dosing protocol that resembles more closely a potential environmental exposure scenario to phenol.

[underlined: Agency Contacts (Chemical Managers)]: Jewel Crawford; Obaid Faroon; Jewell Wilson

## BENCHMARK MODELING OF MATERNAL WEIGHT GAIN IN RATS

Benchmark dose models in the EPA Benchmark Dose Software (BMDS version 2.0) (linear, polynomial, power, and Hill models) were fit to the maternal body weight gain data (see Tables A-1, and A-2, and Figure A-1) to determine potential points of departure for the MRL. The linear model with homogeneous variance (which was identical to the power model), was selected because it was the simplest model and provided the best fit. In the absence of a clear criteria as to what level of change in weight gain during pregnancy should be considered adverse, the BMR was defined as a change in mean body weight gain equal to one standard deviation from the control mean (EPA 2000c).

Table A-1 Data for the Change in Body Weight Gain in Pregnant Rats Exposed to Phenol on Gestation Days 6–15

Dose (mg/kg/day) | Number of animals tested | Body weight gain (g) | Standard deviation
0 | 23 | 64 | 10.7
60 | 25 | 58 | 9.4
120 | 23 | 56.8 | 10.8
360 | 25 | 39.8 | 9.5

Source: York 1997

The corresponding BMD was 152.1 mg/kg/day; the corresponding BMDL was 124.6 mg/kg/day. Applying an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability) to the BMDL results in an acute-duration oral MRL of 1 mg/kg/day.

Table A-2 Model Predictions for Changes in Body Weight Gain in Pregnant Rats Exposed to Phenol on Gestation Days 6–15

Model | BMD_1stddev_ (mg/kg/day) | BMDL_1stddev_ (mg/kg/day) | p-value^a^ | AIC-fitted
Linear^b,c^ | 152.1 | 124.6 | 0.6055 | 542.79
2-degree polynomial ^c^ | 157.0 | 124.6 | 0.3191 | 544.78
Power^b^ | 152.1 | 124.6 | 0.6055 | 542.79
Hill | 151.2 | 123.7 | 0.3156 | 544.79

a Values <0.05 fail to meet conventional goodness-of-fit criteria.

b Best-fitting models

c The polynomial coefficients are restricted to be negative.

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; NA = not applicable; p = p value from the Chi-squared test

Source: York 1997

Figure A-1 Changes in Body Weight Gain in Pregnant Rats Exposed to Phenol on Gestation Days 6–15^*^ * BMDs and BMDLs indicated are for a change of 1 standard deviation and are in units of mg/kg/day.

Source: York 1997

The homogeneous variance linear model form of the response function for the change in maternal body weight gain is:

Y[dose] = beta_0 + beta_1*dose + beta_2*dose^2 + ...

Linear Model Parameter Estimates for the Change in Maternal Body Weight Gain:

Variable | Estimate | Standard Error
alpha | 98.6 | 14.2
beta_0 | 63.4 | 1.4
beta_1 | −0.07 | 0.007