# 9 REFERENCES

*Not cited in text

ACGIH. 2004. Perchlorates. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Atlanta, GA: Subcommittee on Biomarkers of Organ Damage and Dysfunction, Agency for Toxic Substances and Disease Registry.
Agency for Toxic Substances and Disease Registry. 2000. Public health assessment for Lockheed Propulsion Company: Evaluation of exposure to perchlorate contamination in the city of Loma Linda’s domestic water supply. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS No. CAD980893093. PB2000105429.
Agency for Toxic Substances and Disease Registry. 2004. Toxicological profile for iodine. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
American Thyroid Association. 2006. Iodine supplementation for pregnancy and lactation-United States and Canada: Recommendations of the American Thyroid Association. Thyroid 16(10):949–951.17042677
Amitai Y, Winston G, Sack J, . 2007. Gestational exposure to high perchlorate concentrations in drinking water and neonatal thyroxine levels. Thyroid 17(9):843–850.17956158
Anbar M, Guttmann S, Lweitus Z. 1959. The mode of action of perchlorate ions on the iodine uptake of the thyroid gland. Int J Appl Radiat Isot 7:87–96.13793274
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Andersen S, Pedersen KM, Bruun NH, . 2002. Narrow individual variations in serum T4 and T3 in normal subjects: A clue to the understanding of subclinical thyroid disease. J Clin Endocrinol Metab 87(3):1068–1072.11889165
Anderson GW, Mariash CN, Oppenheimer JH. 2000. Molecular actions of thyroid hormone. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 174–195.
Andros G, Wollman SH. 1991. Kinetics of equilibration of radioiodide in individual mouse thyroid follices in vivo. Am J Physiol 261(24):E529–E538.1928343
Antonsen DH. 1996. Nickel compounds. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 17. New York, NY: John Wiley & Sons, 20.
Arieli A, Chinet A. 1985. Brown adipose tissue heat production in heat acclimated and perchlorate treated rats. Horm Metab Res 17:12–15.2981759
Ashford RD. 1994. Ashford’s dictionary of industrial chemicals: Properties, production, uses. Wavelength Publications Ltd., 758, 821, 823.
Aziz C, Borch R, Nicholson P, . 2006. Alternative causes of wide-spread, low concentration perchlorate impacts to groundwater. In: Gu B, Coates JD, eds. Perchlorate. Environmental occurrence, interactions and treatment. New York, NY: Springer Science and Business Media, Inc., 71–91.
Backus SM, Klawuun P, Brown S. 2005. Determination of perchlorate in selected surface waters in the Great Lakes Basin by HPLC/MS/MS. Chemosphere 61:834–843.15964050
Bagchi N, Fawcett DM. 1973. Role of sodium ion in active transport of iodide by cultured thyroid cells. Biochim Biophys Acta 318:235–251.4795651
Baier-Anderson C, Blount BC, Lakind JS, . 2006. Estimates of exposures to perchlorate from consumption of human milk, dairy milk, and water, and comparison to current reference dose. J Toxicol Environ Health A 69(4):319–330.16407090
Bardiya N, Bae J. 2005. Bioremediation potential of a perchlorate-enriched sewage sludge consortium. Chemosphere 58:83–90.15522336
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Bartha KG. 1974. Utilization of iodine kinetic coefficients for the analysis of pharmacological responses. Acta Med Acad Sci Hung 31(1–2):51–57.4377194
Barzilai D, Sheinfeld M. 1966. Fatal complications following use of potassium perchlorate in thyrotoxicosis. Report of two cases and a review of the literature. Isr J Med Sci 2(4):453–456.4290684
Bauer RJ. 1990. Lithium and lithium compounds. In: Elvers B, Hawkins S, Schulz G, eds. Ullmann’s encyclopedia of industrial chemistry, Vol. A15. New York, NY: VCH Publishers, 393–414.
Bekkedal MYV, Arfsten D, Mattie D. 2004. An evaluation of neurobehavioral tests used to assess the neurodevelopmental effects of early ammonium perchlorate exposure. J Toxicol Environ Health A 67:835–844.15192872
Bekkedal MYV, Carpenter TL, Smith J. 2000. A neurodevelopmental study of oral ammonium perchlorate exposure on the motor activity of pre-weanling rat pups. Wright-Patterson Air Force Base, OH: Naval Health Research Center Detachment (Toxicology), Report No. TOXDET-00-03.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Bernal J, Pekonen F. 1984. Ontogenesis of the nuclear 3,5,3’-triiodothyronine receptor in the human fetal brain. Endocrinology 114(2):677–679.6317365
Blount BC, Valentín-Blasini L. 2007. Biomonitoring as a method for assessing exposure to perchlorate. Thyroid 17(9):837–841.17822374
Blount BC, Pirkle JL, Osterloh JD, . 2006. Urinary perchlorate and thyroid hormone levels in adolescent and adult men and women living in the United States. Environ Health Perspect 114(12):1865–1871.17185277
Blount BC, Valentin-Blasini L, Osterloh JD, . 2007. Perchlorate exposure of the U.S. population, 2001-2002. J Expo Anal Environ Epidemiol 1–8. www.nature.com/jes. March 12, 2007.
Bodek I, Lyman WJ, Reehl W, . 1988. Environmental inorganic chemistry: Properties, processes, and estimation methods. New York, NY: Pergamon Press.
Bortle WH. 1996. Sodium nitrate. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 22. New York, NY: John Wiley & Sons, Inc., 383–403.
Boyages SC. 2000. The neuromuscular system and brain in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 803–810.
Brabant G, Bergmann P, Kirsch CM, . 1992. Early adaptation of thyrotropin and thyroglobulin secretion to experimentally decreased iodine supply in man. Metabolism 41:1093–1096.1328820
Braverman LE, Utiger RD, eds. 2000. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8^th^ ed. Philadelphia, PA: Lippincott Williams & Wilkins, 593–666, 774–832.
Braverman LE, He XM, Pino S, . 2005. The effect of perchlorate, thiocyanate, and nitrate on thyroid function in workers exposed to perchlorate long-term. J Clin Endocrinol Metab 90(2):700–706.15572417
Braverman LE, Pearce EN, He X, . 2006. Effects of six months of daily low-dose perchlorate exposure on thyroid function in healthy volunteers. J Clin Endocrinol Metab 91(7):2721–2724.16636123
Brechner RJ, Parkhurst GD, Humble WO, . 2000. Ammonium perchlorate contamination of Colorado River drinking water is associated with abnormal thyroid function in newborns in Arizona. J Occup Environ Med 42(8):777–782.10953814
Brown JC, Snoeyink VL, Raskin L, . 2003. The sensitivity of fixed-bed biological perchlorate removal to changes in operating conditions and water quality characteristics. Water Res 37(1):206–214.12465802
Brown-Grant K. 1966. Failure of orally administered perchlorate to affect deciduoma formation or pregnancy in the rat. J Reprod Fertil 12:353–357.4288675
Brown-Grant K, Sherwood MR. 1971. Viability of the rat blastocyst following the oral administration of potassium perchlorate or potassium iodide to the mother. J Reprod Fertil 27:265–267.4331003
BRT. 2000. Ammonium perchlorate: Effect on immune function. Burleson Research Technologies. Raleigh, NC.
Bruce RA, Achenbach LA, Coates JD. 1999. Reduction of (per)chlorate by a novel organism isolated from paper mill waste. Environ Microbiol 1(4):319–329.11207750
Buckley SG, Sclippa GC, Bazter LL, . 1999. Combustion tests of rocket motor washout material: Focus on air toxics formation potential of asbestos remediation. Sandia National Laboratories: Albuquerque, NM. DE00005953.
Bürgi H, Benguerel M, Knopp J, . 1974. Influence of perchlorate on the secretion of non-thyroxine iodine by the normal human thyroid gland. Eur J Clin Invest 4:65–69.4132128
CADHS. 2007. Perchlorate in California drinking water. California Department of Health Services, Division of Drinking Water and Environment Management. http://www.dhs.ca.gov/ps/ddwem/chemicals/perch/default.htm. January 2, 2007.
CADTSC. 2005. Perchlorate letters and comments. Past workshops on perchlorate best management practices. California Department of Toxic Substances Control. http://www.dtsc.ca.gov/LawsRegsPolicies/Regs/upload/HWMP_FLY_PLC.pdf. February 14, 2008.
Caldwell DJ, King JH, Kinkead ER, . 1995. Results of a fourteen day oral-dosing toxicity study of ammonium perchlorate. Chemical Propulsion Information Agency Publication.
CalEPA. 2004. Public health goal for perchlorate in drinking water. Sacramento, CA: California Environmental Protection Agency, Office of Environmental Health Hazard Assessment. http://www.oehha.org/water/phg/pdf/finalperchlorate31204.pdf. February 07, 2008.
CalEPA. 2007. Identification and listing of hazardous waste. Sacramento, CA: California Environmental Protection Agency, Department of Toxic Substances Control. California Code of Regulations. 22 CCR Chapter 11, Appendix X. http://chemcite.bna.com/chlw4/htm/1337.htm. February 06, 2008.
Calvo R, Jauniaux E, Gulbis B, . 2002. Fetal tissues are exposed to biologically relevant free thyroxine concentrations during early phases of development. J Clin Endocrinol Metab 87(4):1768–1777.11932315
Calvo R, Obregon MJ, Ruiz de Ona C, . 1990. Congenital hypothyroidism, as studied in rats. J Clin Invest 86:889–899.2394838
Capen CC. 1997. Mechanistic data and risk assessment of selected toxic end points of the thyroid gland. Toxicol Pathol 25(1):39–48.9061850
Capuco AV, Rice CP, Baldwin RL, . 2005. Fate of dietary perchlorate in lactating dairy cows: Relevance to animal health and levels in the milk supply. Proc Natl Acad Sci USA 102(45):16152–16157.16260728
Carr CW. 1952. Studies on the binding of small ions in protein solutions with the use of membrane electrodes. I. The binding of the chloride ion and other inorganic anions in solutions of serum albumin. Arch Biochem Biophys 40:286–294.12997214
Carrasco N. 1993. Iodide transport in the thyroid gland. Biochim Biophys Acta 1154:65–82.8507647
Chambard M, Verrier B, Gabrion J, . 1983. Polarization of thyroid cells in culture: Evidence for the basolateral localization of the iodide “pump” and of the thyroid-stimulating hormone receptor-adenyl cyclase complex. J Cell Biol 96:1172–1177.6300145
Chan ML, Reed R, Ciaramitaro DA. 2000. Advances in solid propellant formulations. In: Yang V, Brill TB, Ren W, eds. Solid propellant chemistry, combustion, and motor interior ballistics. Vol. 185. Reston, VA: American Institute of Aeronautics and Astronautics, Inc., 185–206.
Chang S, Crothers C, Lai S, . 2003. Pediatric neurobehavioral diseases in Nevada counties with respect to perchlorate in drinking water: An ecological inquiry. Birth Defects Res A Clin Mol Teratol 67:886–892.14745943
ChemIDplus. 2007. Lithium perchlorate. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. July 9, 2007.
Chow SY, Woodbury DM. 1970. Kinetic of distribution of radioactive perchlorate in rat and guinea-pig thyroid glands. J Endocrinol 47:207–218.4317286
Chow SY, Chang LR, Yen MS. 1969. A comparison between the uptakes of radioactive perchlorate and iodine by rat and guinea-pig thyroid glands. J Endocrinol 45:1–8.4310461
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clewell RA. 2008. Personal communication from Rebecca Clewell, The Hamner Institutes for Health Sciences, Research Triangle Park, NC to Agency for Toxic Substances and Disease Registry, Division of Toxicology and Environmental Medicine, Atlanta, GA. June 19, 2008.
Clewell RA, Merrill EA, Gearhart JM, . 2007. Perchlorate and radioiodide kinetics across life stages in the human: Using PBPK models to predict dosimetry and thyroid inhibition and sensitive subpopulations based on developmental stage. J Toxicol Environ Health A 70:408–428.17454566
Clewell RA, Merrill EA, Narayanan L, . 2004. Evidence for competitive inhibition of iodide uptake by perchlorate and translocation of perchlorate into the thyroid. Int J Toxicol 23(1):17–23.15162843
Clewell RA, Merrill EA, Robinson PJ. 2001. The use of physiologically based models to integrate diverse data sets and reduce uncertainty in the prediction of perchlorate kinetics across life stages and species. Toxicol Ind Health 17:210–222.12539865
Clewell RA, Merrill EA, Yu KO, . 2003a. Predicting fetal perchlorate dose and inhibition of iodide kinetics during gestation: A physiologically-based pharmacokinetic analysis of perchlorate and iodide kinetics in the rat. Toxicol Sci 73:235–255.12700398
Clewell RA, Merrill EA, Yu KO, . 2003b. Predicting neonatal perchlorate dose and inhibition of iodide uptake in the rat during lactation using physiologically-based pharmacokinetic modeling. Toxicol Sci 74:416–436.12805655
*Cline TR, Plumlee MP, Christian JE, . 1969. Effect of potassium perchlorate and sodium chloride given orally upon radioiodine deposition into milk of goats. J Dairy Sci 52(7):1124–1126.5371226
Coates JD, Anderson RT. 2000. Emerging techniques for anaerobic bioremediation of contaminated environments. Trends Biotechnol 18(10):408–412.10998506
Coates JD, Michaelidou U, Bruce RA, . 1999. Ubiquity and diversity of dissimilatory (per)chlorate-reducing bacteria. Appl Environ Microbiol 65(12):5234–5241.10583970
Cohen AP. 1993. Desiccants. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer’s encyclopedia of chemical technology. Vol. 7. New York, NY: John Wiley & Sons, Inc., 1031–1055.
Cohen RN, Weintraub BD, Wondisford FE. 2000. Thyrotropin. In: Braverman, LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia: Lippincott Williams & Wilkins, 202–219.
Collette TW, Williams TL, Urbansky ET, . 2003. Analysis of hydroponic fertilizer matrixes for perchlorate: Comparison of analytical techniques. Analyst 128(1):88–97.12572810
Conkling JA. 1996. Pyrotechnics. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 20. New York, NY: John Wiley & Sons, Inc., 680–697.
Connell JMC. 1981. Long-term use of potassium perchlorate. Postgrad Med J 57:516–517.6272249
Contempre B, Jauniaux E, Calvo R, . 1993. Detection of thyroid hormones in human embryonic cavities during the first trimester of pregnancy. J Clin Endocrinol Metab 77(6):1719–1722.8263162
*Conti A, Kneubuehl F, Studer H, . 1975. Increased iodotyrosine deiodinase activity in human goiters and in rats treated with perchlorate. In: Robbins J, Braverman LE, eds. Thyroid research: Proceedings of the 7th International Thyroid Conference, Boston, Massachusetts, June 9–13, 1975, 166–168.
Corvilain B, Dumont HE, Vassart G. 2000. Toxic adenoma and toxic multinodular goiter. In: Braverman LE, Utiger RD eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 564–572.
Costa M, Zhitkovich A, Gargas M, . 1996. Interlaboratory validation of a new assay for DNA-protein crosslinks. Mutat Res 369:13–21.8700178
Cotton FA, Wilkinson G. 1980. Advanced inorganic chemistry. New York, NY: John Wiley & Sons, 560.
Cowan D. 2000. Innovative abatement and remediation of perchlorate at McGregor, Texas weapons plant site. Soil Sediment Groundwater 5:25–26.
Cramer RJ, Yates C, Hatzinger P, . 2004. Field demonstration of in situ perchlorate bioremediation at building 1419. Indian Head, MD: U.S. Naval Sea Systems Command. ADA421555.
CRIS. 2008. Perchlorates. Current Research Information System. U.S. Department of Agriculture. http://cris.csrees.usda.gov/. February 6, 2008.
Crooks J, Wayne EJ. 1960. A comparison of potassium perchlorate, methylthiouracil, and carbimazole in the treatment of thyrotoxicosis. Lancet 1:401–404.13812986
Crump C, Michaud P, Tellez R, . 2000. Does perchlorate in drinking water affect thyroid function in newborns or school-age children? J Occup Environ Med 42(6):603–612.10874653
CSB. 1999. Chemical safety board investigators dispatched to site of fireworks factory explosion. Chemical Safety and Hazard Investigation Board. http//www.csb.gov/ (http://www.csb.gov/). April 20, 1999.
Darras VM, Hume R, Visser TJ. 1999. Regulation of thyroid hormone metabolism during fetal development. Mol Cell Endocrinol 151:37–47.10411318
Dasgupta PK, Dyke JV, Kirk AB, . 2006. Perchlorate in the United States. Analysis of relative source contributions to the food chain. Environ Sci Technol 40:6608–6614.17144285
Dasgupta PK, Martinelango PK, Jackson WA, . 2005. The origin of naturally occurring perchlorate: The role of atmospheric processes. Environ Sci Technol 39(6):1569–1575.15819211
Dean KE, Palachek RM, Noel JM, . 2004. Development of freshwater water-quality criteria for perchlorate. Environ Toxicol Chem 23(6):1441–1451.15376530
De Borba BM, Urbansky ET. 2002. Performance of poly (vinyl alcohol) gel columns on the ion chromatographic determination of perchlorate in fertilizers. J Environ Monit 4(1):49–55.
De Groef B, Decallonne R, Van der Geytem, . 2006. Perchlorate versus other environmental sodium/iodide symporter inhibitors: Potential thyroid-related health effects. Eur J Endocrinol 155:17–25.16793945
DeGroot LJ, Buhler U. 1971. Effect of perchlorate and methimazole on iodine metabolism. Acta Endocrinol 68:696–706.
de Zegher F, Vanhole C, Van den Berghe G, . 1994. Properties of thyroid-stimulating hormone and cortisol secretion by the human newborn on the day of birth. J Clin Endocrinol Metab 79:576–581.8045979
DOD. 1995. Instrumentation advances in emissions characterization from propellant/explosive combustion. Washington, DC: Department of Defense. DE960008231.
DOD. 1999. Effects of ammonium perchlorate on immunotoxicological, hematological, and thyroid parameters in B6C3F1 female mice. United States Department of Defense.
*DOD. 2005a. Success stories: Longhorn Army Ammunition Plant. Department of Defense, Perchlorate Work Group. http://www.dodperchlorateinfo.net/efforts/successes/army/longhorn.html. June 29, 2005.
*DOD. 2005b. Perchlorate treatment technology: Fact sheet: Bioreactors. Department of Defense. AFCEE/ERT Fact Sheet. http://www.dodperchlorateinfo.net/efforts/successes/army/documents/bioreactors.pdf. June 30, 2005.
DOD. 2005c. Success stories: Edwards Air Force Base. Department of Defense, Perchlorate Work Group. http://www.dodperchlorateinfo.net/efforts/successes/air-force/edwards.html. June 30, 2005.
DOD. 2005d. Perchlorate treatment technology. Fact sheet. Ion exchange. Department of Defense. AFCEE/ERT Fact Sheet. http://www.dodperchlorateinfo.net/efforts/successes/air-force/documents/Ion-Exchange.pdf. June 30, 2005.
DOD. 2006a. DOD perchlorate handbook. U.S. Department of Defense. Prepared by the Department of Defense Environmental Data Workgroup.
DOD. 2006b. Policy on DoD required actions relating to perchlorate. Office of Undersecretary of Defense. Washington, DC: U.S. Department of Defense, Office of Undersecretary of Defense. https://www.denix.osd.mil/portal/page/portal/content/environment/MERIT/EC/ECAL/Perchlorate/PolicyGuidance/PERCHLORATEPOLICY.PDF. August 7, 2008.
DOD. 2007. Department of Defense concerns with findings section of H.R. 1747, 110^th^ Congress, the “Safe Drinking Water for Health Communities Act of 2007.” Washington, DC: U.S. Department of Defense.
DOD. 2008. Emerging contaminants/MERIT. Emerging contaminants (EC): EC action list: Perchlorate: Perchlorate facts. Office of Undersecretary of Defense. U.S. Department of Defense. Washington, DC. https://www.denix.osd.mil/portal/page/portal/denix/environment/MERIT/EC/ECAL/Perchlorate/PerchlorateFacts. July 02, 2008.
Dodds ED, Kennish JM, Von Hippel FA, . 2004. Quantitative analysis of perchlorate in extracts of whole fish homogenates by ion chromatography: Comparison of suppressed conductivity detection and electrospray ionization mass spectrometry. Anal Bioanal Chem 379(5–6):681–687.
DOE. 2003. Treatment of perchlorate-contaminated groundwater using highly-selective, regenerable anion-exchange resins at Edwards Air Force Base. Oak Ridge, TN: U.S. Department of Energy. DE2003814536.
Dohán O, Portulano C, Basquin C, . 2007. The Na^+^/I^−^ symporter (NIS) mediates electroneutral active transport of the environmental pollutant perchlorate. Proc Natl Acad Sci USA 104(51):20250–20255.18077370
DOT. 2007. Hazardous materials table. Washington, DC: U.S. Department of Transportation, Research and Special Programs Administration. Code of Federal Regulations 49 CFR 172.101. http://a257.g.akamaitech.net/7/257/2422/16nov20071500/edocket.access.gpo.gov/cfr_2007/octqtr/pdf/49cfr172.101.pdf. February 14, 2008.
Dowling ALS, Zoeller RT. 2000. Thyroid hormone of maternal origin regulates the expression of RC3/neurogranin mRNA in the fetal rat brain. Mol Brain Res 82:126–132.11042365
Dowling ALS, Iannacone EA, Zoeller RT. 2001. Maternal hypothyroidism selectivity affects the expression of neuroendocrine-specific protein A messenger ribonucleic acid in the proliferative zone of the fetal rat brain cortex. Endocrinology 142(1):390–399.11145602
Druy MA. 1986. More about perchlorates and conducting polymers. Chem Eng News 64:2.
Duncan PB, Morrison RD, Vavricka E. 2005. Forensic identification of anthropogenic and naturally occurring sources of perchlorate. Environ Forensics 6:205–215.
Dunson DB. 2001. Statistical analysis of the effects of perchlorate on neurobehavior (motor activity) in SD rats. Memorandum (November 1, 2001) to Annie M. Jarabek, National Center for Environmental Assessment (MD-52). Research Triangle Park, NC: U.S. Environmental Protection Agency.
Durand MJ. 1938. Recherces sur l’elimination des perchlorates, sur leur repartition dans les organes et sur leur toxicite. Bull Soc Chim Biol 20:428–435.
Dyke JV, Ito K, Obitsu T, . 2007. Perchlorate in dairy milk. Comparison of Japan versus the United States. Environ Sci Technol 41:88–92.17265931
Eichler O. 1929. [The pharmacology of the perchlorate effect. Naunyn-Schmiedebergs.] Arch Exp Pathol Pharmakol 144:251–260. (German)
Eichler O, Hackenthal E. 1962. [Secretion and metabolism of perchlorate measured with ^36^ClO_4_.] Naunyn-Schmiedebergs Arch Exp Pathol Pharmakol 243:554–565. (German)
El Aribi H, Le Blanc YJC, Antonsen S, . 2006. Analysis of perchlorate in foods and beverages by ion chromatography coupled with tandem mass spectrometry (IC-ESI-MS/MS). Anal Chim Acta 567:39–47.17723377
Ellington JJ, Evans JJ. 2000. Determination of perchlorate at parts-per-billion levels in plants by ion chromatography. J Chromatogr A 898:193–199.11117417
Ellington JJ, Wolfe NL, Garrison AW, . 2001. Determination of perchlorate in tobacco plants and tobacco products. Environ Sci Technol 35(15):3213–3218.11506007
Ells B, Barnett DA, Purves RW, . 2000. Trace level determination of perchlorate in water matrices and human urine using ESI-FAIMS-MS. J Environ Monitor 2(5):393–397.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1992a. Code of federal regulations. U.S. Environmental Protection Agency. 49 CFR 261.22.
*EPA. 1992b. U.S. Environmental Protection Agency. Provisional non-cancer and cancer toxicity values for potassium perchlorate. Superfund Health Risk Technical Support Center. Chemical Mixtures Assessment Branch.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. U.S. Environmental Protection Agency. EPA600890066F.
EPA. 1997a. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1997b. Exposure factors handbook. Washington, DC: U.S. Environmental Protection Agency, National Center of Environmental Assessment, Office of Research and Development. EPA600P95002Fa. http://rais.ornl.gov/homepage/EFH_Final_1997_EPA600P95002Fa.pdf. July 09, 2007.
EPA. 1998a. Announcement of the drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 63(40):10274–10287.
*EPA. 1998b. Assessment of thyroid follicular cell tumors. U.S. Environmental Protection Agency. Risk Assessment Forum. EPA630R97002.
*EPA. 1998c. Perchlorate environmental contamination: Toxicological review and risk characterization based on emerging information. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. NCEA-1-0503.
*EPA. 1998d. Perchlorate ecological risk studies: A report on literature reviews and studies conducted by the ecological impact/transport and transformation subcommittee of the interagency perchlorate steering committee. Edison, NJ: U.S. Environmental Protection Agency. TR20010004. ADA397933.
EPA. 1999a. Perchlorate. U.S. Environmental Protection Agency. Office of Ground Water and Drinking Water. http://www.epa.gov/ogwdw000/ccl/perchlor/perchlo.html. June 21, 2000.
EPA. 1999b. Revisions to unregulated contaminant monitoring regulation for public water systems. U.S. Environmental Protection Agency. Fed Regist 64(180):50556–50620.
EPA. 1999c. Method 314.0. Determination of perchlorate in drinking water using ion chromatography. In: Methods for the determination of organic and inorganic compounds in drinking water. Volume 1. U.S. Environmental Protection Agency. EPA815R00014. http://nepis.epa.gov/. July 06, 2007.
EPA. 2000. Unregulated contaminant monitoring regulation for public water systems: Analytical methods for perchlorate and acetochlor; announcement of laboratory approval and performance testing (PT) program for the analysis of perchlorate. U.S. Environmental Protection Agency. Fed Regist 65(42):11372–11385.
EPA. 2001a. Survey of fertilizers and related materials for perchlorate (ClO_4_^−^). Cincinnati, OH: U.S. Environmental Protection Agency. PB2005103648. EPA600R01047.
*EPA. 2001b. Ion chromatographic determination of perchlorate ion: Analysis of fertilizers and related materials. Washington, DC: U.S. Environmental Protection Agency. PB2001105531. EPA600R01026.
*EPA. 2002a. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. wysiwyg://40/http//www.epa.gov/OGWDW/ccl/cclfs.html (http://wysiwyg://40/http//www.epa.gov/OGWDW/ccl/cclfs.html). June 2, 2002.
*EPA. 2002b. National primary drinking water regulations. Monitoring requirements for unregulated contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.40(a)(3). http://ecfr.access.gpo.gov/otcgi/cfr/otfil…Y=71724&RGN=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. June 2, 2002.
EPA. 2002c. Perchlorate environmental contamination: Toxicological review and risk characterization. U.S. Environmental Protection Agency. Office of Research and Development. NCEA-1-0503.
*EPA. 2002d. Perchlorate. U.S. Environmental Protection Agency. Office of Water. wysiwyg://30/http//www.epa.gov/ogwdw/ccl/perchlor/perchlo.html (http://wysiwyg://30/http//www.epa.gov/ogwdw/ccl/perchlor/perchlo.html). July 16, 2003.
*EPA. 2002e. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Examples of potentially incompatible waste. Appendix V. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264. http://ecfr.access.gpo.gov/otcg…=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. June 20, 2005.
*EPA. 2002f. Perchlorate ecological studies - A report on literature reviews and studies conducted by the ecological impact/transport and transformation subcommittee of the interagency perchlorate steering committee. Edison, NJ: U.S. Environmental Protection Agency. ADA397933.
EPA. 2003. Occurrence and potential sources of perchlorate releases to the environment as of April, 2003. U.S. Environmental Protection Agency. http://www.epa.gov/fedfac/pdf/perchlorate_occurrence_april03a.pdf. July 5, 2005.
*EPA. 2004a. Drinking water contaminant candidate list 2: Notice. Washington, DC: U.S. Environmental Protection Agency. Fed Regist 69(64):17406–17415.
*EPA. 2004b. A study on the accumulation of perchlorate in young head lettuce. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB2005105427. EPA600R03003.
EPA. 2005a. National primary drinking water regulations. Monitoring requirements for unregulated contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.40(a)(3).
EPA. 2005b. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Examples of potentially incompatible waste. Appendix V. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264.
EPA. 2005c. Known perchlorate releases in the U.S. – March 25, 2005. U.S. Environmental Protection Agency. http://www.epa.gov/fedfac/documents/detection_with_dates_03_25_05.xls. June 30, 2005.
*EPA. 2005d. Known or suspected perchlorate manufacturers/users in U.S. – as of April 2003. U.S. Environmental Protection Agency. http://www.epa.gov/fedfac/documents/knwn_perch_mftrs_usrs_04_03.xls. June 29, 2005.
EPA. 2005e. Perchlorate. Drinking water contaminant candidate list. Ground water & drinking water. U.S. Environmental Protection Agency. http://www.epa.gov/safewater/ccl/perchlorate/perchlorate.html. June 30, 2005.
*EPA. 2005f. Perchlorate. Federal facilities restoration and reuse. U.S. Environmental Protection Agency. http://www.epa.gov/fedfac/documents/perchlorate.htm. June 25, 2005.
EPA. 2005g. Accessing unregulated contaminant monitoring data. Office of Ground Water and Drinking Water. U.S. Environmental Protection Agency. http://www.epa.gov/safewater/data/ucmrgetdata.html. June 30, 2005.
EPA. 2005h. Method 314.1. Determination of perchlorate in drinking water using inline column concentration/matrix elimination ion chromatography with suppressed conductivity detection. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA815R05009.
EPA. 2005i. Method 331.0. Determination of perchlorate in drinking water by liquid chromatography electrospray ionization mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA815R05007.
EPA. 2005j. Method 332.0. Determination of perchlorate in drinking water by ion chromatography with suppressed conductivity and electrospray ionization mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600R05049.
EPA. 2005k. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006a. Perchlorate monitoring results-Henderson, Nevada to the lower Colorado River. December 2005 report. San Francisco, CA: U.S. Environmental Protection Agency. http://www.epa.gov/fedfac/pdf/perrpt12_05.pdf. February 12, 2008.
EPA. 2006b. Written communication April 6, 2006 to Congresswomen Solis and Congressman Dingell, United States Congress, responses to questions regarding the presence of perchlorate and other constituents found at Department of Defense facilities. U.S. Environmental Protection Agency.
EPA. 2006c. Assessment guidance for perchlorate. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. http://www.epa.gov/fedfac/pdf/perchlorate_guidance.pdf. August 04, 2008.
EPA. 2007. Drinking water: Regulatory determinations regarding contaminants on the second drinking water contaminant candidate list-preliminary determinations. U.S. Environmental Protection Agency. Fed Regist 72(83):24016–24058. http://a257.g.akamaitech.net/7/257/2422/01jan20071800/edocket.access.gpo.gov/2007/pdf/E7-7539.pdf. February 15, 2008.
EPA. 2008a. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations.40 CFR 261. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=385ea9ac5d6e0fb83be2351f0836eb09&rgn=div5&view=text&node=40:25.0.1.1.2&idno=40#PartTop. February 15, 2008.
EPA. 2008b. Personal communication from Mary T. Cooke, U.S. Environmental Protection Agency Office of Solid Waste and Emergency Response Federal Facilities Restoration and Reuse Office (FFRRO) Washington, DC to Agency for Toxic Substances and Disease Registry, Division of Toxicology and Environmental Medicine, Atlanta, GA.
EPA. 2008c. National Priorities List (NPL). NPL site totals by status and milestone. U.S. Environmental Protection Agency. http://www.epa.gov/superfund/sites/query/queryhtm/npltotal.htm. August 04, 2008.
ERG. 2004. 2004 Emergency response guidebook: A guidebook for first responders during the initial phase of a dangerous goods/hazardous materials incident. U.S. Department of Transportation, Transport Canada, Secretariat of Communications and Transportation of Mexico. http://hazmat.dot.gov/pubs/erg/gydebook.htm. July 9, 2007.
Erickson BE. 2004. Tracing the origin of perchlorate. Anal Chem 76(21):388A–389A.
Escobar del Rey F, Pastor R, Mallol J, . 1986. Effects of maternal iodine deficiency on the L-thyroxine and 3,5,3’-triiodo-L-thyronine contents of rat embryonic tissues before and after onset of fetal thyroid function. Endocrinology 118(4):1259–1265.3948782
Eskandari S, Loo DD, Dai G, . 1997. Thyroid Na+/I- symporter: Mechanism, stoichiometry, and specificity. J Biol Chem 272(43):27230–27238.9341168
Eskin BA, Merion JA, Krouse TB, . 1976. Blockade of breast iodine by perchlorate in estrogen deficiency. Excerpta Medica 378:625–629.
Eskin BA, Shuman R, Krouse T, . 1975. Rat mammary gland atypia produced by iodine blockade with perchlorate. Cancer Res 35:2332–2339.167953
Fagin JA. 2000. Molecular genetics of tumors of thyroid follicular cells. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 886–898.
Faure N, Dussault J-H. 1975. [The effect of a single dose of perchlorate on the 24-hour I 131 uptake.] Union Med Can 104(8):1208–1210. (French)175538
Fawcett JW, Clarke CWF. 1961. Aplastic anaemia due to potassium perchlorate. Br Med J 1:1537.
FDA. 1998. Code of federal regulations-Indirect food additives: Polymers. Food and Drug Administration. 21 CFR 177.1210. http://squid.law.cornell.edu/cgi-b…21&PART-177&SECTION-1210&TYPE=TEXT. June 2, 1999.
FDA. 2005. Substances for use as basic components of single and repeated use food contact surfaces. Closures with sealing gaskets for food containers. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.1210(b)(5). http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200521. June 24, 2005.
FDA. 2007a. Preliminary estimation of perchlorate dietary exposure based on FDA 2004/2005 exploratory data. Food and Drug Administration. http://www.cfsan.fda.gov/~dms/clo4ee.html. June 08, 2007.
FDA. 2007b. 2004-2005 Exploratory survey data on perchlorate in food. Food and Drug Administration. http://www.cfsan.fda.gov/~dms/clo4data.html. June 08, 2007.
FDA. 2007c. U.S. Food and Drug Administration’s total diet study: dietary intake of perchlorate and iodine. College Park, MD: U.S. Food and Drug Administration, Center for Food Safety and Applied Nutrition. (Draft).
FEDRIP. 2008. Perchlorates. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Fernandez-Rodriguez A, Galera-Davidson H, Salguero-Villadiego M, . 1991. Induction of thyroid proliferative changes in rats treated with antithyroid compound. Anat Histol Embryol 20:289–298.1665679
Fernández-Santos JM, De-Miguel M, Gonzalez-Campora R, . 2004. Ki-ras mutational analysis in rat follicular-cell proliferative lesions of the thyroid gland induced by radioactive iodine and potassium perchlorate. J Endocrinol Invest 27(1):12–17.15053237
Ferreiro B, Bernal J, Goodyear CG, . 1988. Estimation of nuclear thyroid hormone receptor saturation in human fetal brain and lung during early gestation. J Clin Endocrinol Metab 67:853–856.3417852
Fisher DA, Brown RS. 2000. Thyroid physiology in the perinatal period and during childhood. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 959–972.
Fisher DA, Oddie TH, Burroughs JC. 1962. Thyroidal radioiodine uptake rate measurement in infants. Am J Dis Child 103:738–749.13893227
Fisher J, Todd P, Mattie D, . 2000. Preliminary development of a physiological model for perchlorate in the adult male rat: A framework for further studies. Drug Chem Toxicol 23(1):243–258.10711400
Florencio Vicente MDR. 1990. [Proliferative thyroid lesions: An experimental study.] Diss Abstr Int C 54(1):176. (Spanish)
Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forhead AJ, Li J, Gilmour RS, . 2002. Thyroid hormones and the mRNA of the GH receptor and IGFs in skeletal muscle of fetal sheep. Am J Physiol Endocrinol Metab 282(1):E80–E86.11739087
GAO. 2005. Perchlorate. A system to track sampling and cleanup results is needed. Report to the Chairman, Subcommittee on Environment and Hazardous Materials, Committee on Energy and Commerce, House of Representatives. United States Government Accountability Office. http://www.gao.gov/new.items/d05462.pdf. February 13, 2008.
GAO. 2007. Department of Defense activities related to trichloroethylene, perchlorate, and other emerging contaminants. Washington, DC: United States Government Accountability Office. GAO-07-1042T. http://www.gao.gov/new.items/d071042t.pdf. February 12, 2008.
Gauss W. 1972. [Physiological and histological criteria of thyroid gland function during a single or longer treatment of potassium perchlorate in adult mice (Mus musculus). I. Long-lasting medication experiments.] Z Mikrosk Anat Forsch 85:469–500. (German)4345187
GFS. 1997. GFS Chemical Company catalog. Powell, OH: GFS Chemicals, Inc., 79–89.
Gibbs JP. 2006. A comparative toxicological assessment of perchlorate and thiocyanate based on competitive inhibition of iodine uptake as the common mode of action. Hum Ecol Risk Assess 12(1):157–173.
Gibbs JP, Ahmad R, Crump KS, . 1998. Evaluation of a population with occupational exposure to airborne ammonium perchlorate for possible acute or chronic effects on thyroid function. J Occup Environ Med 40:1072–1082.9871884
Giblin T, Frankenberger WT. 2001. Perchlorate and nitrate reductase activity in the perchlorate-respiring bacterium perclace. Microb Releases 156(4):311–315.
Giblin TL, Herman DC, Frankenberger WT. 2000. Removal of perchlorate from ground water by hydrogen-utilizing bacteria. J Environ Qual 29:1057–1062.
Ginsberg GL, Hattis DB, Zoeller RT, . 2007. Evaluation of the U.S. EPA/OSWER preliminary remediation goal for perchlorate in groundwater: Focus on exposure to nursing infants. Environ Health Perspect 115(3):361–369.17431484
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Suppl 2):65–71.7902273
Gjemdal N. 1963. Fatal aplastic anaemia following use of potassium perchlorate in thyrotoxicosis. Acta Med Scand 174:129–131.14051128
GMELIN. 1999. GMELIN97 (CAS Reg. No.: 7601-89-0; 89650-98-4). Gmelin-Institute last updated May 21, 1997. STN International. http://stnweb.cas.org/ May 11, 1999.
Godley AF, Stanbury JB. 1954. Preliminary experience in the treatment of hyperthyroidism with potassium perchlorate. J Clin Endocrinol 14:70–78.
Goldman SJ, Stanbury JB. 1973. The metabolism of perchlorate in the rat. Endocrinology 92:1536–1538.4348655
Golstein J, Corvilain B, Lamy F, . 1988. Effects of a selenium deficient diet on thyroid function of normal and perchlorate treated rats. Acta Endocrinol 118:495–502.
Green WL. 1996. Antithyroid compounds. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 7th ed. Philadelphia, PA: Lippincott-Raven Publishers, 266–276.
Greer MA, Goodman G, Pleus RC, . 2002. Health effects assessment for environmental perchlorate contamination: The dose-response for inhibition of thyroidal radioiodine uptake in humans. Environ Health Perspect 110(9):927–937.12204829
Grotheer MP. 1994. Electrochemical processing. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 9. New York, NY: John Wiley & Sons, Inc, 111–159.
Gullick RW, Lechevallier MW, Barhorst TS. 2001. Occurrence of perchlorates in drinking water sources. J Am Water Works Assoc 93:66–77.
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddow JE, Palomaki GE, Allan WC, . 1999. Maternal thyroid deficiency during pregnancy and subsequent neuropsychological development of the child. N Engl J Med 341:549–555.10451459
Harris WR, Cafferty AM, Abdollahi S, . 1998. Binding of monovalent anions to human serum transferrin. Biochim Biophys Acta 1383(2):197–210.9602126
Hartmann N, Vogler H, Vogler CH. 1971. [Effect of some thyroid inhibitors on the peripheral turnover of thyroid hormones.] Acta Biol Med Ger 26:513–521. (German)4112529
Hays MT, Solomon DH. 1965. Influence of the gastrointestinal iodide cycle on the early distribution of radioactive iodide in man. J Clin Invest 44:117–127.14254247
Herman DC, Frankenberger WT. 1998. Microbial-mediated reduction of perchlorate in groundwater. J Environ Qual 27:750–754.
Herman DC, Frankenberger WT. 1999. Bacterial reduction of perchlorate and nitrate in water. J Environ Qual 28(3):1018–1024.
Hiasa Y, Kitahori Y, Kato Y, . 1987. Potassium perchlorate, potassium iodide, and propylthiouracil: promoting effect on the development of thyroid tumors in rats treated with n-bis(2-hydroxypropyl)-nitrosamine. Jpn J Cancer Res 78:1335–1440.2828294
*Hildebrandt JD, Halmi NS. 1981. Intrathyroidally generated iodine: The role of transport in its utilization. Endocrinology 106(3):842–849.
Hindman EE II, Finnegan WG. 1980. Cloud-forming nuclei from combustion of solid-rocket-motor propellants. CPIA Publ 325:49–55.
Hobson QJG. 1961. Aplastic anemia due to treatment with potassium perchlorate. Br Med J 5236:1368–1369.
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoffmeister G. 1993. Fertilizers. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer’s encyclopedia of chemical technology. Vol. 10. New York, NY: John Wiley & Sons, Inc., 441–514.
Howard BJ, Voigt G, Segal MG, . 1996. A review of countermeasures to reduce radioiodine in milk of dairy animals. Health Phys 71(5):661–673.8887510
HSDB. 2006. Perchlorates. Hazardous Substances Data Bank. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB. December 12, 2006.
Hume R, Richard K, Kaptein E. 2001. Thyroid hormone metabolism and the developing human lung. Biol Neonate 80:18–21.11359040
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1-82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. February 15, 2005.
Iff HW, Wilbrandt W. 1963. [The dependency of iodine accumulation in thyroid slices on the ional composition of the incubation medium; influence of heart glycosides.] Biochim Biophys Acta 70:711–752. (German)14102762
IRIS. 2007. Perchlorate and perchlorate salts. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. July 11, 2007.
ITRC. 2008. Remediation technologies for perchlorate contamination in water and soil (PERC-2). Interstate Technology and Regulatory Council, Perchlorate Team. March 2008. http://www.itrcweb.org/homepage.asp. August 04, 2008.
Jackson PE, Gokhale S, Streib T, . 2000. Improved method for the determination of trace perchlorate in ground and drinking waters by ion chromatography. J Chromatogr A 888(1–2):151–158.10949483
Jackson PE, Laikhtman M, Rohrer JS. 1999. Determination of trace level perchlorate in drinking water and ground water by ion chromatography. J Chromatogr A 850(1–2):131–135.10457473
Jackson WA, Anadam SK, Anderson T, . 2005b. Perchlorate occurrence in the Texas southern high plains aquifer system. Ground Water Monit Rem 25(1):137–149.
Jackson WA, Joseph P, Laxman P, . 2005a. Perchlorate accumulation in forage and edible vegetation. J Agric Food Chem 53(2):369–373.15656674
Jaegle L, Yung YL, Toon GC, . 1996. Balloon observations of organic and inorganic chlorine in the stratosphere: The role of HClO_4_ production on sulfate aerosols. Geophys Res Lett 23(14):1749–1752.11539365
Jansen LH. 1992. Boron compounds. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 4. New York, NY: John Wiley & Sons, 364.
Jobelius HH, Scharff H-D. 1989. Hydrazoic acid and azides. In: Elvers B, Hawkins S, Ravenscroft M, et al., eds. Ullmann’s encyclopedia of industrial chemistry, Vol. A13. Basel, Switzerland: VCH, 193–197.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190:3–16.6769537
Johnson RS, Moore WG. 1961. Fatal aplastic anemia after treatment of thyrotoxicosis with potassium perchlorate. Br Med J 5236:1369–1371.
Kamienski CW, McDonald DP, Stark MW. 1995. Lithium and lithium compounds. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 15. New York, NY: John Wiley & Sons, Inc., 434–463.
Kamm G, Drescher G. 1973. [Demonstration of perchlorate in urine.] Beitr Gerichtl Med 30:206–210. (German)4349853
Kang N, Anderson TA, Jackson WA. 2006. Photochemical formation of perchlorate from aqueous oxychlorine anions. Anal Chim Acta 567:48–56.17723378
Kapitola J, Schullerova M, Schreiberova O. 1971. Blood flow and radioiodine uptake in the thyroid gland of rats after administration and discontinuation of carbimazole and perchlorate. Acta Endocrinol 68:817–825.
Kelsh MA, Buffler PA, Daaboul JJ, . 2003. Primary congenital hypothyroidism, newborn thyroid function, and environmental perchlorate exposure among residents of a Southern California community. J Occup Environ Med 45:1116–1127.14534454
Kessler FJ, Kruskemper HL. 1966. [Experimental thyroid tumors caused by many years of potassium perchlorate administration.] Klin Wochenschr 44(19):1154–1156. (German)5927802
Khan MA, Fenton SE, Swank AE. 2005. A mixture of ammonium perchlorate and sodium chlorate enhances alterations of the pituitary-thyroid axis caused by the individual chemicals in adult male F344 rats. Toxicol Pathol 33:776–783.16392172
Kiesche ES. 1994. American Pacific get go-ahead on ammonium perchlorate, sodium azide. Chem Week 154:11.
Kim K, Logan BE. 2001. Microbial reduction of perchlorate in pure and mixed culture packed-bed bioreactors. Water Res 35(13):3071–3076.11487102
Kirk AB, Martinelango PK, Tian K, . 2005. Perchlorate and iodine in dairy and breast milk. Environ Sci Technol 39:2011–2017.15871231
Kirk AB, Dyke JV, Martin CF, . 2007. Temporal patterns in perchlorate, thiocyanate, and iodide excretion in human milk. Environ Health Perspect 115(2):182–186.17384762
Klein I, Levey GS. 2000. The cardiovascular system in thyrotoxicosis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 596–604.
Koester CJ, Beller HR, Halden RU. 2000. Analysis of perchlorate in groundwater by electrospray ionization mass spectrometry/mass spectrometry. Environ Sci Technol 34(9):1862–1864.
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Kotzaurek R. 1965. Nil nocere!: Akute leberatrophie nach perchlorat-therapie. Munch Med Wochenschr 42:2067–2070.
Krevans JR, Asper SP, Rienhoff WF. 1962. Fatal aplastic anemia following use of potassium perchlorate in thyrotoxicosis. JAMA 181:182–184.
Krynitsky AJ, Niemann RA, Nortrup DA. 2004. Determination of perchlorate anion in foods by ion chromatography–tandem mass spectrometry. Anal Chem 76 (18):5518–5522.15362915
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krynitsky AJ, Niemann RA, Nortrup DA. 2004. Determination of perchlorate anion in foods by ion chromatography - tandem mass spectrometry. Anal Chem 76(18):5518–5522.15362915
Ladenson PW. 2000. Diagnosis of hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 848–852.
Lamm SH. 2003. Letters to the editor: Perchlorate exposure does not explain differences in neonatal thyroid function between Yuma and Flagstaff. J Occup Environ Med 45(11):1131–1132.14610392
Lamm SH, Doemland M. 1999. Has perchlorate in drinking water increased the rate of congenital hypothyroidism? J Occup Environ Med 41(5):409–411.10337612
Lamm SH, Braverman LE, Li FX, . 1999. Thyroid health status of ammonium perchlorate workers: A cross-sectional occupational health study. J Occup Environ Med 41(4):248–260.10224590
Lampe L, Modis L, Gehl A. 1967. Effect of potassium perchlorate on the foetal rabbit thyroid. Acta Med Acad Sci Hung 23(3):223–232.4168139
*Langer P. 1968. Fluctuation of thyroid function following a single and repeated administration of antithyroid drugs. Endocrinology 83:1268–1272.4177462
Larsen PR. 1989. Maternal thyroxine and congenital hypothyroidism. N Engl J Med 321:44–46.2733744
*Larsson-Nyren G. 1996. Perchlorate is hypoglycaemic by amplifying glucose-stimulated insulin secretion in mice. Acta Physiol Scand 158:71–76.8876750
Laue W, Thiemann M, Scheibler E, . 1991. Nitrates and nitrites. In: Elvers B, Hawkins S, Schulz G, eds. Ullmann’s encyclopedia of industrial chemistry. Vol. A17. New York, NY: VCH Publishers, 265, 270, 271, 290, 291.
Lawrence J, Lamm S, Braverman LE. 2001. Letter to the editor. Low dose perchlorate (3 mg daily) and thyroid function. Thyroid 11(3):295.11327623
Lawrence JE, Lamm SH, Pino S, . 2000. The effect of short-term low-dose perchlorate on various aspects of thyroid function. Thyroid 10(8):659–663.11014310
Lazar MA. 1993. Thyroid hormone receptors: Multiple forms, multiple possibilities. Endocrine Rev 14(2):184–193.8325251
Lazarus JH, Harden RM, Robertson JW. 1974. Quantitative studies of the inhibitory effect of perchlorate on the concentration of ^36^C1O_4_^−^ ^125^I^−^ and ^99m^TcO_4_^−^ in salivary glands of male and female mice. Arch Oral Biol 19(7):493–498.4370307
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
*Lengemann FW. 1973. Reduction of iodine transfer to milk of cows after perchlorate ingestion. J Dairy Sci 56:753–756.4350658
Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levy O, Dai G, Riedel C, . 1997. Characterization of the thyroid Na^+^/I^−^ symporter with an anti-COOH terminus antibody. Proc Natl Acad Sci U S A 94:5568–5573.9159113
Levy O, De la Vieja A, Carrasco N. 1998a. The Na^+^/I^−^ symporter (NIS): Recent advances. J Bioenerg Biomembr 30(2):195–206.9672241
Lewandowski TA, Seeley MR, Beck BD. 2004. Interspecies differences in susceptibility to perturbation of thyroid homeostasis: A case study with perchlorate. Regul Toxicol Pharmacol 39(3):348–362.15135213
Lewis RJ. 2000. Sax’s dangerous properties of industrial materials. New York, NY: John Wiley & Sons, Inc., 2854–2856.
Lewis RJ. 2001. Potassium perchlorate, magnesium perchlorate, lithium perchlorate, ammonium perchlorate, and sodium perchlorate. In: Hawley’s condensed chemical dictionary. New York, NY: Van Nostrand Reinhold Company, 916, 689, 677, 65, 64, 1021.
Li FX, Byrd DM, Deyhle GM, . 2000a. Neonatal thyroid-stimulating hormone level and perchlorate in drinking water. Teratology 62:429–431.11091365
Li Z, Li FX, Byrd D, . 2000b. Neonatal thyroxine level and perchlorate in drinking water. J Occup Environ Med 42(2):200–205.10693082
Li FX, Squartsoff L, Lamm SH. 2001. Prevalence of thyroid diseases in Nevada counties with respect to perchlorate in drinking water. J Occup Environ Med 43(7):630–634.11464394
Lindner V. 1993. Explosives and propellants. In: Kroschwitz J, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 10. New York, NY: John Wiley & Sons, 69, 115–125.
Liu Y, Mou S. 2003. Determination of trace levels of haloacetic acids and perchlorate in drinking water by ion chromatography with direct injection. J Chromatogr A 997(1–2):225–235.12830896
Liu Y, Mou S, Heberling S. 2002. Determination of trace level bromate and perchlorate in drinking water by ion chromatography with an evaporative preconcentration technique. J Chromatogr A 956(1–2):85–91.12108672
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Logan BE. 1998. A review of chlorate- and perchlorate-respiring microorganisms. Biorem J 2(2):69–79.
Logan BE. 2001. Assessing the outlook for perchlorate remediation. Environ Sci Technol 35(23):482A–487A.
Logan BE, LaPoint D. 2002. Treatment of perchlorate-and nitrate-contaminated groundwater in an autotrophic, gas phase, packed-bed bioreactor. Water Res 36(14):3647–3653.12230211
Logan BE, Bliven AR, Olsen SR, . 1998. Growth kinetics of mixed cultures under chlorate-reducing conditions. J Environ Eng 124:1008–1011.
Logan BE, Wu J, Unz RF. 2001a. Biological perchlorate reduction in high-salinity solutions. Water Res 35(12):3034–3038.11471705
Logan BE, Zhang H, Mulvaney P, . 2001b. Kinetics of perchlorate- and chlorate-respiring bacteria. Appl Environ Microbiol 67(6):2499–2506.11375156
Logonder-Mlinsek M, Kalisnik M, Pajer Z. 1985. Follicular, parafollicular and mast cells in mouse thyroid gland after antithyroid drug application. Acta Sterol 4(1):67–76.
Lyman WJ, Reehyl WF, Rosenblatt DH. 1990. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. Washington, DC: American Chemical Society.
MacDermott M. 1992. Intracellular sodium and potassium activities of skeletal muscle fibres of hypothyroid rats. Exp Physiol 77:649–652.1326291
Magnuson ML, Urbansky ET, Kelty CA. 2000. Determination of perchlorate at trace levels in drinking water by ion-pair extraction with electrospray ionization mass spectrometry. Anal Chem 72:25–29.10655630
Mahle DA, Yu KO, Narayanan L, . 2003. Changes in cross-fostered Sprague-Dawley rat litters exposed to perchlorate. Int J Toxicol 22:87–94.12745989
Mannisto PT, Ranta T, Leppaluoto J. 1979. Effects of methylmercaptoimidazole (MMI), propylthiouracil (PTU), potassium perchlorate (KClO_4_) and potassium iodide (KI) on the serum concentrations of thyrotrophin (TSH) and thyroid hormones in the rat. Acta Endocrinol 91:271–281.
Martinelango PK, Tian K, Dasgupta PK. 2006. Perchlorate in seawater. Bioconcentration of iodide and perchlorate by various seaweed species. Anal Chim Acta 567:100–107.17723385
Martino E, Bartalena L, Bogazzi F, . 2001. The effects of amiodarone on the thyroid. Endocrine Rev 22(2):240–254.11294826
MassDEP. 2006a. The occurrence and sources of perchlorate in Massachusetts. Massachusetts Department of Environmental Protection. http://www.mass.gov/dep/water/drinking/percinfo.htm. December 28, 2006.
MassDEP. 2006b. Maximum contaminant level for inorganic chemicals. Boston, MA: Massachusetts Department of Environmental Protection. Code of Massachusetts Regulations. 310 CMR 22.06. http://www.mass.gov/dep/service/regulations/310cmr22.pdf. February 14, 2008.
MassDPH. 1994. Right to Know list. Boston, MA: Massachusetts Department of Public Health. Code of Massachusetts Regulations. 105 CMR 670, Appendix A. http://chemcite.bna.com/chlw4/htm/262.htm. February 06, 2008.
Matsuzaki S, Suzuki M. 1981. Paradoxical effect of perchlorate on thyroidal weight, glucose 6-phosphate dehydrogenase and polyamines in methylthiouracil-treated rats. Acta Endocrinol 97:491–495.
Mausteller JW. 1996. Oxygen-generation systems. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 17. New York, NY: John Wiley & Sons, Inc., 940–952.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McLanahan ED, Campbell JL, Ferguson DC, . 2007. Low-dose effects of ammonium perchlorate on the hypothalamic-pituitary-thyroid axis of adult male rats pretreated with PCB126. Toxicol Sci 97(2):308–317.17379623
Mendiratta SK, Dotson RL, Brooker RT. 1996. Perchloric acid and perchlorates. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 18. New York, NY: John Wiley & Sons, Inc., 157–170.
Merrill CI, O’Drobinak JD. 1998. Sea water immersion of GEM II propellant. 1998 JANNAF Propellant Development & Characterization Subcommittee and Safety & Environmental Protection Subcommittee Joint Meeting. Vol. 1. CPIA Publ 674:561–567.
Merrill EA, Clewell RA, Gearhart JM, . 2003. PBPK predictions of perchlorate distribution and its effect on thyroid uptake of radioiodide in the male rat. Toxicol Sci 73:256–269.12700397
Merrill EA, Clewell RA, Robinson PJ, . 2005. PBPK model for radioactive iodide and perchlorate kinetics and perchlorate-induced inhibition of iodide uptake in humans. Toxicol Sci 83(1):25–43.15509666
Mill T. 1982. Hydrolysis and oxidation processes in the environment. Environ Toxicol Chem 1:135–141.
Millero FJ. 1990. Effect of ionic interactions on the oxidation rates of metals in natural waters. Chemical modeling in aqueous systems II. Vol. 416. American Chemical Society.
Min B, Evans PJ, Chu AK, . 2004. Perchlorate removal in sand and plastic media bioreactors. Water Res 38(1):47–60.14630102
Morgan JW, Cassady RE. 2002. Community cancer assessment in response to long-time exposure to perchlorate and trichloroethylene in drinking water. J Occup Environ Med 44:616–621.12134524
Morgans ME, Trotter WR. 1960. Potassium perchlorate in thyrotoxicosis. Br Med J 2:1086–1087.
*Morreale de Escobar G, Calvo R, Obregon MJ, . 1990. Contribution of maternal thyroxine to fetal thyroxine pools in normal rats near term. Endocrinology 126(5):2765–2767.2328706
Morreale de Escobar G, Obregon MJ, Escobar del Rey F. 2000. Is neuropsychological development related to maternal hypothyroidism or to maternal hypothyroxinemia? J Clin Endocrinol Metab 85(11):3975–3987.11095417
Morreale de Escobar G, Pastor R, Obregon MJ, . 1985. Effects of maternal hypothyroidism on the weight and thyroid hormone content of rat embryonic tissues, before and after onset of fetal thyroid function. Endocrinology 117(5):1890–1900.4042969
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Mukhopadhyay S, Ghosh D, Chatterjee A, . 2005. Evaluation of possible goitrogenic and anti-thyroidal effect of nitrate. A potential environmental pollutant. Indian J Physiol Pharmacol 49(3):284–288.16440845
Murray CW, Egan SK, Kim H, . 2008. US Food and Drug Administration’s Total Diet Study: Dietary intake of perchlorate and iodine. J Expo Sci Environ Epidemiol EPUB ahead of print (2 January 2008). http://www.nature.com/jes. February 14, 2008. doi:10.1038/sj.jes.7500648
Nair LM, Saari-Nordhaus R, Montgomery RM. 1997. Applications of a new methacrylate-based anion stationary phase for the separation of inorganic anions. J Chromatogr 789:127–134.
Nakamura S, Kosaka H. 1989. [Genotoxicity of inorganic metal compounds with umu test.] Jpn J Ind Health 31:430–431. (Japanese)
Nakamura Y, Kotani T, Ohtaki S. 1990. Transcellular iodide transport and iodination on the apical plasma membrane by monolayer porcine thyroid cells cultured on collagen-coated filters. J Endocrinol 126:275–281.2401868
Narayanan L, Butler GW, Yu KO, . 2003. Sensitive high-performance liquid chromatography method for the determination of low levels of perchlorate in biological samples. J Chromatogr B Analyt Technol Biomed Life Sci 788(2):393–399.
NAS. 2005. Health implications of perchlorate ingestion. Washington, DC: National Academies Press. http://www.nap.edu/books/0309095689/html/. January 31, 2005.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
Nilsson M, Bjorkman U, Ekholm R, . 1990. Iodide transport in primary cultured thyroid follicle cells: evidence of a TSH-regulated channel mediating iodide efflux selectively across the apical domain of the plasma membrane. Eur J Cell Biol 52:270–281.1706997
NIOSH. 1995. National Occupational Exposure Survey. Cincinnati, OH: Department of Health and Human Services, National Institute for Occupational Safety and Health. March 29, 1989.
NIOSH. 2005. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention, http://www.cdc.gov/niosh/npg/npgdname.html. June 24, 2005.
NJDEP. 2007. NJ environmental hazardous substance list pursuant to NJ community right to know (N.J.A.C. 7:1G) by CAS number. Trenton, NJ: New Jersey Department of Environmental Protection. New Jersey Administrative Code. NJAC 7:1G, Appendix A. http://www.nj.gov/dep/opppc/crtk/Melissa/ehscasno.pdf. February 14, 2008.
NJDHSS. 2006. Workplace hazardous substance list and special health hazard substance list. Trenton, NJ: New Jersey Department of Health and Senior Services. New Jersey Administrative Code. NJAC 8:59, Appendix A and B. http://chemcite.bna.com/chlw4/htm/110.htm. February 06, 2008.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press. National Research Council.
NTP. 2004. Report on carcinogens. 11th edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. February 15, 2005.
Nzengung VA, Penning H, O’Niell W. 2004. Mechanistic changes during phytoremediation of perchlorate under different root-zone conditions. Int J Phytoremediation 6(1):63–83.15224776
Nzengung VA, Wang C, Harvey G. 1999. Plant-mediated transformation of perchlorate into chloride. Environ Sci Technol 33:1470–1478.
Okamoto HS, Rishi DK, Steeber WR, . 1999. Using ion chromatography to detect perchlorate. J Am Water Works Assoc 91(10):73–84.
O’Neil MJ, ed. 2001. The Merck index. 13th ed. Whitehouse Station, NJ: Merck & Co., Inc., 92, 992, 1017, 1371, 1545.
O’Neill B, Magnolato D, Semenza G. 1987. The electrogenic, Na+-dependent I- transport system in plasma membrane vesicles from thyroid glands. Biochim Biophys Acta 896:263–274.3801472
Oppenheimer JH, Schwartz HL. 1997. Molecular basis of thyroid hormone-dependent brain development. Endocrine Rev 18(4):462–475.9267760
Ortiz-Caro J, Pastor RM, Jolin T. 1983. Effects of KClO4 in propylthiouracil-hypothyroid rats. Acta Endocrinol 103:81–87.
*OSHA. 2005a. Safety and health regulations for construction. List of highly hazardous chemicals, toxics and reactives. Appendix A. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.64.
*OSHA. 2005b. Occupational safety and health standards. List of highly hazardous chemicals, toxic and reactives. Appendix A. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.119.
OSHA. 2005c. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.64, Appendix A. http://www.osha.gov/comp-links.html. June 24, 2005.
OSHA. 2005d. Highly hazardous chemicals. Occupational safety and health standards. Code of Federal Regulations. 29 CFR 1910.119, Appendix A. http://www.osha.gov/comp-links.html. February 16, 2005.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
PADLI. 2007. Hazardous substance lists. Harrisburg, PA: Pennsylvania Department of Labor and Industry. Title 34, Chapter 323, Appendix A. http://chemcite.bna.com/chlw4/htm/151/htm. February 06, 2008.
Pajer Z, Kalisnik M. 1991. The effect of sodium perchlorate and ionizing irradiation on the thyroid parenchymal and pituitary thyrotropic cells. Oncology 48:317–320.1653924
Papini MP, Majone M. 1997. Experimental investigation of transport of strongly retained species by soil columns. Water Air Soil Pollut 95:337–351.
Paulus BF, Bazar MA, Salice CJ, . 2007. Perchlorate inhibition of iodide uptake in normal and iodine-deficient rats. J Toxicol Environ Health A 70(13):1142–1149.17558809
Pearce EN, Leung AM, Blount BC, . 2007. Breast milk iodine and perchlorate concentrations in lactating Boston-area women. J Clin Endocrine Metab 92:1673–1677.17311853
Perron B, Rodriguez A-M, Leblanc G, . 2001. Cloning of the mouse sodium iodide symporter and its expression in the mammary gland and other tissues. J Endocrinol 170:185–196.11431151
Pintar JE. 2000. Normal development of the hypothalamic-pituitary-thyroid axis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 7–19.
Plummer IN, Bohlke JK, Doughten MW. 2006. Perchlorate in Pleistocene and Holocene groundwater in north-central New Mexico. Environ Sci Technol 40:1757–1763.16570594
Polesello S, Valsecchi S, Cavalli S, . 2001. Ion-chromatographic screening method for monitoring arsenate and other anionic pollutants in ground waters of Northern Italy. J Chromatogr A 920:231–238.11453004
Pop VJ, Kuijpenst JL, van Baar AL, . 1999. Low maternal free thyroxine concentrations during early pregnancy are associated with impaired psychomotor development in infancy. Clin Endocrin 50:149–155.
*Poredos P. 1981. The dependence of the microstructure of the rat’s thyroid gland on the TSH. Stereol Iugosl 3(Supp 1):577–583.
Porterfield SP, Hendrich CE. 1993. The role of thyroid hormones in prenatal and neonatal neurological development-current perspectives. Endocrine Rev 14(1):94–106.8491157
Postel S. 1957. Placental transfer of perchlorate and triiodothyronine in the guinea pig. Endocrinology 60:53–66.13384383
Puls RW, Powell RM. 1992. Transport of inorganic colloids through natural aquifer material: implications for contaminant transport. Environ Sci Technol 26:614–621.
Rajagopalan S, Anderson TA, Fahlquist L, . 2006. Widespread presence of naturally occurring perchlorate in high plains of Texas and New Mexico. Environ Sci Technol 40:3156–3162.16749675
Renner R. 2005. Atmospheric processes may create perchlorate. Environ Sci Technol 39(6):120A.
Rice CP, Baldwin RL, Abbott LC. 2007. Predicting perchlorate exposure in milk from concentrations in dairy feed. J Agric Food Chem 55(21):8806–8813.17892259
RIDLT. 2007. Hazardous substance list. Cranston, RI: Rhode Island Department of Labor and Training. http://chemcite.bna.com/chlw4/htm/617.htm. February 06, 2008.
Rillema JA, Rowady DL. 1997. Characteristics of the prolactin stimulation of iodide uptake in mouse mammary gland explants. Proc Soc Exp Biol Med 215:366–369.9270719
Rillema JA, Yu TX, Jhiang SM. 2000. Effect of prolactin on sodium iodide symporter expression in mouse mammary gland explants. Am J Physiol Endocrinol Metab 279:E769–E772.11001757
Robbins J. 2000. Thyroid hormone transport proteins and the physiology of hormone binding. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 105–120.
Rodriguez AF, Davidson HG, Villadiego MS, . 1991. Induction of thyroid proliferative changes in rats treated with antithyroid compound. Anat Histol Embryol 20:289–298.1665679
Rovet J, Ehrlich R, Sorbara D. 1987. Intellectual outcome in children with fetal hypothyroidism. J Pediatr 110(5):700–704.3572621
San RHC, Clarke JJ. 1999. In vitro mammalian cell gene mutation test (L5178Y/TK+/- mouse lymphoma assay). Rockville, MD: Perchlorate Study Group. BioReliance Study Number G98BAO6.702.
Sanchez CA, Blount BC, Valentin-Blasini L, . 2007. Perchlorate, thiocyanate, and nitrate in edible cole crops (Brassica sp.) produced in the lower Colorado River region. Bull Environ Contam Toxicol 79:655–659.17962898
Sanchez CA, Crump KS, Krieger RI, . 2005a. Perchlorate and nitrate in leafy vegetables of North America. Environ Sci Technol 39(24):8381–9397.
Sanchez CA, Krieger RI, Khandaker N, . 2005b. Accumulation and perchlorate exposure potential of lettuce produced in the lower Colorado River region. J Agric Food Chem 53(13):5479–5486.15969537
Sanchez CA, Krieger RI, Khandaker N, . 2006. Potential perchlorate exposure from Citrus sp. Irrigated with contaminated water. Anal Chim Acta 567:33–38.17723376
Sangan P, Motlag DB. 1986. Activities of aldolase, lactate dehydrogenase, glucose-6-phosphatase, and arginase in perchlorate toxicity. Curr Sci 55:1238–1240.
Sangan P, Motlag DB. 1987. Glycogen metabolism in liver in perchlorate-treated rats. Curr Sci 56:88–90.
Sato E, Nakashima T, Miura Y, . 2001. Phenotypes associated with replacement of His723 by Arg in the Pendred syndrome gene. Eur J Endocrinol 145:697–703.11720893
Scanlon MF, Toft AD. 2000. Regulation of thyrotropin secretion. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 234–253.
Scatchard G, Black ES. 1949. The effect of salts on the isoionic and isoelectric points of proteins. J Phys Colloid Chem 53:88–99.18124175
Scheffee RS, Wheatley BK. 1999. Ammonium perchlorate-based gas generator compositions containing chlorine scavengers for inflation of air bags. Patent # 5,861,571.
Scheuplein RJ, Bronaugh RL. 1983. Percutaneous absorption. In: Goldsmith LA, ed. Biochemistry and physiology of the skin. New York, NY: Oxford University Press, 1255–1295.
Schilt AA. 1979. Preparation and properties of perchloric acid. Perchloric acid and perchlorates. Columbus, Ohio: The G. Frederick Smith Chemical Company, 9–63.
Schonbaum E, Sellers EA, Gill MJ. 1965. Some effects of perchlorate on the distribution of 131-iodide. Acta Endocrinol 50:195–201.
Schröder-van der Elst JP, van der Heide D, Kasteljin J, . 2001. The expression of sodium/iodide symporter is up-regulated in the thyroid of fetuses of iodine-deficient rats. Endocrinology 142:3736–3741.11517148
Schwartz HL, Lazar MA, Oppenheimer JH. 1994. Widespread distribution of immunoreactive thyroid hormone [B]2 receptor (TR[B]2) in the nuclei of extrapituitary rat tissues. J Biol Chem 269(40):24777–24782.7929155
Schwartz J. 2001. Gestational exposure to perchlorate is associated with measures of decreased thyroid function in a population of California neonates. Thesis. Berkely, CA: University of California.
Scinicariello F, Murray HE, Smith L, . 2005. Genetic factors that might lead to different responses in individuals exposed to perchlorate. Environ Health Perspect 113(11):1479–1484.16263499
Selivanova LN, Vorobieva EN. 1969. [Toxicology of ammonium perchlorate during repeated action on the organism.] Farmakol Toksikol 32:480–482. (Russian)4311480
Selivanova LN, Boltromeyuk LP, Aref’eva ZS, . 1986. [Dynamics of the absorption and elimination of perchloric acid salts in laboratory animals and livestock.] Khim Selsk Khoz 106(5):43–45. (Russian)
SERDP. 2005. Alternative causes of wide-spread, low concentration perchlorate impacts to groundwater. Strategic Environmental Research and Development Program. Department of Defense. ADA. http://stinet.dtic.mil/cgi-bin/GetTRDoc?AD=ADA435950&Location=U2&doc=GetTRDoc.pdf. February 12, 2008.
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shen DHY, Kloos RT, Mazzaferri EL, . 2001. Sodium iodide symporter in health and disease. Thyroid 11(5):415–425.11396700
Shevtsova NM, Kozlov IA, Novitskii VV. 1994. [Mechanism of hematopoietic disorders in primary experimental hypothyroidsm.] Patol Fiziol Eksp Ter Jan-Mar 1994(1):14–16. (Russian)
Shimura H, Haraguchi K, Miyazaki A, . 1997. Iodide uptake and experimental ^131^I therapy in transplanted undifferentiated thyroid cancer cells expressing the Na^+^/I^−^ symporter gene. Endocrinology 138(10):4493–4496.9322970
SI/EPA. 2008. Perchlorates. The Science Inventory. U.S. Environmental Protection Agency. http://cfpub.epa.gov/si/. February 6, 2008.
Siglin JC, Mattie DR, Dodd DE, . 2000. A 90-day drinking water toxicity study in rats of the environmental contaminant ammonium perchlorate. Toxicol Sci 57:61–74.10966512
Silva JE, Matthews PS. 1984. Production rates and turnover of triiodothyronine in rat-developing cerebral cortex and cerebellum. J Clin Invest 74:1035–1049.6470136
Singh G, Kapoor IPS, Mannan SM, . 2000. Studies on energetic compounds part 8: Thermolysis of salts of HNO_3_ and HClO_4_. J Hazard Mater A79(1–2):1–18.
Smanik PA, Liu Q, Furminger TL, . 1996. Cloning of the human sodium iodide symporter. Biochem Biophys Res Commun 226:339–345.8806637
Smanik PA, Ryu K, Theil KS, . 1997. Expression, exon-intron organization, and chromosome mapping of the human sodium iodide symporter. Endocrinology 138(8):3555–3558.9231811
Smith PN, Lu Y, McMurry ST, . 2004. Perchlorate in water, soil, vegetation, and rodents collected from the Las Vegas Wash, Nevada, USA. Environ Pollut 132(1):121–127.15276280
Smith PN, Theodorakis CW, Anderson TA, . 2001. Preliminary assessment of perchlorate in ecological receptors at the Longhorn Army ammunition plant (LHAAP), Karnack, Texas. Ecotoxicology 10:305–313.11556118
Snyder SA, Pleus RC, Vanderford BJ, . 2006. Perchlorate and chlorate in dietary supplements and flavor enhancing ingredients. Anal Chim Acta 567:26–32.17723375
Snyder SA, Vanderford BJ, Rexing DJ. 2005. Trace analysis of bromate, chlorate, iodate, and perchlorate in natural and bottled waters. Environ Sci Technol 39(12):4586–4593.16047796
Soldin OP, Braverman LE, Lamm SH. 2001. Perchlorate clinical pharmacology and human health: A review. Ther Drug Monit 23:316–331.11477312
Southwell N, Randall K. 1960. Potassium perchlorate in thyrotoxicosis. Lancet 1:653–654.
Spaulding SW. 2000. Biological actions of thyrotropin. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 227–233.
Spaulding SW, Burrow GN, Bermudez F, . 1972. The inhibitory effect of lithium on thyroid hormone release in both euthyroid and thyrotoxic patients. J Clin Endocrinol Metab 35:905–911.4634489
*Spitzweg C, Joba W, Eisenmenger W. 1998. Analysis of human sodium iodide symporter gene expression in extrathyroid tissues and cloning of its complementary deoxyribonucleic acids from salivary gland, mammary gland, and gastric mucosa. J Clin Endocrinol 83(5):1746–1751.
Spitzweg C, Joba W, Morris JC, . 1999. Regulation of sodium iodide symporter gene expression in FRTL-5 rat thyroid cells. Thyroid 9(8):65–69.10037079
Sposito G, Traina SJ. 1987. An ion-association model for highly saline, sodium chloride-dominated waters. J Environ Qual 16:80–85.
Spreca A, Musy JP. 1974. Comportement des mastocytes chez les rats traites au perchlorate de potassium. Experientia 30(3):278–279.4363225
*Spreca A, Laszlo M, Musy JP. 1973. [Biochemical study of various mucopolysaccharide constituents and glycoproteins of serum and of several organs of rats treated with potassium perchlorate.] Pharm Acta Helv 48:297–306. (French)4361598
SRI. 2007. Directory of chemical producers: United States of America. Menlo Park, CA: SRI Consulting, 46, 47, 178, 179, 426.
Stanbury JB, Wyngaarden JB. 1952. Effect of perchlorate on the human thyroid gland. Metabolism 1:533–539.13002073
Stiefel EI. 1995. Molybdenum compounds. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, 957, 962.
Stockigt JR. 2000. Serum thyrotropin and thyroid hormone measurements and assessment of thyroid hormone transport. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 376–392.
Sundberg SE, Ellington JJ, Evans JJ, . 2003. Accumulation of perchlorate in tobacco plants: Development of a plant kinetic model. J Environ Monit 5:505–512.12833996
Sunar O. 1963. Case report—Agranulocytosis associated with potassium perchlorate treatment. J Laryngol Otol 77:353–355.13979276
Susarla S, Collette TW, Garrison AW, . 1999. Perchlorate identification in fertilizers. Environ Sci Technol 33(19):3469–3472.
Susarla S, Collette TW, Garrison AW, . 2000. Additions and corrections; perchlorate identification in fertilizers. Environ Sci Technol 34(1):224.
Sztanyik LB, Turai I. 1988. Modification of radioiodine incorporation in the fetus and newborn rats by the thyroid blocking agents. Acta Phys Hungaria 72:343–354.
Tan K, Anderson TA, Jackson WA. 2005. Temporal and spatial variation of perchlorate in streambed sediments: Results from in-situ dialysis samplers. Environ Pollut 136(2):283–291.15840536
Tan K, Jackson WA, Anderson TA. 2004b. Fate of perchlorate-contaminated water in upflow wetlands. Water Res 38(19):4173–4185.15491665
Tarin-Remohi MJ, Jolin T. 1972. [Effects of corticoid and adrenalectomy on thyroid weight of rats treated with goitrogens.] Rev Esp Fisiol 28:1–12. (Spanish)4680099
Taurog A. 2000. Hormone synthesis: Thyroid iodine metabolism. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 61–84.
Téllez RT, Chacon PM, Abarca CR, . 2005. Long-term environmental exposure to perchlorate through drinking water and thyroid function during pregnancy and the neonatal period. Thyroid 15(9):963–975.16187904
Theodorakis C, Rinchard J, Anderson T, . 2006. Perchlorate in fish from a contaminated site in east-central Texas. Environ Pollut 139:59–69.15993996
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thorpe-Beeston JG, Nicolaides KH, Felton CV, . 1991. Maturation of the secretion of thyroid hormone and thyroid-stimulating hormone in the fetus. N Engl J Med 324:532–536.1899469
Tian K, Dasgupta PK, Anderson TA. 2003. Determination of trace perchlorate in high-salinity water samples by ion chromatography with on-line preconcentration and preelution. Anal Chem 75(3):701–706.12585505
Tikkanen MW. 2006. Development of a drinking water regulation for perchlorate in California. Anal Chim Acta 567:20–25.17723374
Tipton DK, Rolston DE, Scow KM. 2003. Bioremediation and biodegradation: Transport and biodegradation of perchlorate in soils. J Environ Qual 32(1):40–46.12549540
Tollenaar H, Martin C. 1972. Perchlorate in Chilean nitrate as the cause of leaf rugosity in soybean plants in Chile. Phytopathology 62:1164–1166.
Tonacchera M, Pinchera A, Dimida A, . 2004. Relative potencies and additivity of perchlorate, thiocyanate, nitrate, and iodide on the inhibition of radioactive iodide uptake by the human sodium iodide symporter. Thyroid 14(12):1012–1019.15650353
Toro Guillen M. 1991. [Reversibility of proliferative thyroid lesions.] Diss Abstr Int C 54:1186. (Spanish)
Tran N, Valentín-Blasini, Blount BC, . 2008. Thyroid-stimulating hormone increases active transport of perchlorate into thyroid cells. Am J Physiol Endocrinol Metab 294:E802–E806.18303123
TRI05. 2007. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. July 6, 2007.
Urbansky ET. 1998. Perchlorate chemistry: Implications for analysis and remediation. Biorem J 2(2):81–95.
Urbansky ET. 2000. Quantitation of perchlorate ion: Practices and advances applied to the analysis of common matrices. Crit Rev Anal Chem 30(4):311–343.
Urbansky ET. 2002. Perchlorate as an environmental contaminant. Environ Sci Pollut Res Int 9(3):187–192.12094532
Urbansky ET, Brown SK. 2003. Perchlorate retention and mobility in soils. J Environ Monit 5:455–462.12894753
Urbansky ET, Collette TW. 2001. Comparison and evaluation of laboratory performance on a method for the determination of perchlorate in fertilizers. J Environ Monitor 3(5):454–462.
Urbansky ET, Brown SK, Magnuson ML, . 2001. Perchlorate levels in samples of sodium nitrate fertilizer derived from Chilean caliche. Environ Pollut 112(3):299–302.11291435
Urbansky ET, Gu B, Magnuson ML, . 2000a. Survey of bottled waters for perchlorates by electrospray ionization mass spectrometry (ESI-MS) and ion chromatography. J Sci Food Agric 80(12):1798–1804.
Urbansky ET, Magnuson ML, Kelty CA, . 2000b. Comment on “perchlorate identification in fertilizers” and the subsequent addition/correction. Environ Sci Technol 34(20):4452–4453.
Urbansky ET, Magnuson ML, Kelty CA, . 2000c. Perchlorate uptake by salt cedar (Tamarix ramosissima) in the Las Vegas Wash riparian ecosystem. Sci Total Environ 256:227–232.10902849
U.S. Air Force Space Missile Systems Center. 2002. Biological effects of inadvertant perchlorate releases during launch operations. Los Angeles Air Force Base, CA: U.S. Air Force Space Missile Systems Center, Environmental Management Branch. ADA414070.
U.S. Army Corp of Engineers. 2004. Field screening method for perchlorate in water and soil. Hanover, NH: U.S. Army Corp of Engineers.
U.S. Census Bureau. 1999. Census bureau facts for features: Fireworks. June 25, 1998. http://www.census.gov/Press-Release/ff98-08.html.
USITC. 2008. United States International Trade Commission. http://dataweb.usitc.gov/. February 11, 2008.
Uyttersprot N, Pelgrims N, Carrasco N, . 1997. Moderate doses of iodide in vivo inhibit cell proliferation and the expression of thyroperoxidase and Na^+^/I^−^ symporter mRNAs in dog thyroid. Mol Cell Endocrinol 131:195–203.9296378
Valentín-Blasini L, Mauldin JP, Maple D, . 2005. Analysis of perchlorate in human urine using ion chromatography and electrospray tandem mass spectrometry. Anal Chem 77(8):2475–2481.15828783
van Aken B, Schnoor JL. 2002. Evidence of perchlorate (C104) reduction in plant tissues (Poplar Tree) using radio-labeled 36C104. Environ Sci Technol 36(12):2783–2788.12099480
Vanderpump MPJ, Tunbridge WMG. 1996. The epidemiology of thyroid diseases. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. 8th ed. Philadelphia, PA: Lippincott Williams & Wilkins, 474–482.
Van Sande J, Massart C, Beauwens, . 2003. Anion selectivity by the sodium iodide symporter. Endocrinology 144:247–252.12488351
van Vliet G. 1999. Merck AG thyroid symposium. Thyroid 9(1):79–84.10037081
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vijayalakshmi K, Motlag DB. 1989a. Effect of perchlorate on plasma and tissue lipid pattern in rats. J Health Sci 15:72–75.
Vijayalakshmi K, Motlag DB. 1989b. Lipoprotein profile during perchlorate toxicity. Indian J Biochem Biophys 26:273–274.2560766
Vijayalakshmi K, Motlag DB. 1990. Effect of perchlorate on mitochondrial function. Indian J Biochem Biophys 27(1):48–51.2160426
Vijayalakshmi K, Motlag DB. 1992. Biochemical changes in mitochondria during chronic perchlorate toxicity. J Environ Biol 13:149–158.
Vogt H, Balej J, Bennett JE, . 1986. Chlorine oxides and chlorine oxygen acids. In: Gerhartz W, Yamamoto YS, Campbell FT, ., eds. Ullmann’s encyclopedia of industrial chemistry, Vol. A6. New York, NY: VCH Publishers, 483–525.
Vogt H, Balej J, Bennett JE, . 2005. Chlorine oxides and chlorine oxygen acids. Ullmann’s encyclopedia of industrial chemistry. http://www.mrw.interscience.wiley.com/emrw/9783527306732/ueic/article/a06_483/current/pdf. November 27, 2007.
Von Burg R. 1995. Perchlorates. J Appl Toxicol 15:237–241.7560746
Vroye L, Beauwens R, Van Sande J, . 1998. The Na^+^-I^−^ cotransporter of the thyroid: characterisation of new inhibitors. Pflugers Arch (Eur J Physiol) 435:259–266.9382940
Vulsma T, Gons MH, De Vijlder JJM. 1989. Maternal-fetal transfer of thyroxine in congenital hypothyroidism due to a total organification defect or thyroid agenesis. N Engl J Med 321:13–16.2733742
Weber A, Wolf J. 1969. [Nephrotic syndrome during thyreostatic treatment with sodium perchlorate.] Munch Med Wochenschr 111:2274–2275. (German)4311961
Weetman AP. 2000. Chronic autoimmune thyroiditis. In: Braverman LE, Utiger RD, eds. Werner and Ingbar’s the thyroid: A fundamental and clinical text. Philadelphia, PA: Lippincott Williams & Wilkins, 721–732.
Weiss SJ, Philp NJ, Grollman EF. 1984b. Effect of thyrotropin on iodide efflux in FRTL-5 cells mediated by Ca^+2^. Endocrinology 114:1108–1113.6323130
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2000. Air quality guidelines. 2nd edition. World Health Organization. Geneva, Switzerland. http://www.euro.who.int/air/Activities/20050104_1. February 15, 2005.
WHO. 2004. Guidelines for drinking-water quality. 3rd edition. World Health Organization. Geneva, Switzerland. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. February 15, 2005.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wilkin RT, Fine DD, Burnett NG. 2007. Perchlorate behavior in a municipal lake following fireworks display. Environ Sci Technol 41(11):3966–3971.17612176
Winkler P, Minteer M, Willey J. 2004. Analysis of perchlorate in water and soil by electrospray LC/MS/MS. Anal Chem 76(2):469–473.14719899
Wolff J. 1964. Transport of iodide and other anions in the thyroid gland. Physiol Rev 44:45–90.14105583
Wolff J. 1998. Perchlorate and the thyroid gland. Pharmacol Rev 50(1):89–105.9549759
Wolff J, Maurey JR. 1962. Thyroidal iodide transport III. Comparison of iodide with anions of periodic group VIIA. Biochim Biophys Acta 57:422–426.14008017
Wolff J, Maurey JR. 1963. Thyroidal iodide transport IV. The role of ion size. Biochim Biophys Acta 69:48–58.14001206
Wolter R, Noël P, DeCock P, . 1979. Neuropsychological study in treated thyroid dysgenesis. Acta Paediatr Scand Suppl 227:41–46.
Wyngaarden JB, Wright BM, Ways P. 1952. The effect of certain anions upon the accumulation and retention of iodide by the thyroid gland. Endocrinology 50:537–549.14936940
*Yamada T. 1967. Effects of perchlorate and other anions on thyroxine metabolism in the rat. Endocrinology 81(6):1285–1290.4169022
York RG, Barnett J, Brown WR, . 2004. A rat neurodevelopmental evaluation of offspring, including evaluation of adult and neonatal thyroid, from mothers treated with ammonium perchlorate in drinking water. Int J Toxicol 23:191–214.15204722
York RG, Barnett J, Girard MF, . 2005b. Refining the effects observed in a developmental neurobehavioral study of ammonium perchlorate administered orally in drinking water to rats. II. Behavioral and neurodevelopment effects. Int J Toxicol 24(6):451–467.16393938
York RG, Brown WR, Girard MF, . 2001a. Two-generation reproduction study of ammonium perchlorate in drinking water in rats evaluates thyroid toxicity. Int J Toxicol 20(4):183–197.11563414
York RG, Brown WR, Girard MF, . 2001b. Oral (drinking water) developmental toxicity study of ammonium perchlorate in New Zealand white rabbits. Int J Toxicol 20(4):199–205.11563415
York RG, Funk KA, Girard MF, . 2003. Oral (drinking water) developmental toxicity study of ammonium perchlorate in Sprague-Dawley rats. Int J Toxicol 22(6):453–464.14680992
York RG, Lewis E, Brown WR, . 2005a. Refining the effects observed in a developmental neurobehavioral study of ammonium perchlorate administered orally in drinking water to rats. I. Thyroid and reproductive effects. Int J Toxicol 24(6):403–418.16393933
Yoshida A, Sasaki N, Mori A, . 1997. Different electrophysiological character of I^−^, ClO_4_^−^, and SCN^−^ in the transport by NA^+^/I^−^ symporter. Biochem Biophys Res Commun 231:731–734.9070882
Yu KO, Narayanan L, Mattie DR, . 2002. The pharmacokinetics of perchlorate and its effect on the hypothalamus-pituitary-thyroid axis in the male rat. Toxicol Appl Pharmacol 182(2):148–159.12140178
Yu L, Canas JE, Cobb GP, . 2004. Uptake of perchlorate in terrestrial plants. Ecotoxicol Environ Saf 58(1):44–49.15087162
Zeiger E. 1998a. Salmonella mutagenicity testing of ammonium perchlorate [memorandum with attachment to Annie Jarabek]. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Institute of Environmental Health Services.
Zeiger E. 1998b. Ammonium perchlorate MN test results [memorandum with attachment to Annie Jarabek]. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Institute of Environmental Health Services.
Zhang Z, Else T, Amy P, . 2002. Evaluation of in situ biodegradation of perchlorate in a contaminated site. In: Leeson A, ed. International in situ on-site bioremediation symposium. 6th ed. Columbus, OH: Batelle Press, 257–263.
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zoeller RT. 2006. Collision of basic and applied approaches to risk assessment of thyroid toxicants. Ann NY Acad Sci 1076:169–170.
Zoeller RT, Crofton KM. 2000. Thyroid hormone action in fetal brain development and potential for disruption by environmental chemicals. Neurotoxicology 21(6):935–946.11233763
Zoeller RT, Rovet J. 2004. Timing of thyroid hormone action in the developing brain: Clinical observations and experimental findings. J Neuroendocrinol 16:809–818.15500540