# PEER REVIEW

Peer reviewers were selected to review the ATSDR Toxicological Profile for Perchlorates.

The post-public comment draft was reviewed on April 18, 2007 by:

1. Dr. Jeffrey Fisher, Department Head and Professor, Department of Environmental Health Science, the University of Georgia, Athens, Georgia;
2. Dr. Stephen LaFranchi, Professor, Department of Pediatrics, Head, Pediatric Endocrinology, Associate Chair for Education, Oregon Health Sciences University (CDRCP), Portland, Oregon;
3. Dr. Kannan Krishnan, Professor of Occupational and Environmental Health, University of Montreal, Montreal, Quebec, Canada; and
4. Dr. R. Thomas Zoeller, Professor, Department of Biology, University of Massachusetts at Amherst, Morrill Science Center, Amherst, Massachusetts.

The pre-public comment draft was reviewed on June 26, 2002 by:

1. Dr. Kannan Krishnan, Professor of Occupational and Environmental Health, University of Montreal, Montreal, Quebec, Canada;
2. Dr. R. Thomas Zoeller, Professor, Department of Biology, University of Massachusetts at Amherst, Morrill Science Center, Amherst, Massachusetts; and
3. Dr. Gary Williams, Professor of Pathology, Department of Pathology, New York Medical College, Valhalla, New York.

These experts collectively have knowledge of perchlorates’ physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR. Nevertheless, the expert peer reviewers on April 18, 2007 concluded that the minimal risk level (MRL) should still be based on the Reference Dose (RfD) as recommended by the NAS Panel Report (2005) given the research data available at the time of the 2007 peer review.