# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of the most widely used perchlorates is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Perchlorates are high melting point inorganic salts that are soluble in water at environmentally significant concentrations. There are five perchlorate salts that are manufactured in substantial amounts: magnesium, potassium, ammonium, sodium, and lithium perchlorate. Perchlorates are powerful oxidizing agents and at elevated temperatures can react explosively (Schilt 1979). The activation energy of ammonium perchlorate is 123.8 kJ/mol below 240 °C, 79.1 kJ/mol above 240 °C, and 307.1 kJ/mol between 400 and 440 °C (Mendiratta et al. 1996). The production volume of ammonium perchlorate far outpaces the other salts (Mendiratta et al. 1996).

Information regarding the physical and chemical properties of these five perchlorate salts is located in Table 4-2.

Table 4-1 Chemical Identity of Perchlorates^a^

Characteristic | Magnesium perchlorate | Potassium perchlorate | Ammonium perchlorate | Sodium perchlorate | Lithium perchlorate
Synonym(s) | Anhydrous magnesium perchlorate; perchloric acid, magnesium salt (1:1) | Potassium hyperchloride; perchloric acid, potassium salt (1:1) | Perchloric acid, ammonium salt (1:1) PKHA, APC^b^ | Perchloric acid, sodium salt (1:1) | No data
Registered trade name(s) | Anhydrone, Dehydrite | Peroidin, Astrumal, Irenal, Irenat | No data | Irenat | No data
Chemical formula | Mg(ClO_4_)_2_ | KClO_4_ | NH_4_ClO_4_ | NaClO_4_ | LiClO_4_^c^
Chemical structure | [Mg^2+^][ClO_4_^−^]_2_ | [K^+^][ClO_4_^−^] | [NH_4_^+^][ClO_4_^−^] | [Na^+^][ClO_4_^−^] | [Li^+^][ClO_4_^−^]
Identification numbers:
CAS Registry | 10034-81-8 | 7778-74-7 | 7790-98-9 | 7601-89-0 | 7791-03-9^c^
NIOSH RTECS | SC8925000 | SC9700000 | SC7520000 | SC9800000 | No data
EPA Hazardous Waste^d^ | D003 | D003 | D003 | D003 | D003
OHM/TADS | No data | No data | 7216589 | No data | No data
DOT/UN/NA/IMDG | UN1475, IMO 5.1 | UN 1489, IMO 5.1 | UN1442, IMO 5.1 | UN1502, IMO 5.1 | UN1481^e^
HSDB | 661 | 1222 | 474 | 5038 | No data
NCI | No data | No data | No data | No data | 0106672^f^

a All information was obtained from HSDB 2006 unless otherwise noted. Perchlorate ion was not included in this table since it is never found independent of a corresponding cation.

b Ashford 1994

c O’Neil 2001

d EPA 1992a

e ERG 2004

f ChemIDplus 2007

CAS = Chemical Abstracts Services; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Perchlorates^a^

Property | Magnesium perchlorate | Potassium perchlorate | Ammonium perchlorate | Sodium perchlorate | Lithium perchlorate
Molecular weight | 223.21 | 138.55 | 117.49 | 122.44 | 106.39
Color | White | Colorless or white | White crystals^b^ | White | Colorless crystals^c^
Physical state | Solid granular or flaky powder | Solid crystals | Solid orthombic crystals | Solid deliquesce crystals | Solid crystals
Melting point | ~250 °C dec. | 400 °C dec. | 130 °C dec.^d^ | 471 °C dec.^d^ | 236 °C^e^
Boiling point | N/A | N/A | N/A | N/A | ~400 °C dec.^c^
Density at −20 °C | 2.21 g/mL^f^ | 2.52 g/mL | 1.95 g/mL | 2.02 g/mL^g^ | 2.43 g/mL
Odor^b^ | No odor | No odor | No odor | No odor | No odor
Odor threshold:
Water | N/A | N/A | N/A | N/A | N/A
Air | N/A | N/A | N/A | N/A | N/A
Taste | No data | No data | Imparts a bitter and salty taste to water^c^ | No data | No data
Solubility:
Freshwater at 25 °C^f^ | 9.96×10^5^ mg/L | 2.06×10^4^ mg/L | 2.49×10^5^ mg/L | 2.10×10^6^ mg/L | 5.97×10^5^ mg/L
Organic solvent(s)^d^
Methanol | 5.18×10^5^ mg/L | 1.05×10^3^ mg/L | 6.86×10^4^ mg/L | 5.14×10^5^ mg/L | 1.82×10^6^ mg/L
Ethanol | 2.40×10^5^ mg/L | 1.20×10^2^ mg/L | 1.91×10^4^ mg/L | 1.47×10^5^ mg/L | 1.52×10^6^ mg/L
n-Propanol | 7.34×10^5^ mg/L | 1.00×10^2^ mg/L | 3.87×10^3^ mg/L | 4.89×10^4^ mg/L | 1.05×10^6^ mg/L
Acetone | 4.29×10^5^ mg/L | 1.55×10^3^ mg/L | 2.26×10^4^ mg/L | 5.17×10^5^ mg/L | 1.37×10^6^ mg/L
Ethyl acetate | 7.09×10^5^ mg/L | 1.00×10^1^ mg/L | 3.20×10^2^ mg/L | 9.65×10^4^ mg/L | 9.51×10^5^ mg/L
Ethyl ether | 2.91×10^3^ mg/L | No data | No data | No data | 1.14×10^6^ mg/L
Vapor pressure at 25 °C^a^ | Very low | Very low | Very low | Very low | Very low
Polymerization | N/A | N/A | N/A | N/A | N/A
Incompatibilities | Oil, grease, benzene, calcium hydride, charcoal, olefins, ethanol, strontium hydride, sulfur, sulfuric acid, and carbonaceous material^b,f^ | Charcoal, magnesium, reducing agents, sulfur, oil, grease, benzene, calcium hydride, olefins, ethanol, strontium hydride, sulfuric acid, carbonaceous material^b,f^ | Nitryl perchlorate, potassium iodate, potassium permanganate, metals, powdered carbon, ferrocene, sulfur, organic matter, charcoal, copper^b,f^ | Organic material, oil, grease, benzene, calcium hydride, charcoal, olefins, ethanol, strontium hydride, sulfur, sulfuric acid, carbonaceous material^b,f,g^ | Sulfur, sulfuric acid, powdered magnesium, aluminum, benzene, calcium hydride, charcoal, olefins, ethanol, strontium hydride, carbonaceous material^b,f^
Other | Sensitive to rubbing, shock, percussion, sparks, and heating.^c^ Dissolves in water with evolution of a considerable amount of heat. | Sensitive to rubbing, shock, percussion, sparks, and heating.^c^ | Sensitive to rubbing, shock, percussion, sparks, and heating.^c^ | Sensitive to rubbing, shock, percussion, sparks, and heating.^c^ Hygroscopic.^d^ | Sensitive to rubbing, shock, percussion, sparks, and heating.^c^

a Perchlorate ion was not included in this table since it is never found independent of a corresponding cation. All information was taken from O’Neil 2001 unless otherwise noted. Measured data were not available for the following end points: log K_ow_, K_oc_, Henry’s law constant. Conversion factors were also not available. Autoignition temperature, flashpoint, flammability limits, and explosive limits are not applicable.

b Lewis 2000

c Von Burg 1995

d Schilt 1979

e Bauer 1990

f Vogt et al. 1986

g Lewis 2001

dec. = decomposes; N/A = not applicable