# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Perchlorates Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Perchlorates
CAS Numbers: | 10034-81-8, 7778-74-7, 7790-98-9, 7601-89-0
Date: | August 2008
Profile Status: | Post-Public, Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 2
Species: | Humans

[underlined: Minimal Risk Level]: ATSDR adopts the National Academy of Sciences (NAS 2005) recommended chronic RfD of 0.0007 mg/kg/day for chronic oral MRL. NAS based the RfD on the findings of a human study by Greer et al. (2002) summarized below.

[underlined: References]: Greer MA, Goodman G, Pleus RC, . 2002. Health effects assessment for environmental perchlorate contamination: The dose-response for inhibition of thyroidal radioiodine uptake in humans. Environ Health Perspect 110(9):927–937.12204829

NAS. 2005. Health implications of perchlorate ingestion. Washington, DC: National Academies Press. http://www.nap.edu/books/0309095689/html/. January 31, 2005.

[underlined: Experimental design]: The study was conducted in 37 healthy (euthyroid) volunteers (16 males, 21 females) who consumed potassium perchlorate in drinking water in doses of 0.007, 0.02, 0.1, or 0.5 mg perchlorate/kg/day for 14 days. In 24 subjects, thyroidal uptake of radioactive iodine (RAIU) was measured 8 and 24 hours after administration of radioactive iodine on exposure days 2 and 14 and also 15 days after exposure. To estimate daily iodine intake, 24-hour urine samples were collected. Free and total T4, T3, and TSH were sampled 16 times throughout the study. Serum antibodies to thyroglobulin and thyroid peroxidase were also measured. Hematological and clinical chemistry tests were also conducted throughout the study.

[underlined: Effects noted in study and corresponding doses]: Baseline thyroid iodine uptake varied greatly among the subjects: 5.6–25.4% for the 8-hour uptake and 9.8–33.7% for the 24-hour uptake. Perchlorate inhibited RAIU in a dose-related manner. As a percentage of baseline RAIU, inhibition in the 0.007, 0.02, 0.1, and 0.5 mg/kg/day dose groups was 1.8, 16.4, 44.7, and 67.1%, respectively. The small decrease in RAIU at 0.007 mg/kg/day was not statistically significant and is well within the variation of repeated measurements in normal subjects. The dose is considered the study NOEL. No significant differences were seen between the 8- and 24-hour measurements or between the 2- and 14-day measurements. On post-exposure day 15, RAIU rebounded to values slightly over but not significantly greater than 100%. Consumption of perchlorate in drinking water did not significantly alter serum TSH, free T4 or total T4 and T3 levels. Serum antiglobulin levels were below detection levels in all samples tested. Serum anti-thyroid peroxidases were elevated in two subjects at the screening visit and thus, were not related to treatment with perchlorate. Hematology and clinical chemistry tests to assess liver and kidney function revealed no significant deviations from normal ranges. No difference was observed between the response of male and female subjects.

Based on the known mechanism of action of perchlorate as a competitive inhibitor of NIS and on the elimination half-time of perchlorate of approximately 8 hours (perchlorate is not expected to accumulate in the body), the NAS concluded that a dose that produced minimal inhibition of thyroid iodide uptake after 14 days of continuous exposure would also have no appreciable effects on thyroid iodide uptake with more prolonged (i.e., intermediate or chronic) exposure. On this basis, the 14-day study was used as the basis for adopting the RfD for the chronic MRL. This is supported by another 14-day study (Lawrence et al. 2000), long-term studies of workers (Braverman et al. 2005; Gibbs et al. 1998; Lamm et al. 1999), and studies of the general population (Li et al. 2001; Téllez et al. 2005) exposed to perchlorate that found no significant alterations in thyroid function in the populations examined. A study by Braverman et al. (2006) in which 13 volunteers dosed with perchlorate in capsules for 6 months at doses of 0, 0.5, and 3 mg/day exhibited no changes in iodine uptake or thyroid hormone level, was considered for derivation of the MRL.

An uncertainty factor of 10 was applied to the NOEL of 0.007 mg/kg/day. The uncertainty factor of 10 is intended to protect the most sensitive population—the fetuses of pregnant women who might have hypothyroidism or iodide deficiency. Other sensitive populations include preterm infants and nursing infants. As discussed by NAS (2005), preterm infants are more sensitive than term infants. The fetus is dependent on maternal thyroid hormones at least until the fetal thyroid begins to produce T4 and T3 (Zoeller and Crofton 2000). In humans, this occurs at approximately 16–20 weeks of gestation. Thyroid hormones are present in human amniotic fluid at 8 weeks of gestation prior to the onset of fetal thyroid hormone production (Contempre et al. 1993; Thorpe-Beeston et al. 1991). Thyroid hormone receptors are present and occupied by hormone at this time as well, suggesting that the fetus is capable of responding to maternal thyroid hormones (Bernal and Pekonen 1984; Ferreiro et al. 1988). The contribution of maternal thyroid hormones to the fetal thyroid hormone status is also evident from infants who have an inherited disorder that abolishes T4 production but are born, nevertheless, with normal serum thyroid hormone levels (i.e., euthyroid) and become hypothyroid after birth if not administered thyroid hormones within the first 2 weeks after birth (Larsen 1989; van Vliet et al. 1999; Vulsma et al. 1989). This suggests that, in the complete absence of fetal thyroid function, the maternal thyroid is able to maintain at least partially protective levels of thyroid hormone in the fetus at late term. Uncorrected maternal hypothyroidism, on the other hand, may result in impaired neurodevelopment of the fetus (Haddow et al. 1999; Pop et al. 1999; Soldin et al. 2001). By inhibiting NIS in breast tissue (Levy et al. 1997; Smanik et al. 1997; Spitzweg et al. 1998), perchlorate may also limit the availability of iodide to nursing infants, who depend entirely on breast milk for the iodide needed to produce thyroid hormone (Agency for Toxic Substances and Disease Registry 2002). No information is available on the doses in humans that might decrease iodide uptake into breast milk. It is important to note that a recent study of 51 women in the Boston area found that 47% of the women sampled may have been providing breast milk with insufficient iodine to meet the infants’ requirements (Pearce et al. 2007). Radioiodine uptake into mammary milk was decreased in rats exposed to 1 or 10 mg/kg/day perchlorate in drinking water (Yu et al. 2002). Studies conducted in cows and goats have also shown that perchlorate can decrease radioiodine uptake into mammary milk (Howard et al. 1996). As discussed by Ginsberg et al. (2007), additional factors that make neonates a sensitive group include their shorter serum half-life for T4 of approximately 3 days compared to approximately 7–10 days in adults, a lower storage capacity of the thyroid for T4, and possibly slower urinary clearance of perchlorate due to immature renal function. In addition, PBPK models predict that pregnant women and the fetus will have higher blood concentrations of perchlorate and greater iodide uptake inhibition at a given concentration of perchlorate in drinking water than either nonpregnant adults or older children (Clewell et al. 2007).

Another potential susceptible population is women with urinary iodine levels <100 µg/L (Blount et al. 2006), as regression analysis indicted that perchlorate exposure was correlated with decreased T4 and increased TSH. According to the World health Organization (WHO 2004), median urinary iodine levels ≥100 µg/L indicate sufficient iodine intake for the non-pregnant population, whereas pregnant women should maintain urinary levels of iodine >150 µg/L. The American Thyroid Association (2006) recommends that women generally consume iodine from diary products, bread, seafood, meat, and some iodized salt, but pregnant and lactating women may require additional supplements and vitamins.

[underlined: Dose and end point used for MRL derivation]: 0.007 mg/kg/day (NOEL for inhibition of iodide uptake into the thyroid). As indicated by the NAS (2005), iodide uptake inhibition is a key biochemical event that precedes all potential thyroid-mediated effects of perchlorate exposure. Using a nonadverse effect that is upstream of adverse effects is a conservative approach to perchlorate hazard assessment.

[underlined: Uncertainty Factors used in MRL derivation]: 10

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to NAS’s RfD]: Lawrence et al. (2000) evaluated serum TSH, free thyroxine index (FTI), total serum triiodothyronine (TT3), and RAIU; serum and 24-hour urine perchlorate; and 24-hour urinary iodide excretion in volunteers who ingested approximately 0.14 mg perchlorate/kg/day in drinking water for 14 days. Tests were conducted pre-dosing, on day 7 and 14, and 14 days after perchlorate ingestion was discontinued. The only significant finding was a significant decrease in 4-, 8-, and 24-hour RAIU values by a mean of about 38% relative to baseline on day 14 of dosing. Fourteen days later, RAIU had recovered to a mean of 25% above baseline values. In another study, Braverman et al. (2006) administered capsules containing potassium perchlorate to 13 volunteers (4 males, 9 females) for 6 months. The estimated doses were 0 (placebo), 0.5 and 3.0 mg perchlorate/day (approximately 0.04 and 0.007 mg perchlorate/kg/day). The outcomes measured were serum thyroid function tests, 24-hour RAIU, serum thyroglobulin (Tg), urinary iodine and perchlorate, and serum perchlorate. RAIU, measured at baseline, 3, 6 months and 1 month after termination, was not significantly affected by administration of perchlorate and there were no significant changes in serum total T3, FTI, TSH, or Tg levels during or after perchlorate exposure compared to baseline values. The small number of subjects per group (4–5), the dosing by capsule rather than intermittent exposure in drinking water, and the lack of information on RAIU during the first 3 months of the study somewhat diminish the strengths of this study.

Relatively large doses of perchlorate (600–900 mg/day, 8–13 mg/kg/day) are required to deplete thyroidal iodine stores sufficiently to decrease serum levels of T4 (Brabant et al. 1992; Bürgi et al. 1974). A 4-week oral exposure to 900 mg/day (approximately 13 mg/kg/day) significantly decreased serum levels of FT4 (not out of the normal range), but not FT3 and did not significantly change serum TSH levels (Brabant et al. 1992).

A study conducted in an ammonium perchlorate manufacturing facility found that intermittent, high exposure to perchlorate for many years did not induce goiter or any evidence of hypothyroidism among the workers, as judged by no significant alterations in serum TSH or thyroglobulin even though iodine uptakes were decreased during the work shift (Braverman et al. 2005). The median estimated absorbed dose was 0.167 mg/kg/day, equivalent to drinking approximately 2 L of water containing 5 mg perchlorate/L.

[underlined: Agency Contact (Chemical Manager)]: Sharon Wilbur