# CHAPTER 8 REFERENCES

Ahlborg UG, Lindgren JE, Mercier M. 1974. Metabolism of pentachlorophenol. Arch Toxicol 32(4):271–281. 10.1007/bf00330109.4480027
Ahlborg UG, Larsson K, Thunberg T. 1978. Metabolism of pentachlorophenol in vivo and in vitro. Arch Toxicol 40(1):45–53. 10.1007/bf00353278.580375
Andersen KJ, Leighty EG, Takahashi MT. 1972. Evaluation of herbicides for possible mutagenic properties. J Agric Food Chem 20:649–656.4561194
Ansari GA, Britt SG, Reynolds ES. 1985. Isolation and characterization of palmitoylpentachlorophenol from human fat. Bull Environ Contam Toxicol 34(5):661–667. 10.1007/bf01609790.4005445
Armstrong RW, Eichner ER, Klein DE, 1969. Pentachlorophenol poisoning in a nursery for newborn infants. II. Epidemiologic and toxicologic studies. J Pediatr 75(2):317–325. 10.1016/s0022-3476(69)80407-5.5795353
Arrhenius E, Renberg L, Johansson L, 1977. Disturbance of microsomal detoxication mechanisms in liver by chlorophenol pesticides. Chem Biol Interact 18(1):35–46. 10.1016/0009-2797(77)90139-9.890839
Arsenault RD. 1976. Pentachlorophenol and contained chlorinated dibenzodioxins in the environment: A study of environmental fate, stability, and significance when used in wood preservation. AWPA Proc 72:122–147.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1993. Public health assessment for Munisport Landfill, North Miami, Dade County, Florida, Region 4. CERCLIS No. FLD0084535442. Springfield, VA: Agency for Toxic Substances and Disease Registry.
ATSDR. 1994. Toxicological profile for chlorodibenzofurans (CDFs). Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp32.pdf. February 26, 2020.
ATSDR. 1995. Health assessment for American Creosote Works, Incorporated (Winnfield Plant) Winnfield, Winn Parish, Louisiana, Region 6. CERCLIS No. LAD000239814. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB95195186.
ATSDR. 1998. Toxicological profile for chlorinated dibenzo-p-dioxins (CDDs). Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp104.pdf. February 26, 2020.
ATSDR. 1999. Public health assessment for Camilla Wood Preserving Company, Camilla, Mitchell County, Georgia, Region 4. CERCLIS No. GAD008212409. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB2000103266. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2000103266.xhtml. February 26, 2020.
ATSDR. 2007. Health consultation: Exposure investigation report - Meredith William C Co. Inc. East Point, Georgia. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/hac/pha/meredithwilliamsccoinc/meredithwilliameihc8-23-07.pdf. December 28, 2021.
ATSDR. 2019. Pentachlorophenol. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Baader EW, Bauer HJ. 1951. Industrial intoxication due to pentachlorophenol. Ind Med Surg 20:286–290.14850152
Bader M, Zimmer H, Triebig G. 2007. Urinary pentachlorophenol in painters and bricklayers in a four-years time interval after the PCP prohibition ordinance in Germany. Ind Health 45(2):338–342. 10.2486/indhealth.45.338.17485880
Baker MD, Mayfield CI, Inniss WE. 1980. Degradation of chlorophenols in soil, sediment and water at low temperature. Water Res 14:1765–1771.
Ballhorn L, Rozman T, Rozman K, 1981. Cholestyramine enhances fecal elimination of pentachlorophenol in Rhesus monkeys. Chemosphere 10:877–888.
Barbieri F, Colosio C, Schlitt H, 1995. Urine excretion of pentachlorophenol (PCP) in occupational exposure. Pestic Sci 43:259–262.
Bargagna S, Chiovato L, Dinetti D, 1997. Neuropsychological development in a child with early-treated congenital hypothyroidism as compared with her unaffected identical twin. Eur J Endocrinol 136:100–104.9037135
Bauchinger M, Dresp J, Schmid E, 1982. Chromosome changes in lymphocytes after occupational exposure to pentachlorophenol (PCP). Mutat Res 102(1):83–88. 10.1016/0165-1218(82)90148-3.7121476
Baygi SF, Fernando S, Hopke PK, 2021. Nontargeted discovery of novel contaminants in the great lakes region: A comparison of fish fillets and fish consumers. Environ Sci Technol 55(6):3765–3774. 10.1021/acs.est.0c08507.33646760
Beard AP, Rawlings NC. 1998. Reproductive effects in mink (Mustela vison) exposed to the pesticides lindane, carbofuran and pentachlorophenol in a multigeneration study. J Reprod Fertil 113(1):95–104. 10.1530/jrf.0.1130095.9713382
Beard AP, Rawlings NC. 1999. Thyroid function and effects on reproduction in ewes exposed to the organochlorine pesticides lindane or pentachlorophenol (PCP) from conception. J Toxicol Environ Health 58(8):509–530. 10.1080/009841099157124.
Beard AP, McRae AC, Rawlings NC. 1997. Reproductive efficiency in mink (Mustela vison) treated with the pesticides lindane, carbofuran and pentachlorophenol. J Reprod Fertil 111(1):21–28. 10.1530/jrf.0.1110021.9370963
Beard AP, Bartlewski PM, Rawlings NC. 1999a. Endocrine and reproductive function in ewes exposed to the organochlorine pesticides lindane or pentachlorophenol. J Toxicol Environ Health 56(1):23–46. 10.1080/009841099158213.
Beard AP, Bartlewski PM, Chandolia RK, 1999b. Reproductive and endocrine function in rams exposed to the organochlorine pesticides lindane and pentachlorophenol from conception. J Reprod Fertil 115(2):303–314. 10.1530/jrf.0.1150303.10434936
Begley J, Reichert EL, Rashad MN, 1977. Association between renal function tests and pentachlorophenol exposures. Clin Toxicol 11:97–106.872545
Bekhouche K, Ozen T, Boussaha S, 2019. Hepatoprotective effects of the n-butanol extract from Perralderia coronopifolia Coss. against PCP-induced toxicity in Wistar albino rats. Environ Sci Pollut Res Int 26(30):31215–31224. 10.1007/s11356-019-06231-6.31463753
Berghuis SA, Van Braeckel K, Sauer PJJ, 2018. Prenatal exposure to persistent organic pollutants and cognition and motor performance in adolescence. Environ Int 121(Pt 1):13–22. 10.1016/j.envint.2018.08.030.30172231
Bergner H, Constantinidis P, Martin JH. 1965. Industrial pentachlorophenol poisoning in Winnipeg. Can Med Assoc J 92:448–451.14259335
Berkowitz GS, Obel J, Deych E, 2003. Exposure to indoor pesticides during pregnancy in a multiethnic, urban cohort. Environ Health Perspect 111(1):79–84. 10.1289/ehp.5619.12515682
Bernard BK, Hoberman AM. 2001. A study of the developmental toxicity potential of pentachlorophenol in the rat. Int J Toxicol 20(6):353–362. 10.1080/109158101753333631.11797817
Bernard BK, Ranpuria AK, Hoberman AM. 2001. Developmental toxicity study of pentachlorophenol in the rabbit. Int J Toxicol 20(6):345–352. 10.1080/109158101753333622.11797816
Bernard BK, Hoberman AM, Brown WR, 2002. Oral (gavage) two-generation (one litter per generation) reproduction study of pentachlorophenol (penta) in rats. Int J Toxicol 21(4):301–318. 10.1080/10915810290096469.12171631
Bevenue A, Beckman H. 1967. Pentachlorophenol: a discussion of its properties and its occurrence as a residue in human and animal tissue. Residue Rev 19:83–133.4980615
Bevenue A, Wilson J, Casarett LJ, 1967. A Survey of pentachlorophenol content in human urine. Bull Environ Contam Toxicol 2(6):319–332. 10.1007/BF01684407.24189956
Bevenue A, Emerson ML, Casarett LJ, 1968. A sensitive gas chromatographic method for the determination of pentachlorophenol in human blood. J Chromatogr 38(4):467–472. 10.1016/0021-9673(68)85075-7.5701784
Birrell J, Frost GJ, Parkin JM. 1983. The development of children with congenital hypothyroidism. Dev Med Child Neurol 25(4):512–519. 10.1111/j.1469-8749.1983.tb13798.x.6618029
Blakley BR, Yole MJ, Brousseau P, 1998. Effect of pentachlorophenol on immune function. Toxicology 125(2–3):141–148. 10.1016/s0300-483x(97)00154-6.9570329
Borzelleca JF, Hayes JR, Condie LW, 1985. Acute toxicity of monochlorophenols, dichlorophenols and pentachlorophenol in the mouse. Toxicol Lett 29(1):39–42. 10.1016/0378-4274(85)90197-3.4082204
Boutwell RK, Bosch DK. 1959. The tumor-promoting action of phenol and related compounds for mouse skin. Cancer Res 19(4):413–424.13652126
Boylan J, Egle J, Guzelian R. 1977. Cholestyramine: Use as a new therapeutic approach for chlordecone (kepone) poisoning. Science 199:893–895.
Boyle TP, Robinson-Wilson EF, Petty JD, 1980. Degradation of pentachlorophenol in simulated lentic environments. Bull Environ Contam Toxicol 24(2):177–184. 10.1007/bf01608094.7362895
Bradley PM, Journey CA, Romanok KM, 2017. Expanded target-chemical analysis reveals extensive mixed-organic-contaminant exposure in U.S. Streams. Environ Sci Technol 51(9):4792–4802. 10.1021/acs.est.7b00012.28401767
Braun WH, Sauerhoff MW. 1976. The pharmacokinetic profile of pentachlorophenol in monkeys. Toxicol Appl Pharmacol 38(3):525–533. 10.1016/0041-008x(76)90184-8.827823
Braun WH, Young JD, Blau GE, 1977. The pharmacokinetics and metabolism of pentachlorophenol in rats. Toxicol Appl Pharmacol 41(2):395–406. 10.1016/0041-008x(77)90041-2.898206
Braun WH, Blau GE, Chenowith MB. 1979. The metabolism/pharmacokinetics of pentachlorophenol in man, and a comparison with the rat and monkey. Dev Toxicol Environ Sci 4:289–296. 10.1016/B978-0-444-00288-4.50033-5.
Bryant FO, Hale DD, Rogers JE. 1991. Regiospecific dechlorination of pentachlorophenol by dichlorophenol-adapted microorganisms in freshwater, anaerobic sediment slurries. Appl Environ Microbiol 57(8):2293–2301.1768102
Budavari S, O’Neil MJ, Smith A, 1989. Pentachlorophenol. In: The Merck index. An encyclopedia of chemicals, drugs, and biologicals. Eleventh ed. Rahway, NJ: Merck & Co., Inc., 1126.
Bunce NJ, Nakai JS. 1989. Atmospheric chemistry of chlorinated phenols. J Air Pollut Control Assoc 39:820–823.
Buselmaier W, Rohrborn G, Propping P. 1973. Comparative investigations on the mutagenicity of pesticides in mammalian test systems. Mutat Res 21:25–26.
Campbell LM, Muir DC, Whittle DM, 2003. Hydroxylated PCBs and other chlorinated phenolic compounds in lake trout (Salvelinus namaycush) blood plasma from the Great Lakes region. Environ Sci Technol 37(9):1720–1725. 10.1021/es026225m.12775040
Casarett LJ, Bevenue A, Yauger WL, 1969. Observations on pentachlorophenol in human blood and urine. Am Ind Hyg Assoc J 30(4):360–366. 10.1080/00028896909343138.5798790
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/fourthreport.pdf. December 13, 2019.
CDC. 2019. Fourth national report on human exposure to environmental chemicals, updated tables. January 2019. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/. December 11, 2019.
Cessna AJ, Waite DT, Constable M. 1997. Concentrations of pentachlorophenol in atmospheric samples from three Canadian locations, 1994. Bull Environ Contam Toxicol 58(4):651–658. 10.1007/s001289900383.9060385
Chang NI, Choi J. 1974. Studies on the adsorption of pentachlorophenol (PCP) in soil. Hanguk Touang Bilyo Hakkhoe Chi 7:197–220.
Chapman JB, Robson P. 1965. Pentachlorophenol poisoning from bath-water. Lancet 1(7398):1266–1267. 10.1016/s0140-6736(65)91910-0.14298147
Chen HM, Lee YH, Chen RJ, 2013a. The immunotoxic effects of dual exposure to PCP and TCDD. Chem Biol Interact 206(2):166–174. 10.1016/j.cbi.2013.09.005.24051191
Chen X, Chen M, Xu B, 2013b. Parental phenols exposure and spontaneous abortion in Chinese population residing in the middle and lower reaches of the Yangtze River. Chemosphere 93(2):217–222. 10.1016/j.chemosphere.2013.04.067.23714150
Cheng WN, Coenraads PJ, Hao ZH, 1993. A health survey of workers in the pentachlorophenol section of a chemical manufacturing plant. Am J Ind Med 24(1):81–92. 10.1002/ajim.4700240108.8352294
Chi J, Huang GL. 2004. Photodegradation of pentachlorophenol by sunlight in aquatic surface microlayers. J Environ Sci Health 39(1):65–73. 10.1081/pfc-120027439.
Choi J, Aomine S. 1974. Adsorption of pentachlorophenol by soils. Soil Sci Plant Nutr 20(2):135–144.
Chou PP, Bailey JL. 1986. Liquid-chromatographic determination of urinary pentachlorophenol. Clin Chem 32(6):1026–1028.3708802
Christodoulatos C, Korfiatis GP, Talimcioglu NM, 1994. Adsorption of pentachlorophenol by natural soils. J Environ Sci Health Part A 29(5):883–898.
Cirelli DP. 1978. Patterns of pentachlorophenol usage in the United States of America - an overview. In: Rao KR, ed. Pentachlorophenol. Environmental science research. Boston, MA: Springer, 13–18.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cline RE, Hill RH, Phillips DL, 1989. Pentachlorophenol measurements in body fluids of people in log homes and workplaces. Arch Environ Contam Toxicol 18(4):475–481. 10.1007/bf01055012.2774665
Collins JJ, Bodner K, Aylward LL, 2009. Mortality rates among workers exposed to dioxins in the manufacture of pentachlorophenol. J Occup Environ Med 51(10):1212–1219. 10.1097/JOM.0b013e3181badd4e.19786897
Colosio C, Barberi F, Bersani M, 1993a. Markers of occupational exposure to pentachlorophenol. Bull Environ Contam Toxicol 51:820–826.8257807
Colosio C, Maroni M, Barcellini W, 1993b. Toxicological and immune findings in workers exposed to pentachlorophenol (PCP). Arch Environ Health 48(2):81–88.8476309
Courtney KD, Copeland MF, Robbins A. 1976. The effects of pentachloronitrobenzene, hexachlorobenzene, and related compounds on fetal development. Toxicol Appl Pharmacol 35(2):239–256. 10.1016/0041-008x(76)90285-4.1265744
Cranmer M, Freal J. 1970. Gas chromatographic analysis of pentachlorophenol in human urine by formation of alkyl ethers. Life Sci 9(3):121–128. 10.1016/0024-3205(70)90304-8.
Crosby DG, Hamadmad N. 1971. The photoreduction of pentachlorobenzenes. J Agric Food Chem 19(6):1171–1174. 10.1021/jf60178a014.5132646
Crosby DG, Beynon KI, Korte F, 1981. Environmental chemistry of pentachlorophenol. Pure Appl Chem 53:1051–1080.
Dahlhaus M, Almstadt E, Appel KE. 1994. The pentachlorophenol metabolite tetrachloro-p-hydroquinone induces the formation of 8-hydroxy-2-deoxyguanosine in liver DNA of male B6C3F1 mice. Toxicol Lett 74(3):265–274. 10.1016/0378-4274(94)90085-x.7871550
Dahlhaus M, Almstadt E, Henschke P, 1996. Oxidative DNA lesions in V79 cells mediated by pentachlorophenol metabolites. Arch Toxicol 70(7):457–460. 10.1007/s002040050299.8740541
Daniel V, Huber W, Bauer K, 1995. Impaired in-vitro lymphocyte responses in patients with elevated pentachlorophenol (PCP) blood levels. Arch Environ Health 50(4):287–292. 10.1080/00039896.1995.9935956.7677428
Daniel V, Huber W, Bauer K, 2001. Association of elevated blood levels of pentachlorophenol (PCP) with cellular and humoral immunodeficiencies. Arch Environ Health 56(1):77–83. 10.1080/00039890109604057.11256860
Davis A, Campbell J, Gilbert C, 1994. Attenuation and biodegradation of chlorophenols in ground water at a former wood treating facility. Ground Water 32:248–257.
Deichmann W, Machle W, Kitzmiller KV, 1942. Acute and chronic effects of pentachlorophenol and sodium pentachlorophenate upon experimental animals. J Pharmacol Exp Ther 76:104–117.
Demers PA, Davies HW, Friesen MC, 2006. Cancer and occupational exposure to pentachlorophenol and tetrachlorophenol (Canada). Cancer Causes Control 17(6):749–758. 10.1007/s10552-006-0007-9.16783603
den Besten C, Vet JJ, Besselink HT, 1991. The liver, kidney, and thyroid toxicity of chlorinated benzenes. Toxicol Appl Pharmacol 111(1):69–81. 10.1016/0041-008x(91)90135-2.1949037
Dimich-Ward H, Hertzman C, Teschke K, 1996. Reproductive effects of paternal exposure to chlorophenate wood preservatives in the sawmill industry. Scand J Work Environ Health 22(4):267–273. 10.5271/sjweh.141.8881015
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Donaldson S, Miller G. 1997. Transport and photolysis of pentachlorophenol in soils subject to evaporating water. J Environ Qual 26:402–409.
Donnelly KC, Claxton LD, Huebner HJ, 1998. Mutagenic interactions of model chemical mixtures. Chemosphere 37(7):1253–1261. 10.1016/s0045-6535(98)00123-4.9734320
Dougherty RC, Piotrowska K. 1976. Screening by negative chemical ionization mass spectrometry for environmental contamination with toxic residues: Application to human urines. Proc Natl Acad Sci USA 73(6):1777–1781. 10.1073/pnas.73.6.1777.1064850
Drummond I, Van Roosmalen PB, Kornicki M. 1982. Determination of total pentachlorophenol in the urine of workers. A method incorporating hydrolysis, an internal standard and measurement by liquid chromatography. Int Arch Occup Environ Health 50(4):321–327. 10.1007/bf00377828.7174117
Dubois M, Plaisance H, Thome JP, 1996. Hierarchical cluster analysis of environmental pollutants through P450 induction in cultured hepatic cells. Ecotoxicol Environ Saf 34:205–215.8812189
Dufour P, Pirard C, Petrossians P, 2020. Association between mixture of persistent organic pollutants and thyroid pathologies in a Belgian population. Environ Res 181:108922. 10.1016/j.envres.2019.108922.31759644
Duxbury CL, Thompson JE. 1987. Pentachlorophenol alters the molecular organization of membranes in mammalian cells. Arch Environ Contam Toxicol 16(3):367–373. 10.1007/bf01054955.3592763
Edgehill RU, Finn RK. 1983. Microbial treatment of soil to remove pentachlorophenol. Appl Environ Microbiol 45(3):1122–1125.16346232
Edgerton TR, Moseman RF, Linder RE, 1979. Multi-residue method for the determination of chlorinated phenol metabolites in urine. J Chromatogr 170(2):331–342. 10.1016/s0021-9673(00)95458-x.546845
Ehrlich W. 1990. The effect of pentachlorophenol and its metabolite tetrachlorohydroquinone on cell growth and the induction of DNA damage in Chinese hamster ovary cells. Mutat Res 244(4):299–302. 10.1016/0165-7992(90)90076-v.2385245
Engelhardt G, Wallnofer PR. 1986. Transformations of pentachlorophenol. Part II: Transformations under environmental conditions. Toxicol Environ Chem 11:233–252.
EPA. 1977. Evaluation of selected pesticides as chemical mutagens. In vitro and in vivo studies. U.S. Environmental Protection Agency. PB268647. EPA600177028. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100SHSP.txt. July 8, 2016.
EPA. 1978. National organic monitoring survey. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1979. Water-related environmental fate of 129 priority pollutants. U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100K7FH.txt. December 30, 2019.
EPA. 1980a. Manual of analytical methods for the analysis of pesticides in humans and environmental samples. Research Triangle Park, NC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20007QPD.txt. December 30, 2019.
EPA. 1980b. Exposure and risk assessment for pentachlorophenol. Washington, DC: U.S. Environmental Protection Agency. PB85211944. EPA440481021. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101FM1T.txt. December 30, 2019.
EPA. 1984a. Creosote, pentachlorophenol, and the inorganic arsenicals; intent to cancel registrations of pesticide products containing creosote, pentachlorophenol (including its salts), and the inorganic arsenicals; determination concluding the rebuttable presumption against registration of the wood preservative uses of pesticide products; availability of position document. U.S. Environmental Protection Agency. Fed Regist 49(138):28666–28689.
EPA. 1984b. Wood preservative pesticides: creosote pentachlorophenol and the inorganic arsenicals. Position document 4. U.S. Environmental Protection Agency. 24–26. PB84241538. EPA540984003. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101HF9Q.txt. December 30, 2019.
EPA. 1986a. Ambient water criteria document for pentachlorophenol. U.S. Environmental Protection Agency. EPA440586005. https://www.epa.gov/sites/production/files/2019-03/documents/ambient-wqc-pentachlorophenol-1986.pdf. December 30, 2019.
EPA. 1986b. Pentachlorophenol in log homes: A study of environmental and clinical aspects. U.S. Environmental Protection Agency. EPA560587001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91013BBG.txt. February 26, 2020.
EPA. 1989. Recognition and management of pesticide poisonings. U.S. Environmental Protection Agency. PB91145656. EPA540988001. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB91145656.xhtml. February 26, 2020.
EPA. 1991. Land disposal restrictions for third scheduled wastes. U.S. Environmental Protection Agency. Fed Regist 55(21):3864–3928.
EPA. 1992. Land disposal restrictions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.
EPA. 1996. Method 8151A: Chlorinated herbicides by GC using methylation or pentafluorobenzylation derivatization. Hazardous waste test methods / SW-846. U.S. Environmental Protection Agency. https://www.epa.gov/hw-sw846/sw-846-test-method-8151a-chlorinated-herbicides-gas-chromatography-gc-using-methylation-or. December 11, 2019.
EPA. 1997. Data evaluation record. Pentachlorophenol. 83-1b; Fifty-two week repeated dose chronic oral study of pentachlorophenol administered via capsule to dogs. Washington, DC: U.S. Environmental Protection Agency. DP Barcode D225574. MRID 43982701.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2008. Reregistration eligibility decision for pentachlorophenol. U.S. Environmental Protection Agency. EPA739R08008 https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1002CL2.txt. December 11, 2019.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2010. Toxicological review of pentachlorophenol (CAS no. 87-86-5) in support of summary information on the integrated risk information system (IRIS). U.S. Environmental Protection Agency. EPA635R09004F. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0086tr.pdf. April 12, 2020.
EPA. 2014. 2012 Chemical data reporting results. U.S. Environmental Protection Agency. February 20, 2019. https://www.epa.gov/chemical-data-reporting/chemical-data-reporting-previously-collected-data. March 14, 2019.
EPA. 2016. Analysis of occurrence data from the third six-year review of existing national primary drinking water regulations: Chemical phase rules and radionuclides rules. U.S. Environmental Protection Agency. EPA810R16014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100QO3I.txt. December 11, 2019.
EPA. 2017. 2016 Chemical data reporting results. U.S. Environmental Protection Agency. February 20, 2019. https://www.epa.gov/chemical-data-reporting. March 14, 2019.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2020. Initial list of hazardous air pollutants with modifications. U.S. Environmental Protection Agency. https://www.epa.gov/haps/initial-list-hazardous-air-pollutants-modifications. February 9, 2021.
EPA. 2021. 2016 Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting. December 13, 2021.
Eriksson M, Hardell L, Berg NO, 1981. Soft-tissue sarcomas and exposure to chemical substances: a case-referent study. Br J Ind Med 38(1):27–33. 10.1136/oem.38.1.27.7470401
Eriksson M, Hardell L, Adami HO. 1990. Exposure to dioxins as a risk factor for soft tissue sarcoma: A population-based case-control study. J Natl Cancer Inst 82:486–490.2313720
Exon JH, Koller LD. 1982. Effects of transplacental exposure to chlorinated phenols. Environ Health Perspect 46:137–140. 10.1289/ehp.8246137.7151754
Fahrig R. 1974. Comparative mutagenicity studies with pesticides. IARC Sci Publ 10:161–181.
Fahrig R, Steinkamp-Zucht A. 1996. Co-recombinogenic and anti-mutagenic effects of diethylphthalate, inactiveness of pentachlorophenol in the spot test with mice. Mutat Res 354:59–67.8692207
Fahrig R, Nilsson CA, Rappe C. 1978. Genetic activity of chlorophenols and chlorophenol impurities. In: Rao KR, ed. Pentachlorophenol. Environmental science research. Boston, MA: Springer, 325–338.
Farrington DS, Munday JW. 1976. Determination of trace amounts of chlorophenols by gas-liquid chromatography. Analyst 101:639–643.
FDA. 1989. Residues in foods-1988. Food and Drug Administration. J Assoc Off Anal Chem 72(5):133A–152A.
FDA. 2006. Total diet study. Market baskets 1991-3 through 2003-4. U.S. Food and Drug Administration. https://www.fda.gov/media/77962/download. December 11, 2019.
FDA. 2021a. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. February 3, 2021.
FDA. 2021b. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2021-title21-vol2/pdf/CFR-2021-title21-vol2-sec165-110.pdf. December 16, 2021.
FDA. 2021c. Pentachlorophenol. Indirect additives used in food contact substances. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/index.cfm?set=IndirectAdditives&id=PENTACHLOROPHENOL. December 16, 2021.
FDA. 2021d. Sodium pentachlorophenate. Indirect additives used in food contact substances. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=IndirectAdditives&id=SODIUMPENTACHLOROPHENATE. December 16, 2021.
Fernandes AR, Mortimer D, Rose M, 2019. Recently listed Stockholm convention POPs: Analytical methodology, occurrence in food and dietary exposure. Sci Total Environ 678:793–800. 10.1016/j.scitotenv.2019.04.433.31085495
Fernie KJ, Letcher RJ. 2010. Historical contaminants, flame retardants, and halogenated phenolic compounds in peregrine Falcon (Falco peregrinus) nestlings in the Canadian Great Lakes Basin. Environ Sci Technol 44(9):3520–3526. 10.1021/es100400n.20384324
Ferreira AJ, Vieira DN, Marques EP, 1997. Occupational exposure to pentachlorophenol: the Portuguese situation. Ann N Y Acad Sci 837:291–299. 10.1111/j.1749-6632.1997.tb56881.x.9472347
Fleischer M, Meiss R, Robenek H, 1980. Ultrastructural morphometric investigations on rat liver of young and adult rats after treatment with technical pentachlorophenol (PCP). Arch Toxicol 44(4):243–257. 10.1007/bf00278032.7396711
Fraser DL, Stander BA, Steenkamp V. 2019. Cytotoxic activity of pentachlorophenol and its active metabolites in SH-SY5Y neuroblastoma cells. Toxicol in Vitro 58:118–125. 10.1016/j.tiv.2019.03.024.30905860
Frisbie AAJ, Nies L. 1997. Aerobic and anaerobic biodegradation of aged pentachlorophenol by indigenous microorganisms. Biorem J 1:65–75.
Gab S, Nitz S, Parlar H, 1975. Photomineralisation of certain aromatic xenobiotica. Chemosphere 4:251–256.
Galil NI, Novak JT. 1995. Pentachlorophenol-induced release of soil organics and colloids. Water Res 29:1533–1544.
Gebefigi I, Korte F. 1983. Pentachlorophenol contamination of human milk samples. Chemosphere 12:1055–1060.
Gebefugi I, Parlar H, Kort F. 1976. Beitrage zur okologischen chemie cxxvi. Kurze mitteilung uber die analtyische erfassung von pentachlorophenol in geschlossenen raumen. Chemosphere 4:227–230.
Gerhard I, Derner M, Runnebaum B. 1991. Prolonged exposure to wood preservatives induces endocrine and immunologic disorders in women. Am J Obstet Gynecol 165(2):487–488. 10.1016/0002-9378(91)90131-a.
Gerhard I, Daniel V, Link S, 1998. Chlorinated hydrocarbons in women with repeated miscarriages. Environ Health Perspect 106(10):675–681. 10.1289/ehp.98106675.9755145
Gerhard I, Frick A, Monga B, 1999. Pentachlorophenol exposure in women with gynecological and endocrine dysfunction. Environ Res 80(4):383–388. 10.1006/enrs.1998.3934.10330312
Geyer HJ, Scheunert I, Korte F. 1987. Distribution and bioconcentration potential of the environmental chemical pentachlorophenol (PCP) in different tissues of humans. Chemosphere 16(4):887–899.
Gluth G, Freitag D, Hanke W, 1985. Accumulation of pollutants in fish. Comp Biochem Physiol C 81(2):273–277. 10.1016/0742-8413(85)90005-2.2861946
Gomez-Catalan J, To-Figueras J, Rodamilans M, 1991. Transport of organochlorine residues in the rat and human blood. Arch Environ Contam Toxicol 20(1):61–66. 10.1007/bf01065329.1996912
Gordon D. 1956. How dangerous is pentachlorophenol. Med J Aust 43:485–488.13368830
Gould E, Frankfurt M, Westlind-Danielsson A, 1990. Developing forebrain astrocytes are sensitive to thyroid hormone. Glia 3(4):283–292. 10.1002/glia.440030408.2144508
Gray RE, Gilliland RD, Smith EE, 1985. Pentachlorophenol intoxication: report of a fatal case, with comments on the clinical course and pathologic anatomy. Arch Environ Health 40(3):161–164. 10.1080/00039896.1985.10545910.4026386
Greichus YA, Libal GW, Johnson DD. 1979. Diagnosis and physiologic effects of pentachlorophenols on young pigs. Part I. Effects of purified pentachlorophenol. Bull Environ Contam Toxicol 23(3):418–422. 10.1007/bf01769981.519052
Grimm HG, Schellmann B, Schaller KH, 1981. [Pentachlorophenol concentrations in tissues and body fluids of normal persons (author’s transl)]. Zentralbl Bakteriol Mikrobiol Hyg B 174(1–2):77–90. (German)7324621
Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
Gunderson EL. 1995. FDA total diet study. J AOAC Int 78:1353–1363.8664570
Guo J, Wu C, Zhang J, 2019. Anthropometric measures at age 3 years in associations with prenatal and postnatal exposures to chlorophenols. Chemosphere 228:204–211. 10.1016/j.chemosphere.2019.04.127.31029966
Guvenius DM, Aronsson A, Ekman-Ordeberg G, 2003. Human prenatal and postnatal exposure to polybrominated diphenyl ethers, polychlorinated biphenyls, polychlorobiphenylols, and pentachlorophenol. Environ Health Perspect 111(9):1235–1241. 10.1289/ehp.5946.12842779
Haley TJ. 1977. Human poisoning with pentachlorophenol and its treatment. Ecotoxicol Environ Saf 1(3):343–347. 10.1016/0147-6513(77)90025-2.617097
Haque A, Ebing W. 1988. Uptake and accumulation of pentachlorophenol and sodium pentachlorophenate by earthworms from water and soil. Sci Total Environ 68:113–125. 10.1016/0048-9697(88)90365-8.3363313
Hardell L, Sandstrom A. 1979. Case-control study: soft-tissue sarcomas and exposure to phenoxyacetic acids or chlorophenols. Br J Cancer 39(6):711–717. 10.1038/bjc.1979.125.444410
Hardell L, Eriksson M. 1999. A case–control study of non-Hodgkin lymphoma and exposure to pesticides. Cancer 85(6):1353–1360.10189142
Hardell L, Eriksson M, Degerman A. 1994. Exposure to phenoxyacetic acids, chlorophenols, or organic solvents in relation to histopathology, stage, and anatomical localization of non-Hodgkin’s lymphoma. Cancer Res 54:2386–2389.8162585
Hardell L, Erikksson M, Degereman A. 1995. Meta-analysis of four Swedish case-control studies on exposure to pesticides as risk-factor for soft-tissue sarcoma including the relation to tumour localization and histopathological type. Int J Oncol 6:847–851.21556610
Hardell L, Eriksson M, Nordstrom M. 2002. Exposure to pesticides as risk factor for non-Hodgkin’s lymphoma and hairy cell leukemia: pooled analysis of two Swedish case-control studies. Leuk Lymphoma 43(5):1043–1049. 10.1080/10428190290021560.12148884
Hardy EM, Dereumeaux C, Guldner L, 2021. Hair versus urine for the biomonitoring of pesticide exposure: Results from a pilot cohort study on pregnant women. Environ Int 152:106481. 10.1016/j.envint.2021.106481.33706039
Hassan AB, Seligmann H, Bassan HM. 1985. Intravascular haemolysis induced by pentachlorophenol. Br Med J (Clin Res Ed) 291(6487):21–22. 10.1136/bmj.291.6487.21.
Hattemer-Frey HA, Travis CC. 1989. Pentachlorophenol: environmental partitioning and human exposure. Arch Environ Contam Toxicol 18(4):482–489. 10.1007/bf01055013.2673066
Heacock H, Hogg R, Manion SA, 1998. Fertility among a cohort of male sawmill workers exposed to chlorophenate fungicides. Epidemiology 9:56–62.9430269
Hebert VR, Miller GC. 1990. Depth dependence of direct and indirect photolysis on soil surfaces. J Agric Food Chem 38:913–918.
Hendriksen HV, Larsen S, Ahring BK. 1991. Anaerobic degradation of PCP and phenol in fixed-film reactors: The influence of an additional substrate. Water Sci Technol 24(3/4):431–436.
Hill RH, To T, Holler JS, 1989. Residues of chlorinated phenols and phenoxy acid herbicides in the urine of Arkansas children. Arch Environ Contam Toxicol 18(4):469–474. 10.1007/bf01055011.2774664
Hill RH, Head SL, Baker S, 1995. Pesticide residues in urine of adults living in the United States: reference range concentrations. Environ Res 71(2):99–108. 10.1006/enrs.1995.1071.8977618
Hoak RD. 1957. The causes of tastes and odors in drinking water. Water Sewage Works 105:243–247.
Hoben HJ, Ching SA, Casarett LJ. 1976a. A study of inhalation of pentachlorophenol by rats. IV. Distribution and excretion of inhaled pentachlorophenol. Bull Environ Contam Toxicol 15(4):466–474.1260155
Hoben HJ, Ching SA, Casarett LJ. 1976b. A study of inhalation of pentachlorophenol by rats. III. Inhalation toxicity study. Bull Environ Contam Toxicol 15(4):463–465.1260154
Hoben HJ, Ching SA, Young RA, 1976c. A study of the inhalation of pentachlorophenol by rats. Part V. A protein binding study of pentachlorophenol. Bull Environ Contam Toxicol 16(2):225–232.9173
Holler JS, Fast DM, Hill RH, 1989. Quantification of selected herbicides and chlorinated phenols in urine by using gas chromatography/mass spectrometry/mass spectrometry. J Anal Toxicol 13:152–157.2755087
Holsapple MP, McNerney PJ, McCay JA. 1987. Effects of pentachlorophenol on the in vitro and in vivo antibody response. J Toxicol Environ Health 20(3):229–239. 10.1080/15287398709530977.3820337
Honda M, Kannan K. 2018. Biomonitoring of chlorophenols in human urine from several Asian countries, Greece and the United States. Environ Pollut 232:487–493. 10.1016/j.envpol.2017.09.073.28966025
Hong HC, Zhou HY, Luan TG, 2005. Residue of pentachlorophenol in freshwater sediments and human breast milk collected from the Pearl River Delta, China. Environ Int 31(5):643–649. 10.1016/j.envint.2004.11.002.15910960
Horstman SW, Rossner A, Kalman DA, 1989. Penetration of pentachlorophenol and tetrachlorophenol through human skin. J Environ Sci Health Part A 24(3):229–242.
Hryhorczuk DO, Wallace WH, Persky V, 1998. A morbidity study of former pentachlorophenol-production workers. Environ Health Perspect 106(7):401–408. 10.1289/ehp.98106401.9637797
HSDB. 2001. Pentachlorophenol. Hazardous Substance Data Bank. Bethesda, MD: National Library of Medicine. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB. February 2, 2001.
IARC. 2019. Pentachlorophenol. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 117. Pentachlorophenol and some related compounds. Lyon, France: International Agency for Research on Cancer. 33–140. http://www.inchem.org/documents/iarc/iarcmono/v117iarc.pdf. December 4, 2019.
Ide A, Niki Y, Sakamoto F, 1972. Decomposition of pentachlorophenol in paddy soil. Agric Biol Chem 36:1937–1944.
Iglesias-González A, Hardy EM, Appenzeller BMR. 2020. Cumulative exposure to organic pollutants of French children assessed by hair analysis. Environ Int 134:105332. 10.1016/j.envint.2019.105332.31785528
Ingerslev F, Baun A, Nyholm N. 1998. Aquatic biodegradation behavior of pentachlorophenol assessed through a battery of shake flask die-away tests. Environ Toxicol Chem 17:1712–1719.
Ingram LLJ, McGinnis GD, Gjovik LR. 1986. Studies on the vaporization of pentachlorophenol from treated wood. Arch Environ Contam Toxicol 15:669–676.
Innes JR, Ulland BM, Valerio MG, 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice: a preliminary note. J Natl Cancer Inst 42(6):1101–1114.5793189
IRIS. 2010. Pentachlorophenol. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0086_summary.pdf. December 4, 2019.
Jackson DR, Bisson DL. 1990. Mobility of polychlorinated aromatic compounds in soils contaminated with wood-preserving oil. J Air Waste Manage Assoc 40(8):1129–1133. 10.1080/10473289.1990.10466758.2119627
Jagels R. 1985. Health hazards of natural and introduced chemical components of boatbuilding woods. Am J Ind Med 8(3):241–251. 10.1002/ajim.4700080309.3901739
Jakobson I, Yllner S. 1971. Metabolisms of 14C-pentachlorophenol in the mouse. Acta Pharmacol Toxicol (Copenh) 29:513–524.4940582
JCHECK. 2021. Pentachlorophenol, 87-86-5. Japan CHEmicals Collaborative Knowledge database. https://www.nite.go.jp/chem/jcheck/detail.action?cno=87-86-5&mno=3-2850&request_locale=en. December 13, 2021.
Jekat FW, Meisel ML, Eckard R, 1994. Effects of pentachlorophenol (PCP) on the pituitary and thyroidal hormone regulation in the rat. Toxicol Lett 71(1):9–25. 10.1016/0378-4274(94)90194-5.8140594
Johansson F, Allkvist A, Erixon K, 2004. Screening for genotoxicity using the DRAG assay: investigation of halogenated environmental contaminants. Mutat Res 563(1):35–47. 10.1016/j.mrgentox.2004.05.017.15324747
Johnson RD, Manske DD. 1977. Pesticide and other chemical residues in total diet samples (XI). Pestic Monit J 11(3):116–131.609510
Johnson RL, Gehring PJ, Kociba RJ, 1973. Chlorinated dibenzodioxins and pentachlorophenol. Environ Health Perspect 5:171–175. 10.1289/ehp.7305171.4270942
Jones RD, Winter DP, Cooper AJ. 1986. Absorption study of pentachlorophenol in persons working with wood preservatives. Hum Toxicol 5(3):189–194. 10.1177/096032718600500307.2872154
Jorens PG, Janssens JJ, van Tichelen WI, 1991. Pentachlorophenol concentrations in human cerebrospinal fluid. Neurotoxicology 12(1):1–7.2014066
Juhl U, Witte I, Butte W. 1985. Metabolism of pentachlorophenol to tetrachlorohydroquinone by human liver homogenate. Bull Environ Contam Toxicol 35(5):596–601. 10.1007/bf01636560.4074922
Karlsson L, Cragin L, Center G, 2013. Pentachlorophenol contamination of private drinking water from treated utility poles. Am J Public Health 103(2):276–277. 10.2105/AJPH.2012.300910.23237185
Kaufman DD. 1978. Degradation of pentachlorophenol in soil, and by soil microorganisms. In: Rao KR, ed. Pentachlorophenol. Environmental science research. Boston, MA: Springer, 27–39.
Kerkvliet NI, Baecher-Steppan L, Schmitz JA. 1982. Immunotoxicity of pentachlorophenol (PCP): increased susceptibility to tumor growth in adult mice fed technical PCP-contaminated diets. Toxicol Appl Pharmacol 62(1):55–64. 10.1016/0041-008x(82)90101-6.6278678
Kerkvliet NI, Brauner JA, Matlock JP. 1985a. Humoral immunotoxicity of polychlorinated diphenyl ethers, phenoxyphenols, dioxins and furans present as contaminants of technical grade pentachlorophenol. Toxicology 36:307–324.4049436
Kerkvliet NI, Brauner JA, Baecher-Steppan L. 1985b. Effects of dietary technical pentachlorophenol exposure on T cell, macrophage and natural killer cell activity in C57B1/6 mice. Int J Immunopharmacol 7:239–247.3159692
Kilzer L, Scheunert I, Geyer H, 1979. Laboratory screening of the volatilization rates of organic chemicals from water and soil. Chemosphere 8(10):751–761.
Kimbrough RD, Linder RE. 1978. The effect of technical and purified pentachlorophenol on the rat liver. Toxicol Appl Pharmacol 46(1):151–162. 10.1016/0041-008x(78)90146-1.725940
Klemmer HW, Wong L, Sato MM, 1980. Clinical findings in workers exposed to pentachlorophenol. Arch Environ Contam Toxicol 9(6):715–725. 10.1007/bf01055546.7469482
Knudsen I, Verschuuren HG, den Tonkelaar EM, 1974. Short-term toxicity of pentachlorophenol in rats. Toxicology 2(2):141–152. 10.1016/0300-483x(74)90005-5.4366426
Kogevinas M, Kauppinen T, Winkelmann R, 1995. Soft tissue sarcoma and non-Hodgkin’s lymphoma in workers exposed to phenoxy herbicides, chlorophenols, and dioxins: two nested case-control studies. Epidemiology 6(4):396–402.7548348
Kooistra L, Laane C, Vulsma T, 1994. Motor and cognitive development in children with congenital hypothyroidism: a long-term evaluation of the effects of neonatal treatment. J Pediatr 124(6):903–909. 10.1016/s0022-3476(05)83178-6.8201474
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554. 10.1248/jhs.48.545.
Kuehl DW, Dougherty RC. 1980. Pentachlorophenol in the environment. Evidence for its origin from commercial pentachlorophenol by negative chemical ionization mass spectrometry. Environ Sci Technol 14(4):447–449. 10.1021/es60164a004.22288633
Kutz FW, Murphy RS, Strassman SC. 1978. Survey of pesticide residues and their metabolites in urine from the general population. In: Rao KR, ed. Pentachlorophenol. Environmental science research. Boston, MA: Springer, 363–369.
Kutz FW, Cook BT, Carter-Pokras OD, 1992. Selected pesticide residues and metabolites in urine from a survey of the U.S. general population. J Toxicol Environ Health 37(2):277–291. 10.1080/15287399209531670.1404486
Kuwatsuka S, Igarashi M. 1975. Degradation of PCP in soils: The relationship between the degradation of the properties of soils, and the identification of the degradation products of PCP. Soil Sci Plant Nutr 21:405–414.
Lambert J, Schepens P, Janssens J, 1986. Skin lesions as a sign of subacute pentachlorophenol intoxication. Acta Derm Venereol 66:170–172.2424245
Lamparski LL, Stehl RH, Johnson RL. 1980. Photolysis of pentachlorophenol-treated wood. Chlorinated dibenzo-p-dioxin. Environ Sci Technol 14:196–200.
Larsen RV, Kirsch LE, Shaw SM, 1972. Excretion and tissue distribution of uniformly labeled 14C-pentachlorophenol in rats. J Pharm Sci 61(12):2004–2006. 10.1002/jps.2600611229.4638118
Larsen RV, Born GS, Kessler WV, 1975. Placental transfer and teratology of pentachlorophenol in rats. Environ Lett 10(2):121–128. 10.1080/00139307509435815.1204587
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics. Implications for practice. Pediatr Clin North Am 44(1):55–77. 10.1016/s0031-3955(05)70463-6.9057784
Lemma A, Ames BN. 1975. Screening for mutagenic activity of some molluscicides. Trans R Soc Trop Med Hyg 69:167–168.
Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol 26(1):37–46. 10.1007/bf00212792.8110022
Lilienblum W. 1985. Formation of pentachlorophenol glucuronide in rat and human liver microsomes. Biochem Pharmacol 34(6):893–894. 10.1016/0006-2952(85)90771-3.3977960
Lin PH, Waidyanatha S, Pollack GM, 1997. Dosimetry of chlorinated quinone metabolites of pentachlorophenol in the livers of rats and mice based upon measurement of protein adducts. Toxicol Appl Pharmacol 145:399–408.9266814
Lin PH, Waidyanatha S, Pollack GM, 1999. Dose-specific production of chlorinated quinone and semiquinone adducts in rodent livers following administration of pentachlorophenol. Toxicol Sci 47(1):126–133. 10.1093/toxsci/47.1.126.10048161
Lin PH, La DK, Upton PB, 2002. Analysis of DNA adducts in rats exposed to pentachlorophenol. Carcinogenesis 23(2):365–369. 10.1093/carcin/23.2.365.11872646
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Table 9-20. Rules of thumb for biodegradability. In: Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Co., Table 9-20.
Maheshwari N, Mahmood R. 2020a. 3,4-Dihydroxybenzaldehyde attenuates pentachlorophenol-induced cytotoxicity, DNA damage and collapse of mitochondrial membrane potential in isolated human blood cells. Drug Chem Toxicol:1–18. 10.1080/01480545.2020.1811722.
Maheshwari N, Mahmood R. 2020b. Protective effect of catechin on pentachlorophenol-induced cytotoxicity and genotoxicity in isolated human blood cells. Environ Sci Pollut Res Int 27(12):13826–13843. 10.1007/s11356-020-07969-0.32036526
Maheshwari N, Khan FH, Mahmood R. 2019. Pentachlorophenol-induced cytotoxicity in human erythrocytes: enhanced generation of ROS and RNS, lowered antioxidant power, inhibition of glucose metabolism, and morphological changes. Environ Sci Pollut Res Int 26(13):12985–13001. 10.1007/s11356-019-04736-8.30895543
Makela TP, Petanen T, Kukkonen J, 1991. Accumulation and depuration of chlorinated phenolics in the freshwater mussel (Anodonta anatina L.). Ecotoxicol Environ Saf 22(2):153–163. 10.1016/0147-6513(91)90055-t.1769349
Manske DD, Corneliussen PE. 1976. Pesticide residues in total diet samples (VII). Pestic Monit J 8(2):110–124.
Markiewizc KV, Howie LE, Safe SH, 1996. Mutagenic potential of binary and complex mixtures using different enzyme induction systems. J Toxicol Environ Health 47:443–451.8614014
Martin TJ, Snape JR, Bartram A, 2017. Environmentally relevant inoculum concentrations improve the reliability of persistent assessments in biodegradation screening tests. Environ Sci Technol 51(5):3065–3073. 10.1021/acs.est.6b05717.28125206
Martins JM, Jocteur Monrozier L, Chalamet A, 1997. Microbial response to repeated applications of low concentrations of pentachlorophenol in an Alfisol under pasture. Chemosphere 35(8):1637–1650. 10.1016/s0045-6535(97)00245-2.9353904
Matsunaga H, Mizota K, Uchida H, 2010. Endocrine disrupting chemicals bind to a novel receptor, microtubule-associated protein 2, and positively and negatively regulate dendritic outgrowth in hippocampal neurons. J Neurochem 114(5):1333–1343. 10.1111/j.1471-4159.2010.06847.x.20534002
McAllister KA, Lee H, Trevore JT. 1996. Microbial degradation of pentachlorophenol. Biodegradation 7:1–40.
McConnachie PR, Zahalsky AC. 1991. Immunological consequences of exposure to pentachlorophenol. Arch Environ Health 46(4):249–253. 10.1080/00039896.1991.9937456.2069434
Meerman JHN, Sterenborg HMJ, Mulder GJ. 1983. Use of pentachlorophenol as long-term inhibitor of sulfation of phenols and hydroxamic acids in the rat in vivo. Biochem Pharmacol 32(10):1587–1593.6860346
Mehmood Z, Williamson MP, Kelly DE, 1996. Metabolism of organochlorine pesticides: the role of human cytochrome P450 3A4. Chemosphere 33(4):759–769. 10.1016/0045-6535(96)00212-3.8759309
Meijer L, Brouwer B, Frank HJ, 2008. Influence of prenatal exposure to selected organohalogans on infant sexual and neurological development. Organohalogen Compounds 70:658–661. http://dioxin20xx.org/wp-content/uploads/pdfs/2008/08-368.pdf.
Menon JA. 1958. Tropical hazards associated with the use of pentachlorophenol. Br Med J 1:1156–1158.13536446
Meylan WM, Howard PH. 1991. Bond contribution method for estimating Henry’s Law constant. Environ Toxicol Chem 10:1283–1293.
Mohammed SA, Sorensen DL, Sims RC, 1998. Pentachlorophenol and phenanthrene biodegradation in creosote contaminated aquifer material. Chemosphere 37(1):103–111. 10.1016/s0045-6535(98)00026-5.9637006
Moriya M, Ohta T, Watanabe K, 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116:185–216.6339892
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
NCI. 1968. Evaluation of carcinogenic, teratogenic and mutagenic activities of selected pesticides and industrial chemicals. Volume I. Carcinogenic study. National Cancer Institute. PB223159. http://www.nal.usda.gov/exhibits/speccoll/items/show/4099. February 26, 2020.
NCI. 1986. Monograph on human exposure to chemicals in the workplace: Pentachlorophenol. Bethesda, MD: National Cancer Institute. PB86155116.
Needham LL, Cline RE, Head SL, 1981. Determining pentachlorophenol in body fluids by gas chromatography after acetylation. J Anal Toxicol 5(6):283–286. 10.1093/jat/5.6.283.7339212
Neveu I, Arenas E. 1996. Neurotrophins promote the survival and development of neurons in the cerebellum of hypothyroid rats in vivo. J Cell Biol 133(3):631–646. 10.1083/jcb.133.3.631.8636237
Niimi AJ, Cho CY. 1983. Laboratory and field analysis of pentachlorophenol (PCP) accumulation by salmonids. Water Res 17(12):1791–1795.
NIOSH. 1984. Pentachlorophenol in blood, Method 8001. NIOSH manual of analytical methods. National Institute for Occupational Safety and Health.
NIOSH. 1994. Pentachlorophenol. Immediately dangerous to life or health concentrations (IDLH). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/87865.html. December 4, 2019.
NIOSH. 2019. Pentachlorophenol. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0484.html. December 4, 2019.
Nishimura H, Nishimura N, Oshima H. 1980. Experimental studies on the toxicity of pentachlorophenol. J Aichi Med Univ Assoc 8:203–209.
NLM. 2021. Pentachlorophenol, CID=992. PubChem database. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Pentachlorophenol. December 3, 2021.
NPIRS. 2021. Active ingredient information. PC Code: 63001. National Pesticide Information Retrieval System. http://npirspublic.ceris.purdue.edu/ppis/default.aspx. December 13, 2021.
NTP. 1989. NTP technical report on the toxicology and carcinogenesis studies of two pentachlorophenol technical-grade mixtures (CAS No. 87-86-5) in B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 349. NIH Publication No. 89-2804.
NTP. 1999. Toxicology and carcinogenesis studies of pentachlorophenol (CAS No. 87-86-5) in F344/N rats (feed studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 483. NIH Publication No. 99-3973.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/hat/review/index-2.html. December 4, 2019.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016. Pentachlorophenol and by-products of its synthesis. Report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/pentachlorophenol.pdf. December 4, 2019.
Ohe T. 1979. Pentachlorophenol residues in human adipose tissue. Bull Environ Contam Toxicol 22(3):287–292. 10.1007/bf02026944.465796
O’Malley MA, Carpenter AV, Sweeney MH, 1990. Chloracne associated with employment in the production of pentachlorophenol. Am J Ind Med 17(4):411–421. 10.1002/ajim.4700170401.2139304
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. December 16, 2021.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. December 16, 2021.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. December 16, 2021.
Ostrea EM, Morales V, Ngoumgna E, 2002. Prevalence of fetal exposure to environmental toxins as determined by meconium analysis. Neurotoxicology 23(3):329–339. 10.1016/s0161-813x(02)00077-3.12389578
Pearce NE, Smith AH, Howard JK, 1986a. Case-control study of multiple myeloma and farming. Br J Cancer 54:493–500.3756085
Pearce NE, Smith AH, Howard JK, 1986b. Non-Hodgkin’s lymphoma and exposure to phenoxyherbicides, chlorophenols, fencing work, and meat works employment: A case-control study. Br J Ind Med 43:75–83.3753879
Pekari K, Aitio A. 1982. A simple liquid chromatographic method for the analysis of penta- and tetrachlorophenols in urine of exposed workers. J Chromatogr 232(1):129–136. 10.1016/s0378-4347(00)86015-6.7142321
Pekari K, Luotamo M, Jarvisalo J, 1991. Urinary excretion of chlorinated phenols in saw-mill workers. Int Arch Occup Environ Health 63(1):57–62. 10.1007/bf00406199.1856025
Peper M, Ertl M, Gerhard I. 1999. Long-term exposure to wood-preserving chemicals containing pentachlorophenol and lindane is related to neurobehavioral performance in women. Am J Ind Med 35(6):632–641. 10.1002/(sici)1097-0274(199906)35:6<632::aid-ajim10>3.0.co;2-r.10332516
Pignatello JJ, Martinson MM, Steiert JG, 1983. Biodegradation and photolysis of pentachlorophenol in artificial freshwater streams. Appl Environ Microbiol 46(5):1024–1031.6651292
Pignatello JJ, Johnson LK, Martinson MM, 1985. Response of the microflora in outdoor experimental streams to pentachlorophenol: compartmental contributions. Appl Environ Microbiol 50(1):127–132.4026288
Pommer E, Jaetsch T. 2012. Wood, preservation. In: Ullmann’s encyclopedia of industrial chemistry. Vol. 39. Weinheim: Wiley-VCH Verlag GmBH & Co. KGaA, 507–536. 10.1002/14356007.a28_357.pub2.
Pruitt GW, Grantham BJ. 1977. Accumulation and elimination of pentachlorophenol by the bluegill, Lepomis macrochirus. Trans Amer Fish Soc 106:462–465.
Pu X, Carlson G, Lee L. 2003. Oral bioavailability of pentachlorophenol from soils of varying characteristics using a rat model. J Toxicol Environ Health 66(21):2001–2013. 10.1080/15287390390227615.
Qiao GL, Riviere JE. 2002. Systemic uptake and cutaneous disposition of pentachlorophenol in a sequential exposure scenario: effects of skin preexposure to benzo[a]pyrene. J Toxicol Environ Health 65(18):1307–1331. 10.1080/00984100290071577.
Qiao GL, Brooks JD, Riviere JE. 1997. Pentachlorophenol dermal absorption and disposition from soil in swine: effects of occlusion and skin microorganism inhibition. Toxicol Appl Pharmacol 147(2):234–246. 10.1006/taap.1997.8288.9439719
Raeppel C, Salquebre G, Millet M, 2016. Pesticide detection in air samples from contrasted houses and in their inhabitants’ hair. Sci Total Environ 544:845–852. 10.1016/j.scitotenv.2015.12.020.26706757
Ramlow JM, Spadacene NW, Hoag SR, 1996. Mortality in a cohort of pentachlorophenol manufacturing workers, 1940-1989. Am J Ind Med 30(2):180–194. 10.1002/(SICI)1097-0274(199608)30:2<180::AID-AJIM9>3.0.CO;2-4.8844048
Rawlings NC, Cook SJ, Waldbillig D. 1998. Effects of the pesticides carbofuran, chlorpyrifos, dimethoate, lindane, triallate, trifluralin, 2,4-D, and pentachlorophenol on the metabolic endocrine and reproductive endocrine system in ewes. J Toxicol Environ Health 54(1):21–36. 10.1080/009841098159006.
Reigner BG, Gungon RA, Hoag MK, 1991. Pentachlorophenol toxicokinetics after intravenous and oral administration to rat. Xenobiotica 21(12):1547–1558. 10.3109/00498259109044404.1785202
Reigner BG, Bois FY, Tozer TN. 1992a. Assessment of pentachlorophenol exposure in humans using the clearance concept. Hum Exp Toxicol 11:17–26.1354455
Reigner BG, Rigod JF, Tozer TN. 1992b. Disposition, bioavailability, and serum protein binding of pentachlorophenol in the B6C3F1 mouse. Pharm Res 9(8):1053–1057.1409377
Reigner BG, Bois FY, Tozer TN. 1993. Pentachlorophenol carcinogenicity: extrapolation of risk from mice to humans. Hum Exp Toxicol 12(3):215–225. 10.1177/096032719301200304.8100432
Reiner EA, Chu J, Kirsch EJ. 1978. Microbial metabolism of pentachlorophenol. In: Rao KR, ed. Pentachlorophenol. Environmental science research. Boston, MA: Springer, 67–81.
Renner G. 1989. Urinary excretion of pentachlorophenol (PCP) and its metabolite tetrachlorohydroquinone (TCH) in rats. Toxicol Environ Chem 25:29–32.
Renner G, Hopfer C. 1990. Metabolic studies on pentachlorophenol (PCP) in rats. Xenobiotica 20(6):573–582. 10.3109/00498259009046872.2219952
Renner G, Hopfer C, Gokel JM. 1986. Acute toxicities of pentachlorophenol, pentachloroanisole, tetrachlorohydroquinone, tetrachlorocatechol, tetrachlororesorcinol, tetrachlorodimethoxybenzenes and tetrachlorobenzenediol diacetates administered to mice. Toxicol Environ Chem 11:37–50.
RePORTER. 2021. Pentachlorophenol. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. December 3, 2021.
Rick DL, Licht CF, McCarty LP. 1982. Determination of phenol and pentachlorophenol in plasma and urine samples by gas liquid chromatography. J Anal Toxicol 6(6):297–300. 10.1093/jat/6.6.297.7162140
Roberts HJ. 1963. Aplastic anemia due to pentachlorophenol and tetrachlorophenol. South Med J 56:632–635.13974304
Roberts HJ. 1981. Aplastic anemia due to pentachlorophenol. N Engl J Med 305:1650–1651.
Roberts HJ. 1983. Aplastic anemia and red cell aplasia due to pentachlorophenol. South Med J 76:45–48.6823577
Roberts HJ. 1990. Pentachlorophenol-associated aplastic anemia, red cell aplasia, leukemia and other blood disorders. J Fla Med Assoc 77(2):86–90.2106570
Robson AM, Kissane JM, Elvick NH, 1969. Pentachlorophenol poisoning in a nursery for newborn infants. I. Clinical features and treatment. J Pediatr 75(2):309–316. 10.1016/s0022-3476(69)80406-3.5795352
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Roze E, Meijer L, Bakker A, 2009. Prenatal exposure to organohalogens, including brominated flame retardants, influences motor, cognitive, and behavioral performance at school age. Environ Health Perspect 117(12):1953–1958. 10.1289/ehp.0901015.20049217
Rozman T, Ballhorn L, Rozman K, 1982. Effect of cholestyramine on the disposition of pentachlorophenol in rhesus monkeys. J Toxicol Environ Health 10(2):277–283. 10.1080/15287398209530250.7143481
Ruder AM, Yiin JH. 2011. Mortality of US pentachlorophenol production workers through 2005. Chemosphere 83(6):851–861. 10.1016/j.chemosphere.2011.02.064.21440286
Ruel MVM, Bos AF, Soechitram SD, 2019. Prenatal exposure to organohalogen compounds and children’s mental and motor development at 18 and 30 months of age. Neurotoxicology 72:6–14. 10.1016/j.neuro.2019.01.003.30664974
Rugman FP, Cosstick R. 1990. Aplastic anaemia associated with organochlorine pesticide: case reports and review of evidence. J Clin Pathol 43(2):98–101. 10.1136/jcp.43.2.98.1690760
Sai-Kato K, Umemura T, Takagi A, 1995. Pentachlorophenol-induced oxidative DNA damage in mouse liver and protective effect of antioxidants. Food Chem Toxicol 33(10):877–882. 10.1016/0278-6915(95)00056-8.7590532
Savolainen H, Pekari K. 1979. Neurochemical effects of peroral administration of technical pentachlorophenol. Res Commun Chem Pathol Pharmacol 23(1):97–105.441521
Schellenberg K, Leuenberger C, Schwarzenbach RP. 1984. Sorption of chlorinated phenols by natural sediments and aquifer materials. Environ Sci Technol 18:652–657.
Schwetz BA, Keeler PA, Gehring PJ. 1974. The effect of purified and commercial grade pentachlorophenol on rat embryonal and fetal development. Toxicol Appl Pharmacol 28(1):151–161. 10.1016/0041-008x(74)90141-0.4854776
Schwetz BA, Quast JF, Keeler PA, 1978. Results of two-year toxicity and reproduction studies on pentachlorophenol in rats. In: Rao KR, ed. Pentachlorophenol. Environmental science research. Vol. 12. Boston, MA: Springer, 301–309. 10.1007/978-1-4615-8948-8_26.
Sehgal VN, Ghorpade A. 1983. Fume inhalation chloracne. Dermatologica 167(1):33–36. 10.1159/000249741.6226546
Seidler A, Hellenbrand W, Robra BP, 1996. Possible environmental, occupational, and other etiologic factors for Parkinson’s disease: a case-control study in Germany. Neurology 46(5):1275–1284. 10.1212/wnl.46.5.1275.8628466
Shafik TM. 1973. The determination of pentachlorophenol and hexachlorophene in human adipose tissue. Bull Environ Contam Toxicol 10(1):57–63.
Shan G, Ye M, Zhu B, 2013. Enhanced cytotoxicity of pentachlorophenol by perfluorooctane sulfonate or perfluorooctanoic acid in HepG2 cells. Chemosphere 93(9):2101–2107. 10.1016/j.chemosphere.2013.07.054.23972907
Shin HM, Moschet C, Young TM, 2020. Measured concentrations of consumer product chemicals in California house dust: Implications for sources, exposure, and toxicity potential. Indoor Air 30(1):60–75. 10.1111/ina.12607.31587372
Siqueira ME, Fernicola NA. 1981. Determination of pentachlorophenol in urine. Bull Environ Contam Toxicol 27(3):380–385. 10.1007/bf01611036.7296071
Smejtek P. 1987. The physicochemical basis of the membrane toxicity of pentachlorophenol: An overview. J Memb Sci 33:249–268.
Smith AD, Bharath A, Mallard C, 1990. Bioconcentration kinetics of some chlorinated benzenes and chlorinated phenols in American flagfish, Jordanella floridae (Goode and Bean). Chemosphere 30(3/4):379–386.
Smith JE, Loveless LE, Belden EA. 1996. Pentachlorophenol poisoning in newborn infants - St. Lois, Missouri, April-August 1967. MMWR Morb Mortal Wkly Rep 45(25):545–547.9132572
Spalding JW, French JE, Stasiewicz S, 2000. Responses of transgenic mouse lines p53(+/-) and Tg.AC to agents tested in conventional carcinogenicity bioassays. Toxicol Sci 53(2):213–223. 10.1093/toxsci/53.2.213.10696769
St. Omer VE, Gadusek F. 1987. The acute oral LD50 of technical pentachlorophenol in developing rats. Environ Toxicol Chem 6:147–149.
Stackelberg PE, Furlong ET, Meyer MT, 2004. Persistence of pharmaceutical compounds and other organic wastewater contaminants in a conventional drinking-water-treatment plant. Sci Total Environ 329(1–3):99–113. 10.1016/j.scitotenv.2004.03.015.15262161
Stein SA, Kirkpatrick LL, Shanklin DR, 1991. Hypothyroidism reduces the rate of slow component A (SCa) axonal transport and the amount of transported tubulin in the hyt/hyt mouse optic nerve. J Neurosci Res 28(1):121–133. 10.1002/jnr.490280113.1710281
Tasaki M, Kuroiwa Y, Inoue T, 2014. Lack of nrf2 results in progression of proliferative lesions to neoplasms induced by long-term exposure to non-genotoxic hepatocarcinogens involving oxidative stress. Exp Toxicol Pathol 66(1):19–26. 10.1016/j.etp.2013.07.003.23988840
Thompson TS, Treble RG. 1994. Preliminary results of a survey of pentachlorophenol levels in human urine. Bull Environ Contam Toxicol 53(2):274–279. 10.1007/bf00192044.8086711
Thompson TS, Treble RG. 1996. Pentachlorophenol levels in human urine. Bull Environ Contam Toxicol 56(4):520–526. 10.1007/s001289900075.8645905
Tisch M, Faulde MK, Maier H. 2005. Genotoxic effects of pentachlorophenol, lindane, transfluthrin, cyfluthrin, and natural pyrethrum on human mucosal cells of the inferior and middle nasal conchae. Am J Rhinol 19(2):141–151.15921213
Treble RG, Thompson TS. 1996. Normal values for pentachlorophenol in urine samples collected from a general population. J Anal Toxicol 20(5):313–317. 10.1093/jat/20.5.313.8872241
TRI20. 2021. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-customized-search. November 8, 2021.
Triebig G, Csuzda I, Krekeler HJ, 1987. Pentachlorophenol and the peripheral nervous system: a longitudinal study in exposed workers. Br J Ind Med 44(9):638–641. 10.1136/oem.44.9.638.2822076
Turney GL, Goerlitz DF. 1990. Organic contamination of ground water at Gas Works Park, Seattle, Washington. Ground Water Monit Remed 10(3):187–198. 10.1111/j.1745-6592.1990.tb00014.x.
Uhl S, Schmid P, Schlatter C. 1986. Pharmacokinetics of pentachlorophenol in man. Arch Toxicol 58(3):182–186. 10.1007/bf00340979.3964082
Umemura T, Sai-Kato K, Takagi A, 1996. Oxidative DNA damage and cell proliferation in the livers of B6C3F1 mice exposed to pentachlorophenol in their diet. Fundam Appl Toxicol 30:285–289.8812277
Umemura T, Kai S, Hasegawa R, 1999. Pentachlorophenol (PCP) produces liver oxidative stress and promotes but does not initiate hepatocarcinogenesis in B6C3F1 mice. Carcinogenesis 20(6):1115–1120. 10.1093/carcin/20.6.1115.10357797
Umemura T, Kai S, Hasegawa R, 2003a. Prevention of dual promoting effects of pentachlorophenol, an environmental pollutant, on diethylnitrosamine-induced hepato- and cholangiocarcinogenesis in mice by green tea infusion. Carcinogenesis 24(6):1105–1109. 10.1093/carcin/bgg053.12807750
Umemura T, Kodama Y, Kanki K, 2003b. Pentachlorophenol (but not phenobarbital) promotes intrahepatic biliary cysts induced by diethylnitrosamine to cholangio cystic neoplasms in B6C3F1 mice possibly due to oxidative stress. Toxicol Pathol 31(1):10–13. 10.1080/01926230390173806.12597444
Umemura T, Kuroiwa Y, Kitamura Y, 2006. A crucial role of Nrf2 in in vivo defense against oxidative damage by an environmental pollutant, pentachlorophenol. Toxicol Sci 90(1):111–119. 10.1093/toxsci/kfj076.16352618
van Gestel CA, Ma WC. 1988. Toxicity and bioaccumulation of chlorophenols in earthworms, in relation to bioavailability in soil. Ecotoxicol Environ Saf 15(3):289–297. 10.1016/0147-6513(88)90084-x.3168876
van Langeveld HE. 1975. Hazardous substances. Determination of pentachlorophenol in toy paints. J Assoc Off Anal Chem 58(1):19–22.1141150
van Raaij JAGM, van den Berg KJ, Notten WRF. 1991a. Hexachlorobenzene and its metabolites pentachlorophenol and tetrachlorohydroquinone: interaction with thyroxine binding sites of rat thyroid hormone carriers ex vivo and in vitro. Toxicol Lett 59:101–107.1755017
van Raaij JAGM, van den Berg KJ, Engel R, 1991b. Effects of hexachlorobenzene and its metabolites pentachlorophenol and tetrachlorohydroquinone on serum thyroid hormone levels in rats. Toxicology 67:107–116.2017761
van Raaij JAGM, Frijters CMG, Kong LWY, 1994. Reduction of thyroxine uptake into cerebrospinal fluid and rat brain by hexachlorobenzene and pentachlorophenol. Toxicology 94:197–208.7801323
Vega-Nunez E, Menedez-Hurtado A, Garesse R, 1995. Thyroid hormone-regulated brain mitochondrial genes revealed by differential cDNA cloning. J Clin Invest 96:893–899.7635984
Veith GD, de PD, Knuth M. 1985. Structure-activity relationships for screening organic chemicals for potential ecotoxicity effects. Drug Metab Rev 15(7):1295–1303.
Veningerova M, Uhnak J, Prachar V, 1996. Chlorinated phenols in human milk. Z Lebensm Unters Forsch 203(3):309–310. 10.1007/bf01192883.8873463
Verschueren K. 1983. Pentachlorophenol. In: Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Co., 953–954.
Veyhe AS, Nost TH, Sandanger TM, 2013. Is meconium useful to predict fetal exposure to organochlorines and hydroxylated PCBs? Environ Sci Process Impacts 15(8):1490–1500. 10.1039/c3em00132f.23828374
Villena F, Montoya G, Klaasen R, 1992. Morphological changes on nerves and histopathological effects on liver and kidney of rats by pentachlorophenol (PCP). Comp Biochem Physiol C 101(2):353–363. 10.1016/0742-8413(92)90287-h.1354112
Vogel E, Chandler JLR. 1974. Mutagenicity testing of cyclamate and some pesticides in Drosophila melanogaster. Experientia 30:621–623.4209504
Wagner SL, Durand LR, Inman RD, 1991. Residues of pentachlorophenol and other chlorinated contaminants in human tissues: analysis by electron capture gas chromatography and electron capture negative ion mass spectrometry. Arch Environ Contam Toxicol 21(4):596–606. 10.1007/bf01183883.1759853
Waidyanatha S, Lin PH, Rappaport SM. 1996. Characterization of chlorinated adducts of hemoglobin and albumin following administration of pentachlorophenol to rats. J Anal Toxicol 9(3):647–653. 10.1021/tx950172n.
Waidyanatha S, McDonald TA, Lin PH, 1994. Measurement of hemoglobin and albumin adducts of tetrachlorobenzoquinone. Chem Res Toxicol 7(3):463–468. 10.1021/tx00039a027.8075381
Waite DT, Gurprasad NP, Cessna AJ, 1998. Atmospheric pentachlorophenol concentrations in relation to air temperature at five Canadian locations. Chemosphere 37(9):2251–2260.9828341
Walls CB, Glass WI, Pearce NE. 1998. Health effects of occupational pentachlorophenol exposure in timber sawmill employees: a preliminary study. N Z Med J 111(1074):362–364.11039822
Wang YJ, Lin JK. 1995. Estimation of selected phenols in drinking water with in situ acetylation and study on the DNA damaging properties of polychlorinated phenols. Arch Environ Contam Toxicol 28(4):537–542. 10.1007/bf00211639.7755407
Wang Z, Liu Y, Li T, 2021. Wood preservatives in children’s wooden toys from China: Distribution, migration, oral exposure, and risk assessment. Ecotoxicol Environ Saf 209:111786. 10.1016/j.ecoenv.2020.111786.33340956
Ward MH, Colt JS, Metayer C, 2009. Residential exposure to polychlorinated biphenyls and organochlorine pesticides and risk of childhood leukemia. Environ Health Perspect 117(6):1007–1013. 10.1289/ehp.0900583.19590698
Waters MD, Sandhu SS, Simmon VF, 1982. Study of pesticide genotoxicity. Basic Life Sci 21:275–326. 10.1007/978-1-4684-4352-3_23.7150196
Weinbach EC. 1954. The effect of pentachlorophenol on oxidative phosphorylation. J Biol Chem 210(2):545–550.13211591
Weinbach EC, Garbus J. 1965. The interaction of uncoupling phenols with mitochondria and with mitochondrial protein. J Biol Chem 240:1811–1819.14285529
Welsh JJ, Collins TF, Black TN, 1987. Teratogenic potential of purified pentachlorophenol and pentachloroanisole in subchronically exposed Sprague-Dawley rats. Food Chem Toxicol 25(2):163–172. 10.1016/0278-6915(87)90150-5.3557239
Wester RC, Maibach HI, Sedik L, 1993. Percutaneous absorption of pentachlorophenol from soil. Fundam Appl Toxicol 20(1):68–71. 10.1006/faat.1993.1008.8432428
White KL, Anderson AC. 1985. Suppression of mouse complement activity by contaminants of technical grade pentachlorophenol. Agents Actions 16(5):385–392. 10.1007/bf01982877.4050617
WHO. 1987. Environmental health criteria 71: Pentachlorophenol. Geneva, Switzerland: World Health Organization. http://hdl.handle.net/20.500.11822/29371. February 26, 2020.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wilson NK, Chuang JC, Morgan MK, 2007. An observational study of the potential exposures of preschool children to pentachlorophenol, bisphenol-A, and nonylphenol at home and daycare. Environ Res 103(1):9–20. 10.1016/j.envres.2006.04.006.16750524
Wong AS, Crosby DG. 1981. Photodecomposition of pentachlorophenol in water. J Agric Food Chem 29(1):125–130.
Wood S, Rom WN, White GL, 1983. Pentachlorophenol poisoning. J Occup Med 25(7):527–530.6886856
WQP. 2021. Pentachlorophenol. Water quality portal. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. December 14, 2021.
Wyllie JA, Gabica J, Benson WW, 1975. Exposure and contamination of the air and employees of a pentachlorophenol plant, Idaho--1972. Pestic Monit J 9(3):150–153.1241126
Yang X, Ou W, Zhao S, 2021a. Human transthyretin binding affinity of halogenated thiophenols and halogenated phenols: An in vitro and in silico study. Chemosphere 280:130627. 10.1016/j.chemosphere.2021.130627.33964751
Yang WJ, Wu HB, Zhang C, 2021b. Exposure to 2,4-dichlorophenol, 2,4,6-trichlorophenol, pentachlorophenol and risk of thyroid cancer: a case-control study in China. Environ Sci Pollut Res Int 28(43):61329–61343. 10.1007/s11356-021-14898-z.34173948
Yang WJ, Wu HB, Zhang C, 2021c. Supplemental material: Exposure to 2,4-dichlorophenol, 2,4,6-trichlorophenol, pentachlorophenol and risk of thyroid cancer: a case-control study in China. Environ Sci Pollut Res Int 28(43) 10.1007/s11356-021-14898-z.
You CN, Liu JC. 1996. Desorptive behavior of chlorophenols in contaminated soils. Water Sci Technol 33(6):263–270.
Young HC, Carroll JC. 1951. The decomposition of pentachlorophenol when applied as a residual pre-emergence herbicide. Agron J:504–507.
Yuan JH, Goehl TJ, Murrill E, 1994. Toxicokinetics of pentachlorophenol in the F344 rat. Gavage and dosed feed studies. Xenobiotica 24(6):553–560.7975721
Zarus GM, Rosales-Guevara L. 2012. Exposure to pentachlorophenol near a wood treatment plant. Rev Salud Ambient 12(2):82–92.
Zheng W, Wang X, Yu H, 2011. Global trends and diversity in pentachlorophenol levels in the environment and in humans: a meta-analysis. Environ Sci Technol 45(11):4668–4675. 10.1021/es1043563.21528888
Zheng R, Zhang Q, Zhang Q, 2015. Occupational exposure to pentachlorophenol causing lymphoma and hematopoietic malignancy for two generations. Toxicol Ind Health 31(4):328–342. 10.1177/0748233712472520.23315091
Zhou Q, Wu WL, Lin CQ, 2021. Occurrence and dietary exposure assessment of pentachlorophenol in livestock, poultry, and aquatic foods marketed in Guangdong Province, China: Based on food monitoring data from 2015 to 2018. J Food Sci 86(3):1132–1143. 10.1111/1750-3841.15653.33598948
Ziemsen B, Angerer J, Lehnert G. 1987. Sister chromatid exchange and chromosomal breakage in pentachlorophenol (PCP) exposed workers. Int Arch Occup Environ Health 59:413–417.3610341