# VERSION HISTORY

Date | Description
April 2022 | Final toxicological profile released
July 2021 | Toxicological profile released for public comment
August 2012 | Addendum to toxicological profile released
September 2001 | Final toxicological profile released
October 1994 | Final toxicological profile released