# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding pentachlorophenol in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for pentachlorophenol.

Table 7-1 Regulations and Guidelines Applicable to Pentachlorophenol

Agency | Description | Information | Reference
Air
EPA | Hazardous Air Pollutant | Listed | EPA 2020
EPA | RfC | Not derived | IRIS 2010
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 1 mg/L
EPA | 10-Day health advisory (10-kg child) | 0.3 mg/L
EPA | DWEL | 0.2 mg/L
EPA | Lifetime health advisory | 0.04 mg/L
EPA | 10^−4^ Cancer risk | 0.009 mg/L
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.001 mg/L
EPA | PHG | 0 mg/L
EPA | RfD | 0.005 mg/kg/day | IRIS 2010
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Provisional guideline value | 0.009 mg/L^a,b^
FDA | Substances Added to Food | No data^c^ | FDA 2021a
FDA | Allowable level in bottled water | 0.001 mg/L | FDA 2021b
FDA | Indirect additives used in food contact substances
FDA | Pentachlorophenol | Permitted under adhesives regulation and wood preservatives regulation with limitation | FDA 2021c
FDA | Sodium pentachlorophenate | Permitted under multiple indirect additives regulations, some with limitation | FDA 2021d
Cancer
HHS | Carcinogenicity classification | | NTP 2016
HHS | Pentachlorophenol and byproducts of its synthesis | Reasonably anticipated to be a human carcinogen
EPA | Carcinogenicity classification | Likely to be carcinogenic to humans | IRIS 2010
EPA | Oral slope factor | 4×10^−1^ per mg/kg/day
IARC | Carcinogenicity classification | Group 1^d^ | IARC 2019
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | 0.5 mg/m^3e^ | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA) | 0.5 mg/m^3e^ | NIOSH 2019
NIOSH | IDLH | 0.25 mg/m^3^ | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | Pentachlorophenol
DOE | PAC-1^f^ | 1 mg/m^3^
DOE | PAC-2^f^ | 15 mg/m^3^
DOE | PAC-3^f^ | 150 mg/m^3^
DOE | Sodium pentachlorophenate
DOE | PAC-1^f^ | 0.22 mg/m^3^
DOE | PAC-2^f^ | 2.4 mg/m^3^
DOE | PAC-3^f^ | 8.4 mg/m^3^

a Concentration in drinking-water associated with an upperbound excess lifetime cancer risk of 10^−5^ (one additional case of cancer per 100,000 of the population ingesting drinking water containing the substance at the guideline value for 70 years).

b Value is considered provisional because of variations in metabolism between experimental animals and humans.

c The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

d Group 1: carcinogenic to humans.

e Skin designation.

f Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; LOAEL = lowest observed adverse effect level;

MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; PHG = public health goal; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization