# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of pentachlorophenol is located in Table 4-1. A number of contaminants are found in commercial- and technical-grade pentachlorophenol formulations. Commonly found contaminants that were introduced during production include other chlorophenols, CDDs, CDFs, hexachlorobenzene, and chlorophenoxy compounds. Pure pentachlorophenol compounds are typically ≥98% pure with very low levels of CDDs and CDFs. Commercial-grade pentachlorophenol is typically 90% pentachlorophenol, and technical-grade pentachlorophenol formulations typically contains 85–90% pentachlorophenol. A list of contaminants in technical-grade pentachlorophenol and two commercial-grade pentachlorophenol products (Dowicide EC-7 and DP-2) are presented in Table 2-1.

Table 4-1 Chemical Identity of Pentachlorophenol

Characteristic | Pentachlorophenol | Sodium pentachlorophenate
Synonym(s) and registered trade name(s) | PCP; penchlorol; penta; pentachlorophenate; 2,3,4,5,6-pentachlorophenol^b^ | Pentachlorophenol sodium; pentachlorophenol sodium salt: pentachlorophenoxy sodium: pentaphenate
For 37% aqueous solution | Chlon; Dowicide 7; Dowicide EC-7; Dura Treet II; EP 30; Fungifen^a^ | Dow Dormant Fungicide; Dowicide G; Dowicide
For polymeric form | Grundier Arbezol; Lauxtol; Liroprem; Penta Concentrate; Penta Ready; Penta WR; Permasan; Santophen 20; Woodtreat^b^ | G-St; Mystox D; Napclor-G; Santobrite; Sapco25 Weedbeads
Chemical formula | C_6_HCl_5_O | C_6_Cl_5_ONa
Chemical structure | [image] | [image]
CAS Registry Number | 87-86-5 | 131-52-2

a All information obtained from HSDB 2001, except where noted.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of pentachlorophenol is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of Pentachlorophenol

Property | Pentachlorophenol | Sodium pentachlorophenate
Molecular weight | 266.34 | 288.34
Color | Colorless or white (pure); dark gray to brown (crude product) | White or tan
Physical state | Crystalline solid (pure); pellets or powder (crude product)^b^ | Flakes or powder
Melting point | 174°C | No data
Boiling point | 309–310°C (decomposes) | No data
Density | 1.978 g/mL at 22°C/4°C | 2.0 mg/L at 22°C/4°C
Odor | Phenolic; very pungent (only when hot) | Phenolic odor
Odor threshold:
Water | 0.857 mg/L at 30°C; 12.0 mg/L at 60°C^b,c^ | No data
Air | No data | No data
Solubility:
Water | 14 mg/L at 20°C | 330,000 mg/L at 25°C
Organic solvents | Very soluble in alcohol and ether; soluble in benzene; slightly soluble in cold petroleum ether^d^ | Soluble in acetone and ethanol
Partition coefficients:
Log K_ow_ | 5.01^b^ | No data
Log K_oc_ | 4.5^e^ | No data
Vapor pressure at 20°C | 0.00011 mmHg^f^ | Not applicable
Dissociation constant (pKa) | 4.70 | Not applicable
Henry’s law constant at 22°C | 2.45×10^−8^ atm-m^3^/mol | Not applicable

a All information obtained from NLM (2021) unless otherwise noted.

b Verschueren 1983.

c Hoak 1957.

d Budavari et al. 1989.

e Schellenberg et al. 1984.

f EPA 1979.

g Lyman et al. 1982.