# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR PENTACHLOROPHENOL

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to pentachlorophenol, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to pentachlorophenol:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to pentachlorophenol. The inclusion criteria used to identify relevant studies examining the health effects of pentachlorophenol are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; Human; Laboratory mammals
Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data)
Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of pentachlorophenol. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for pentachlorophenol released for public comment in 2021. See Appendix B for the databases searched and the search strategy.

A total of 3,182 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of pentachlorophenol.

Title and Abstract Screen. In the Title and Abstract Screen step, 487 records were reviewed; 4 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 89 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 89 documents, 117 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted from Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for pentachlorophenol and overviews of the results of the oral exposure studies (no inhalation or dermal exposure laboratory animal studies were identified) are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures table in Section 2.1 of the profile (Error! Reference source not found.).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for pentachlorophenol identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The available human studies examined a range of effects; these studies and case reports have reported respiratory, cardiovascular, gastrointestinal, hematological, hepatic, renal, dermal, ocular, endocrine, immunological, neurological, reproductive, and developmental effects. Animal studies examined a number of endpoints following inhalation, oral, or dermal exposure; the inhalation and dermal studies were limited to an examination of lethality. The oral exposure studies examined most endpoints and reported body weight, gastrointestinal, hematological, hepatic, renal, endocrine, immunological, reproductive, developmental, and other noncancer effects.

Some of these findings were attributed to the contaminants present in technical-grade pentachlorophenol. Of the consistently observed effects attributed to pentachlorophenol, hepatic and developmental effects were considered sensitive outcomes (i.e., effects were observed at low concentrations or doses). Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were 117 studies (published in 89 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Pentachlorophenol Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | 1 | 3 | 0 | 0 | 1 | 0 | 4 | 0 | 5 | 1 | 0 | 2 | 3 | 0 | 0 | 1 | 4
Cohort | 1 | 3 | 0 | 0 | 1 | 0 | 4 | 0 | 5 | 1 | 0 | 2 | 2 | 0 | 0 | 1 | 4
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 8
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 6
Cross sectional | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 2 | 1 | 2 | 0 | 0 | 0
Cross sectional | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 2 | 1 | 1 | 0 | 0 | 0
Case report | 0 | 0 | 0 | 0 | 5 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0
Case report | 0 | 0 | 0 | 0 | 5 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0
Oral studies
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 4 | 0 | 0
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0
Case control | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0
Case report | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Case report | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
Dermal studies
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Cohort | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Case report | 0 | 1 | 0 | 0 | 0 | 0 | 4 | 4 | 2 | 0 | 0 | 1 | 3 | 0 | 0 | 0 | 0
Case report | 0 | 1 | 0 | 0 | 0 | 0 | 4 | 4 | 2 | 0 | 0 | 1 | 3 | 0 | 0 | 0 | 0

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

Table C-4 Overview of the Health Outcomes for Pentachlorophenol Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration
Intermediate-duration
Chronic-duration
Acute-duration | 9 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 7 | 0 | 0 | 8 | 0 | 0
Acute-duration | 6 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 3 | 0 | 0 | 7 | 0 | 0
Intermediate-duration | 16 | 8 | 8 | 7 | 6 | 5 | 15 | 9 | 0 | 0 | 9 | 10 | 2 | 6 | 4 | 3 | 4
Intermediate-duration | 8 | 1 | 0 | 0 | 1 | 0 | 15 | 1 | 0 | 0 | 0 | 7 | 0 | 2 | 4 | 3 | 4
Chronic-duration | 7 | 5 | 5 | 5 | 3 | 4 | 6 | 6 | 0 | 1 | 6 | 0 | 1 | 2 | 0 | 2 | 5
Chronic-duration | 6 | 1 | 0 | 1 | 2 | 0 | 6 | 1 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | 2 | 3
Dermal studies
Acute-duration
Intermediate-duration | | | | | | | | | | | | | | | | | 1
Intermediate-duration | | | | | | | | | | | | | | | | | 1
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (-)
- Definitely high risk of bias (– –)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of pentachlorophenol health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-8 and C-9, respectively.

Table C-8 Summary of Risk of Bias Assessment for Pentachlorophenol—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Comparison groups appropriate? | Study design or analysis account for important confounding and modifying variables?^*^ | Outcome data complete without attrition or exclusion from analysis? | Confidence in the exposure characterization?^*^ | Confidence in the outcome assessment?^*^ | All measured outcomes reported? | Risk of bias tier
Outcome: Hepatic Effects
Cohort
Cheng et al. 1993 | + | – | + | – | – | + | Second
Colosio et al. 1993b | + | – | + | + | + | + | Second
Hryhorczuk et al. 1998 | + | – | + | – | – | + | Second
Klemmer et al. 1980 | + | – | + | + | + | + | Second
Case Reports
Armstrong et al. 1969 | NA | – | NA | – | + | + | Second
Bergner et al. 1965 | NA | – | NA | – | – | – | Third
Gordon 1956 | NA | – | NA | – | + | + | Third
Robson et al. 1969 | NA | – | NA | – | – | + | Third
Smith et al. 1996 | NA | – | NA | – | – | – | Third
Outcome: Developmental Effects
Cohort
Berghuis et al. 2018 | + | – | + | + | + | + | Second
Meijer et al. 2008 | + | – | + | + | + | + | Second
Roze et al. 2009 | + | – | + | + | + | + | Second
Ruel et al. 2019 | + | – | + | + | + | + | Second
Case-Control
Chen et al. 2013b | + | – | + | + | + | + | Second
Dimich-Ward et al. 1996 | – | – | + | – | + | + | Second

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

a Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Pentachlorophenol—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Administered dose or exposure level adequately randomized? | Allocation to study groups adequately concealed? | Experimental conditions identical across study groups? | Research personnel blinded to the study group during the study? | Outcome data complete without attrition or exclusion from analysis? | Confidence in the exposure characterization? | Confidence in the outcome assessment?^*^ | All measured outcomes reported? | Risk of bias tier
Outcome: Hepatic Effects
Oral acute exposure
Umemura et al. 1996 | – | + | + | + | + | + | + | + | First
Bekhouche et al. 2019 | + | + | + | + | + | – | + | + | First
Oral intermediate exposure
Bernard et al. 2002 | ++ | + | + | + | + | ++ | + | ++ | First
Kerkvliet et al. 1982 (technical) | – | + | + | + | + | – – | + | ++ | First
Kerkvliet et al. 1982 (pure) | – | + | + | + | + | – – | + | ++ | First
Kimbrough and Linder 1978 (technical) | + | + | + | + | + | + | + | ++ | First
Kimbrough and Linder 1978 (pure) | + | + | + | + | + | + | + | ++ | First
Knudsen et al. 1974 | – | + | + | + | + | – – | + | ++ | First
NTP 1989 (technical, 30 days) | – | + | + | + | + | + | + | ++ | First
NTP 1989 (EC-7, 30 days) | – | + | + | + | + | + | + | ++ | First
NTP 1989 (pure, 30 days) | – | + | + | + | + | + | + | ++ | First
NTP 1989 (technical, 6 months) | + | + | + | + | + | + | + | ++ | First
NTP 1989 (EC-7, 6 months) | + | + | + | + | + | + | + | ++ | First
NTP 1989 (DP-2, 6 months) | + | + | + | + | + | + | + | ++ | First
NTP 1989 (pure, 6 months) | + | + | + | + | + | + | + | ++ | First
NTP 1999 | ++ | + | + | + | + | ++ | ++ | ++ | First
Umemura et al. 1996 | – | + | + | + | + | + | + | + | First
Umemura et al. 2006 | – | + | + | + | + | – – | + | ++ | First
Oral chronic exposure
EPA 1997 | + | + | + | + | + | + | + | ++ | First
NTP 1999 (2 years) | ++ | + | + | + | + | ++ | ++ | ++ | First
NTP 1999 (1 year) | ++ | + | + | + | + | ++ | ++ | ++ | First
Schwetz et al. 1978 | + | + | + | + | + | ++ | + | + | First
NTP 1989 (technical) | – | + | + | + | + | ++ | ++ | ++ | First
NTP 1989 (pure) | – | + | + | + | + | ++ | ++ | ++ | First
Outcome: Developmental Effects
Oral acute studies
Bernard and Hoberman 2001 | ++ | + | + | + | + | ++ | + | ++ | First
Schwetz et al. 1974 (pure, GDs 6–15) | – | + | + | + | + | + | + | + | First
Schwetz et al. 1974 (pure, GDs 8–11) | – | + | + | + | + | + | + | + | First
Schwetz et al. 1974 (technical, GDs 12–15) | – | + | + | + | + | + | + | + | First
Schwetz et al. 1974 (technical, GDs 6–15) | – | + | + | + | + | + | + | + | First
Schwetz et al. 1974 (technical, GDs 8–11) | – | + | + | + | + | + | + | + | First
Schwetz et al. 1974 (technical, GDs 12–15) | – | + | + | + | + | + | + | + | First
Bernard et al. 2001 | ++ | + | + | + | + | ++ | + | ++ | First
Oral intermediate exposure
Bernard et al. 2002 | ++ | + | + | + | + | ++ | + | ++ | First
Exon and Koller 1982 | – | + | + | + | + | – – | + | ++ | First
Schwetz et al. 1978 | + | + | + | + | + | ++ | + | ++ | First
Welsh et al. 1987 | – | + | + | + | + | ++ | + | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

a Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including DHHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to pentachlorophenol and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to pentachlorophenol and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions in Distiller, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining hepatic effects and developmental effects observed in the observational epidemiology and animal experimental studies are presented in Tables C-13 and C-14, respectively.

Table C-13 Presence of Key Features of Study Design for Pentachlorophenol—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Hepatic Effects
Cohort
Cheng et al. 1993 | No | No | Yes | Yes | Low
Colosio et al. 1993b | No | No | Yes | Yes | Low
Hryhorczuk et al. 1998 | No | No | Yes | Yes | Low
Klemmer et al. 1980 | No | No | Yes | Yes | Low
Case Reports
Armstrong et al. 1969 | No | Yes | No | No | Very low
Bergner et al. 1965 | No | No | Yes | No | Very low
Gordon 1956 | No | No | Yes | No | Very low
Robson et al. 1969 | No | No | Yes | No | Very low
Smith et al. 1996 | No | No | No | No | Very low
Outcome: Developmental Effects
Cohort
Berghuis et al. 2018 | No | Yes | Yes | Yes | Moderate
Meijer et al. 2008 | No | Yes | Yes | Yes | Moderate
Roze et al. 2009 | No | Yes | Yes | Yes | Moderate
Ruel et al. 2019 | No | Yes | Yes | Yes | Moderate
Case-Control
Chen et al. 2013b | No | No | Yes | Yes | Low
Dimich-Ward et al. 1996 | No | No | Yes | Yes | Low

Table C-14 Presence of Key Features of Study Design for Pentachlorophenol—Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Hepatic Effects
Oral acute exposure
Umemura et al. 1996 | Yes | Yes | Yes | No | Moderate
Bekhouche et al. 2019 | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Bernard et al. 2002 | Yes | Yes | Yes | Yes | High
Kerkvliet et al. 1982 (technical) | Yes | Yes | Yes | Yes | High
Kerkvliet et al. 1982 (pure) | Yes | Yes | Yes | Yes | High
Kimbrough and Linder 1978 (technical) | Yes | Yes | Yes | Yes | High
Kimbrough and Linder 1978 (pure) | Yes | Yes | Yes | Yes | High
Knudsen et al. 1974 | Yes | Yes | Yes | Yes | High
NTP 1989 (technical, 30 days) | Yes | Yes | Yes | No | Moderate
NTP 1989 (EC-7, 30 days) | Yes | Yes | Yes | No | Moderate
NTP 1989 (pure, 30 days) | Yes | Yes | Yes | No | Moderate
NTP 1989 (technical, 6 months) | Yes | Yes | Yes | Yes | High
NTP 1989 (EC-7, 6 months) | Yes | Yes | Yes | Yes | High
NTP 1989 (DP-2, 6 months) | Yes | Yes | Yes | Yes | High
NTP 1989 (pure, 6 months) | Yes | Yes | Yes | Yes | High
NTP 1999 | Yes | Yes | Yes | Yes | High
Umemura et al. 1996 | Yes | Yes | Yes | No | Moderate
Umemura et al. 2006 | Yes | Yes | No | Yes | Moderate
Oral chronic exposure
EPA 1997 | Yes | Yes | Yes | Yes | High
NTP 1999 (2 years) | Yes | Yes | Yes | Yes | High
NTP 1999 (1 year) | Yes | Yes | Yes | Yes | High
Schwetz et al. 1978 | Yes | Yes | Yes | Yes | High
NTP 1989 (technical) | Yes | Yes | Yes | Yes | High
NTP 1989 (pure) | Yes | Yes | Yes | Yes | High
Outcome: Developmental Effects
Oral acute studies
Bernard and Hoberman 2001 | Yes | Yes | Yes | Yes | High
Schwetz et al. 1974 (pure, GDs 6–15) | Yes | Yes | Yes | Yes | High
Schwetz et al. 1974 (pure, GDs 8–11) | Yes | Yes | Yes | Yes | High
Schwetz et al. 1974 (technical, GDs 12–15) | Yes | Yes | Yes | Yes | High
Schwetz et al. 1974 (technical, GDs 6–15) | Yes | Yes | Yes | Yes | High
Schwetz et al. 1974 (technical, GDs 8–11) | Yes | Yes | Yes | Yes | High
Schwetz et al. 1974 (technical, GDs 12–15) | Yes | Yes | Yes | Yes | High
Bernard et al. 2001 | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Bernard et al. 2002 | Yes | Yes | Yes | Yes | High
Exon and Koller 1982 | Yes | Yes | Yes | Yes | High
Schwetz et al. 1978 | Yes | Yes | Yes | Yes | High
Welsh et al. 1987 | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-15.

Table C-15 Initial Confidence Rating for Pentachlorophenol Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Hepatic Effects
Inhalation chronic exposure
Human studies
Cheng et al. 1993 | Low | Low
Colosio et al. 1993b | Low | Low
Hryhorczuk et al. 1998 | Low | Low
Klemmer et al. 1980 | Low | Low
Oral acute exposure
Animal studies
Umemura et al. 1996 | Moderate | Moderate
Bekhouche et al. 2019 | Moderate | Moderate
Oral intermediate exposure
Animal studies
Bernard et al. 2002 | High | High
Kerkvliet et al. 1982 (technical) | High | High
Kerkvliet et al. 1982 (pure) | High | High
Kimbrough and Linder 1978 (technical) | High | High
Kimbrough and Linder 1978 (pure) | High | High
Knudsen et al. 1974 | High | High
NTP 1989 (technical, 30 days) | Moderate | High
NTP 1989 (EC-7, 30 days) | Moderate | High
NTP 1989 (pure, 30 days) | Moderate | High
NTP 1989 (technical, 6 months) | High | High
NTP 1989 (EC-7, 6 months) | High | High
NTP 1989 (DP-2, 6 months) | High | High
NTP 1989 (pure, 6 months) | High | High
NTP 1999 | High | High
Umemura et al. 1996 | Moderate | High
Umemura et al. 2006 | Moderate | High
Chronic oral exposure
Animal studies
EPA 1997 | High | High
NTP 1999 (2 years) | High | High
NTP 1999 (1 year) | High | High
Schwetz et al. 1978 | High | High
NTP 1989 (technical) | High | High
NTP 1989 (pure) | High | High
Dermal acute exposure
Human studies
Armstrong et al. 1969 | Very low | Very low
Gordon 1956 | Very low | Very low
Robson et al. 1969 | Very low | Very low
Smith et al. 1996 | Very low | Very low
Dermal chronic exposure
Human studies
Bergner et al. 1965 | Very low | Very low
Outcome: Developmental effects
Chronic inhalation exposure
Human studies
Dimich-Ward et al. 1996 | Low | Low
Acute oral exposure
Animal studies
Bernard and Hoberman 2001 | High | High
Schwetz et al. 1974 (pure, GDs 6–15) | High | High
Schwetz et al. 1974 (pure, GDs 8–11) | High | High
Schwetz et al. 1974 (technical, GDs 12–15) | High | High
Schwetz et al. 1974 (technical, GDs 6–15) | High | High
Schwetz et al. 1974 (technical, GDs 8–11) | High | High
Schwetz et al. 1974 (technical, GDs 12–15) | High | High
Bernard et al. 2001 | High | High
Intermediate oral exposure
Animal studies
Bernard et al. 2001 | High | High
Exon and Koller 1982 | High | High
Schwetz et al. 1978 | High | High
Welsh et al. 1987 | High | High
Chronic oral exposure
Human studies
Berghuis et al. 2018 | Moderate | Moderate
Chen et al. 2013b | Low | Moderate
Meijer et al. 2008 | Moderate | Moderate
Roze et al. 2009 | Moderate | Moderate
Ruel et al. 2019 | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for hepatic effects and developmental effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with pentachlorophenol exposure is presented in Table C-17.

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Hepatic effects
Human studies | Low | −1 risk of bias | Very Low
Animal studies | High | | High
Outcome: Developmental effects
Human studies | Moderate | −1 risk of bias, −1 inconsistency | Very Low
Animal studies | High | +1 consistency | High

Table C-17 Confidence in the Body of Evidence for Pentachlorophenol

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Hepatic effects | Very Low | High
Developmental effects | Very Low | High

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8 and C-9). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for pentachlorophenol, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for pentachlorophenol is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Pentachlorophenol

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Hepatic effects | Very Low | Health effect | Inadequate evidence
Developmental effects | Very Low | Health effect | Inadequate evidence
Animal studies
Hepatic effects | High | Health effect | High evidence
Developmental effects | High | Health effect | High evidence

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1 description

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for pentachlorophenol are listed below and summarized in Table C-19.

Presumed Health Effects

- Hepatic effects
  ○ Inadequate evidence from cohort studies that evaluated porphyrin excretion (Cheng et al. 1993; Hryhorczuk et al. 1998), case reports of hepatic enlargement or centrilobular degeneration (Armstrong et al. 1969; Bergner et al. 1965; Gordon 1956; Robson et al. 1969; Smith et al. 1996), or cohort studies evaluating indirect evidence of liver damage (serum clinical chemistry) (Colosio et al. 1993b; Klemmer et al. 1980).
  ○ High level of evidence in mice following acute oral exposure (Umemura et al. 1996), rats (Bernard et al. 2002; Kimbrough and Linder 1978; Knudsen et al. 1974; NTP 1999) and mice (Kerkvliet et al. 1982; NTP 1989) following intermediate-duration oral exposure, and in rats (NTP 1999; Schwetz et al. 1978), mice (NTP 1989), and dogs (EPA 1997) following chronic oral exposure.
  ○ The hepatic effects observed in animals have been reported in animals exposed to pure pentachlorophenol and several types of technical-grade pentachlorophenol.
- Developmental effects
  ○ Inadequate evidence epidemiological studies. The results of cohort and case-control studies have been inconsistent, with some studies finding associations between maternal or paternal pentachlorophenol levels (Chen et al. 2013b; Dimich-Ward et al. 1996; Meijer et al. 2008; Roze et al. 2009) and others not finding associations (Berghuis et al. 2018; Meijer et al. 2008; Ruel et al. 2019). All of the epidemiological studies involved co-exposure to other developmental toxicants including PCBs, CDDss, and CDFs.
  ○ High level of evidence of increased resorptions in rats (Bernard and Hoberman 2001; Schwetz et al. 1974), decreases in litter size in rats (Exon and Koller 1982; Schwetz et al. 1978), skeletal anomalies in rats (Schwetz et al. 1974), and decreases in fetal/pup body weight in rats (Bernard and Hoberman 2001; Bernard et al. 2002; Schwetz et al. 1978; Welsh et al. 1987) following oral exposure to pure pentachlorophenol or technical-grade pentachlorophenol.

Table C-19 Hazard Identification Conclusions for Pentachlorophenol

Outcome | Hazard identification
Hepatic effects | Presumed health effect
Developmental effects | Presumed health effect