# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR PENTACHLOROPHENOL

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to pentachlorophenol.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for pentachlorophenol. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of pentachlorophenol have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of pentachlorophenol are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for pentachlorophenol released for public comment in 2021; thus, the literature search was restricted to studies published between January 2018 and November 2021. The following main databases were searched in November 2021:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for pentachlorophenol. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to pentachloro-phenol were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
11/2021 | ((“Pentachlorophenol”[mh] OR 87-86-5[rn] OR 131-52-2[rn] OR “pentachlorophenate”[tw] OR “pentachlorophenolate”[tw] OR “(pentachlorophenoxy)-Sodium”[tw] OR “Na-pentachlorophenate”[tw] OR “PCP sodium salt”[tw] OR “PCP-Na”[tw] OR “PCP-Sodium”[tw] OR “Pentachlorophenate sodium”[tw] OR “Pentachlorophenate-Na”[tw] OR “Pentachlorophenol sodium salt”[tw] OR “Pentachlorophenol, sodium salt”[tw] OR “Pentachlorophenoxy sodium”[tw] OR “Pentachlorphenol sodium salt”[tw] OR “Pentaphenate”[tw] OR “Phenol, 2,3,4,5,6-pentachloro-, sodium salt”[tw] OR “Phenol, pentachloro-, sodium deriv.”[tw] OR “Phenol, pentachloro-, sodium salt”[tw] OR “PHENOL, PENTACHLORO-SODIUM SALT”[tw] OR “PHENOLATE, PENTACHLORO-, SODIUM”[tw] OR “Sodium PCP”[tw] OR “Sodium pentachloro-”[tw] OR “Sodium pentachloro-phenate”[tw] OR “Sodium pentachlorophenate”[tw] OR “Sodium pentachlorophenol”[tw] OR “Sodium pentachlorophenolate”[tw] OR “Sodium pentachlorophenoxide”[tw] OR “Sodium pentachlorophonate”[tw] OR “Sodium pentachlorphenate”[tw] OR “Sodium, (pentachlorophenoxy)-”[tw] OR “Dow dormant fungicide”[tw] OR “Dowicide G”[tw] OR “Dowicide G-ST”[tw] OR “GR 48-11PS”[tw] OR “GR 48-32S”[tw] OR “Mystox D”[tw] OR “Napclor-G”[tw] OR “NAPCP”[tw] OR “Pentanot 25”[tw] OR “Pkhfn”[tw] OR “Preventol PN”[tw] OR “Sapco 25”[tw] OR “Sodium pentach”[tw] OR “Weedbeads”[tw] OR “Witophen N”[tw] OR “1-Hydroxy-2,3,4,5,6-pentachlorobenzene”[tw] OR “1-Hydroxypentachlorobenzene”[tw] OR “2,3,4,5,6-Pentachlorophenate”[tw] OR “2,3,4,5,6-Pentachlorophenol”[tw] OR “Chlorophenasic acid”[tw] OR “CHLOROPHENATE”[tw] OR “PCP (pesticide)”[tw] OR “pentachloro-Phenol”[tw] OR “Pentachlorofenol”[tw] OR “Pentachlorophenate”[tw] OR “Pentachlorophenol”[tw] OR “Pentachlorophenols”[tw] OR “pentaclorofenol”[tw] OR “Pentrachlorophenol”[tw] OR “Perchlorophenol”[tw] OR “Phenol, 2,3,4,5,6-pentachloro-”[tw] OR “Phenol, pentachloro-”[tw] OR “AD 73”[tw] OR “CM 613”[tw] OR “CP 1309”[tw] OR “D037”[tw] OR “EP 30”[tw] OR “MB 333”[tw] OR “Chem-Penta”[tw] OR “Chem-Tol”[tw] OR “Chlon”[tw] OR “Chlorophen”[tw] OR “Dowicide 7”[tw] OR “Dowicide EC 7”[tw] OR “Dowicide EC-7”[tw] OR “Dura Treet II”[tw] OR “Durotox”[tw] OR “Forpen-50 Wood Preservative”[tw] OR “Fungifen”[tw] OR “Glazd penta”[tw] OR “Grundier Arbezol”[tw] OR “Lauxtol”[tw] OR “Liroprem”[tw] OR “Ontrack WE Herbicide”[tw] OR “Ortho Triox Liquid Vegetation Killer”[tw] OR “Osmose Wood Preserving Compound”[tw] OR “Penchlorol”[tw] OR “Penta Concentrate”[tw] OR “Penta ready”[tw] OR “Penta WR”[tw] OR “Penta-kil”[tw] OR “Pentacon”[tw] OR “Penton 70”[tw] OR “Pentor 70”[tw] OR “Penwar”[tw] OR “Peratox”[tw] OR “Permacide”[tw] OR “Permagard”[tw] OR “Permasan”[tw] OR “Permatox DP-2”[tw] OR “Permatox penta”[tw] OR “Permite”[tw] OR “PKhF”[tw] OR “Pol Nu”[tw] OR “Pole topper”[tw] OR “Preventol P”[tw] OR “Santobrite”[tw] OR “Santophen”[tw] OR “Satophen”[tw] OR “Sinituho”[tw] OR “Term-i-trol”[tw] OR “Thompson’s wood fix”[tw] OR “Watershed Wood Preservative”[tw] OR “Weed and Brush Killer”[tw] OR “Weedone”[tw] OR “Witophen P”[tw] OR “Woodtreat A”[tw] OR (“pcp”[tw] AND (chlorophenol* OR phenols OR pesticide* OR insecticide* OR herbicide* OR wood preservative))) AND (2018/01/01:3000[dp] OR 2019/01/01:3000[mhda] OR 2019/01/01:3000[crdat] OR 2019/01/01:3000[edat])) OR (“pentachlorphenol”[tw] AND 1999:3000[dp])
NTRL
11/2021 | Hydroxypentachlorobenzene OR Pentachlorophenate OR Pentachlorophenol OR CHLOROPHENATE OR pentachlorophenolate OR Perchlorophenol OR pentachlorophenoxide OR pentachlorphenol
Toxcenter
11/2021 | FILE ‘TOXCENTER’ ENTERED AT 18:38:46 ON 03 NOV 2021; CHARGED TO COST=EH038.12.06.LB.04 DIS SAVED; L1 15609 SEA 87-86-5 OR 131-52-2; L2 14602 SEA L1 NOT PATENT/DT; L3 14536 SEA L2 NOT TSCATS/FS; ACT TOXQUERY/Q; -------; L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L22 QUE (ENDOCRIN? AND DISRUPT?); L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L29 QUE (NEPHROTOX? OR HEPATOTOX?); L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; L33 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L34 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L35 QUE L32 OR L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; -------; L41 503 SEA L3 AND ED>=20190101; L42 281 SEA L41 AND L37; L43 45 SEA L42 AND MEDLINE/FS; L44 236 SEA L42 NOT MEDLINE/FS; L45 234 DUP REM L43 L44 (47 DUPLICATES REMOVED) ANSWERS ‘1-234’ FROM FILE TOXCENTER; L*** DEL 45 S L42 AND MEDLINE/FS; L*** DEL 45 S L42 AND MEDLINE/FS; L46 45 SEA L45; L*** DEL 236 S L42 NOT MEDLINE/FS; L*** DEL 236 S L42 NOT MEDLINE/FS; L47 189 SEA L45; L48 189 SEA (L46 OR L47) NOT MEDLINE/FS D SCAN L48
TSCATS via ChemView
11/2021 | Compounds searched: 87-86-5; 131-52-2
NTP
11/2021 | 87-86-5; 131-52-2; “Pentachlorophenol” “Pentachlorophenate”
Regulations.gov
11/2021 | Dockets and Document tabs searched:; - 87-86-5; - 131-52-2; - Pentachlorophenol; - Pentachlorophenate
NIH RePORTER
12/2021 | Search Criteria:,; Text Search: “pentachlorophenate” OR “pentachlorophenolate” OR “(pentachlorophenoxy)-Sodium” OR “Na-pentachlorophenate” OR “PCP sodium salt” OR “PCP-Na” OR “PCP-Sodium” OR “Pentachlorophenate sodium” OR “Pentachlorophenate-Na” OR “Pentachlorophenol sodium salt” OR “Pentachlorophenol, sodium salt” OR “Pentachlorophenoxy sodium” OR “Pentachlorphenol sodium salt” OR “Pentaphenate” OR “Phenol, 2,3,4,5,6-pentachloro-, sodium salt” OR “Phenol, pentachloro-, sodium deriv.” OR “Phenol, pentachloro-, sodium salt” OR “PHENOL, PENTACHLORO-SODIUM SALT” OR “PHENOLATE, PENTACHLORO-, SODIUM” OR “Sodium PCP” OR “Sodium pentachloro-” OR “Sodium pentachloro- phenate” OR “Sodium pentachlorophenate” OR “Sodium pentachlorophenol” OR “Sodium pentachlorophenolate” OR “Sodium pentachlorophenoxide” OR “Sodium pentachlorophonate” OR “Sodium pentachlorphenate” OR “Sodium, (pentachlorophenoxy)-” OR “Dow dormant fungicide” OR “Dowicide G” OR “Dowicide G-ST” OR “GR 48-11PS” OR “GR 48-32S” OR “Mystox D” OR “Napclor-G” OR “NAPCP” OR “Pentanot 25” OR “Pkhfn” OR “Preventol PN” OR “Sapco 25” OR “Sodium pentach” OR “Weedbeads” OR “Witophen N” OR “1-Hydroxy-2,3,4,5,6-pentachlorobenzene” OR “1-Hydroxypentachlorobenzene” OR “2,3,4,5,6-Pentachlorophenate” OR “2,3,4,5,6-Pentachlorophenol” OR “Chlorophenasic acid” OR “CHLOROPHENATE” OR “PCP (pesticide)” OR “pentachloro-Phenol” OR “Pentachlorofenol” OR “Pentachlorophenate” OR “Pentachlorophenol” OR “Pentachlorophenols” OR “pentaclorofenol” OR “Pentrachlorophenol” OR “Perchlorophenol” OR “Phenol, 2,3,4,5,6-pentachloro-” OR “Phenol, pentachloro-” OR “AD 73” OR “CM 613” OR “CP 1309” OR “D037” OR “EP 30” OR “MB 333” OR “Chem-Penta” OR “Chem-Tol” OR “Chlon” OR “Chlorophen” OR “Dowicide 7” OR “Dowicide EC 7” OR “Dowicide EC-7” OR “Dura Treet II” OR “Durotox” OR “Forpen-50 Wood Preservative” OR “Fungifen” OR “Glazd penta” OR “Grundier Arbezol” OR “Lauxtol” OR “Liroprem” OR “Ontrack WE Herbicide” OR “Ortho Triox Liquid Vegetation Killer” OR “Osmose Wood Preserving Compound” OR “Penchlorol” OR “Penta Concentrate” OR “Penta ready” OR “Penta WR” OR “Penta-kil” OR “Pentacon” OR “Penton 70” OR “Pentor 70” OR “Penwar” OR “Peratox” OR “Permacide” OR “Permagard” OR “Permasan” OR “Permatox DP-2” OR “Permatox penta” OR “Permite” OR “PKhF” OR “Pol Nu” OR “Pole topper” OR “Preventol P” OR “Santobrite” OR “Santophen” OR “Satophen” OR “Sinituho” OR “Term-i-trol” OR “Thompson’s wood fix” OR “Watershed Wood Preservative” OR “Weedone” OR “Witophen P” OR “pentachlorphenol” (advanced)

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
| Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2021 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 458
- Number of records identified from other strategies: 29
- Total number of records to undergo literature screening: 487

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on pentachlorophenol:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 487
- Number of studies considered relevant and moved to the next step: 77

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 77
- Number of studies cited in the previous draft of the toxicological profile: 391
- Total number of studies cited in the profile: 398

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 November 2021 Literature Search Results and Screen for Pentachlorophenol

Figure B-1 description