# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Pentachlorophenol
CAS Numbers: | 87-86-5
Date: | April 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: An acute-duration inhalation MRL was not derived for pentachlorophenol because the acute inhalation database is limited to case reports and a lethality study in rats.

Rationale for Not Deriving an MRL: There are several reports of adverse health outcomes in individuals acutely exposed to pentachlorophenol dust (Gray et al. 1985; Hassan et al. 1985; Rugman and Cosstick 1990). Reported health effects included death, signs of central nervous system toxicity and cerebral edema, intravascular hemolysis, and aplastic anemia. The reports do not include exposure information and therefore, were not considered an adequate basis for an MRL. A lethality study in rats (Hoben et al. 1976b) did not evaluate other potential targets of toxicity; the LC_50_ was 14 mg/m^3^.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Pentachlorophenol
CAS Numbers: | 87-86-5
Date: | April 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: An intermediate-duration inhalation MRL was not derived for pentachlorophenol because no human or laboratory animal studies were identified.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies in humans or laboratory animals were identified.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Pentachlorophenol
CAS Numbers: | 87-86-5
Date: | April 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: A chronic-duration inhalation MRL was not derived for pentachlorophenol because the chronic inhalation database is limited to epidemiological studies that provided limited, in any, exposure information and involved exposure to several other compounds.

Rationale for Not Deriving an MRL: A number of cohort studies (Baader and Bauer 1951; Cheng et al. 1993; Colosio et al. 1993b; Hryhorczuk et al. 1998; Klemmer et al. 1980; Ramlow et al. 1996; Ruder and Yiin 2011; Sehgal and Ghorpade 1983; Triebig et al. 1987; Walls et al. 1998), case-control studies (Dimich-Ward et al. 1996; Hardell and Eriksson 1999; Hardell et al. 1994, 1995; Kogevinas et al. 1995; Seidler et al. 1996), or cross-sectional studies (Daniel et al. 1995; EPA 1986b; Gerhard et al. 1991; McConnachie and Zahalsky 1991; Peper et al. 1999) and case reports (Gordon 1956; Lambert et al. 1986; Roberts 1963, 1981, 1983, 1990) have evaluated the chronic toxicity of inhaled pentachlorophenol among workers at manufacturing facilities, pesticide applicators, sawmill workers, people living in log homes, and the general population. These studies provided limited, if any, information on exposure levels. Although several adverse health effects have been reported (respiratory, hepatic, hematological, dermal, and developmental effects), it is difficult to determine if these effects are due to exposure to pentachlorophenol, pentachlorophenol contaminants, or other chemicals. None of the studies were considered adequate for MRL derivation. No chronic-duration inhalation studies in laboratory animals were identified.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Pentachlorophenol
CAS Numbers: | 87-86-5
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.005 mg/kg/day (5 μg/kg/day)
Critical Effect: | Increased incidence of delayed skull ossification (Developmental)
Reference: | Schwetz et al. 1974
Point of Departure: | 5 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 4
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.005 mg/kg/day (5 μg/kg/day) was derived for pentachlorophenol. The MRL is based on a LOAEL of 5 mg/kg/day for delayed skull ossification in the fetuses of rats administered via gavage pure pentachlorophenol on GDs 6–15 (Schwetz et al. 1974) and an uncertainty factor of 1,000 (10 for the use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: A small number of studies have evaluated the acute oral toxicity of pentachlorophenol; the focus of most of the studies was lethality or developmental toxicity. LD_50_ values of 50–230 mg/kg have been reported in rats and mice (Borzelleca et al. 1985; Deichmann et al. 1942; Renner et al. 1986; St. Omer and Gadusek 1987). At nonlethal doses, decreases in maternal body weight gain, developmental effects (resorptions, decreases in fetal body weight, and soft tissue and skeletal anomalies), and liver effects (increases in liver weight and hepatocellular swelling) have been reported in experimental animals. A summary of the NOAEL and LOAEL values for these effects is presented in Table A-1.

In addition to the body weight, developmental, and liver effects, several studies have reported immunological effects, in particular a decreased response to sheep red blood cells (sRBC) (Holsapple et al. 1987; Kerkvliet et al. 1985a) or inhibition of complement activity (White and Anderson 1985), in mice exposed to technical-grade pentachlorophenol. These effects were not observed in mice similarly exposed to pure pentachlorophenol, suggesting that the effects were likely due to contaminants rather than pentachlorophenol. It is noted that one study did find an immune response (decreases in OVA-specific antibodies) in mice exposed to 6 mg/kg/day pure pentachlorophenol administered 3 times/week for 7 or 14 days (Chen et al. 2013a). Given that the other immunotoxicity studies testing pure pentachlorophenol or commercial-grade pentachlorophenol (Holsapple et al. 1987; Kerkvliet et al. 1985a; NTP 1989) did not find adverse effects at doses as high as 100 mg/kg/day, additional studies are needed to evaluate whether immunotoxicity is a sensitive target of pure pentachlorophenol.

The available data suggest that developmental toxicity is the most sensitive target following acute-duration oral exposure to pentachlorophenol. Skeletal and soft tissue anomalies occurred at doses that did not result in maternal toxicity. More severe developmental effects, including ≥97% fetal resorption, occurred at doses associated with a marked decrease in maternal body weight gain (74% decrease) (Schwetz et al. 1974). The LOAEL values for the maternal and developmental effects in rats exposed to pure pentachlorophenol and technical-grade pentachlorophenol are similar, suggesting that these effects are due to pentachlorophenol exposure rather than a contaminant.

Table A-1 Summary of NOAELs and LOAELs Following Acute-Duration Oral Exposure to Pentachlorophenol

Species, duration, (route) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference | Purity
Rat; GDs 6–15 (GO) | | 5 | Delayed ossification of skull at 5 mg/kg/day | Schwetz et al. 1974 | Pure (>98%)
Rat; GDs 6–15 (GO) | | | Increased incidence of subcutaneous edema and skeletal anomalies at ≥15 mg/kg/day | Schwetz et al. 1974 | Pure (>98%)
Rat; GDs 6–15 (GO) | 15 | 30 (SLOAEL) | Increased incidence of fetal resorptions (97% of fetuses resorbed) and marked decrease in fetal body weights and decreased maternal body weight (74%) on GDs 6–21 | Schwetz et al. 1974 | Pure (>98%)
Rat; GDs 8–11 (GO) | | 30 (SLOAEL) | Increased resorptions, increased incidence of skeletal and soft tissue anomalies; 42% decrease in fetal body weight | Schwetz et al. 1974 | Pure (>98%)
Rat; GDs 8–11 (GO) | | 30 (SLOAEL) | Decreased maternal body weight (67%) on GDs 6–21 | Schwetz et al. 1974 | Pure (>98%)
Rat; GDs 12–15 (GO) | | 30 | Increased incidence of soft tissue and skeletal anomalies and decreased fetal body weight and crown-rump length | Schwetz et al. 1974 | Pure (>98%)
Mouse; 2 weeks (F) | | 41 | Increased liver weight and severe hepatocellular swelling | Umemura et al. 1996 | Pure (98.6%)
Rat; 2 weeks (GW) | | 20 | Increased serum ALT and AST, hepatocellular necrosis, binucleated and pyknotic hepatocytes, and dilation and congestion of the centrilobular vein and sinusoids | Bekhouche et al. 2019 | Methodological grade (purity not specified)
Rat; GDs 6–15 (GO) | 5 | 15 | Increased resorptions and increased incidence of subcutaneous edema and lumbar spurs | Schwetz et al. 1974 | Technical grade (88.4%)
Rat; GDs 6–15 (GO) | 15 | 30 | Decreased maternal body weight (25%) | Schwetz et al. 1974 | Technical grade (88.4%)
Rat; GDs 8–11 (GO) | | 30 (SLOAEL) | Increased resorptions, increased incidence of skeletal and soft tissue anomalies; 25% decrease in fetal body weight | Schwetz et al. 1974 | Technical grade (88.4%)
Rat; GDs 8–11 (GO) | | 30 | Decreased maternal body weight (27%) | Schwetz et al. 1974 | Technical grade (88.4%)
Rat; GDs 12–15 (GO) | | 30 | Increased incidence of sternebrae variations | Schwetz et al. 1974 | Technical grade (88.4%)
Rat; GDs 6–15 (GO) | 30 | 80 | Increased resorptions, decreased fetal body weight, increased incidence of soft tissue and skeletal anomalies | Bernard and Hoberman 2001 | Technical grade (89%)
Rat; GDs 6–15 (GO) | 30 | 80 | Decreased maternal body weight (21% lower than controls on GDs 6–16) | Bernard and Hoberman 2001 | Technical grade (89%)
Rabbit; GDs 6–18 (GO) | 30 | | No developmental effects | Bernard et al. 2001 | Technical grade (88–89%)

ALT = alanine aminotransferase; AST = aspartate aminotransferase; (F) = feed; (GO) = gavage in oil; GD = gestation day; (GW) = gavage in water; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; SLOAEL = serious lowest-observed-adverse-effect level

Selection of the Principal Study: A series of developmental toxicity studies conducted by Schwetz et al. (1974) evaluated the developmental toxicity of pure pentachlorophenol and technical-grade pentachlorophenol in rats exposed on GDs 6–15, 8–11, and 12–15. Bernard and Hoberman (2001) and Bernard et al. (2001) also evaluated the developmental toxicity of technical-grade pentachlorophenol in rats and rabbits, respectively. The Schwetz et al. (1974) study of pure pentachlorophenol administered on GDs 6–15 identified the lowest LOAEL of 5 mg/kg/day; see Table A-1 for a list of the LOAELs from the other developmental studies. This study was selected as the principal study.

Summary of the Principal Study:

Schwetz BA, Keeler PA, Gehring PJ. 1974. The effect of purified and commercial-grade pentachlorophenol on rat embryonal and fetal development. Toxicol Appl Pharmacol 28:151–161.4854776

Groups of 15–20 pregnant Sprague Dawley rats were administered 5, 15, 30, or 50 mg/kg/day pure pentachlorophenol (>98 % purity) in corn oil on GDs 6–15; a vehicle-only control group of 33 rats was similarly exposed. A dose-related decrease in maternal body weight gain was observed at 30 and 50 mg/kg/day. Weight gain on GDs 6–21 was 74% less in both affected groups, as compared to controls. No other signs of maternal toxicity were observed. A significant increase (p<0.05) in the incidence of fetal resorptions was observed at 30 and 50 mg/kg/day; 97 and 100% of the fetuses were resorbed, respectively. The sex ratio (male:female) of surviving offspring was markedly altered from normal in the 30 mg/kg/day dose groups, with majority of the survivors being male offspring (83:17 versus 50:50 in controls); however, this is based on a very small number of surviving fetuses. Decreases in fetal body weight and crown-rump length were observed at 30 mg/kg/day. A significant increase in delayed ossification of the skull was observed at 5 mg/kg/day. At 15 mg/kg/day, significant increases in the incidences of soft tissue (subcutaneous edema) and skeletal anomalies were observed; the skeletal anomalies occurred in the skull (delayed ossification), ribs (supernumerary, lumbar or fused), lumbar spurs, sternebrae (supernumerary, abnormal shape, delayed ossification, missing or unfused centers of ossification), and vertebrae (supernumerary, delayed or unfused centers of ossification, fused or staggered). At 30 mg/kg/day, anomalies in the ribs, vertebrae, and sternebrae were also observed in the surviving fetuses.

Selection of the Point of Departure for the MRL: The LOAEL of 5 mg/kg/day was selected at the point of departure (POD).

Benchmark dose (BMD) modeling was conducted to identify a potential POD using the incidence data for litters with fetus having delayed ossification of the skull; the incidences (number of affected litter/total litters) were 6/33, 9/15, and 13/18 in the 0, 5, and 15 mg/kg/day groups, respectively; the data for the 30 mg/kg/day group was not modeled (0/12) due to the small number of surviving fetuses (n=6 fetuses). The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.2) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). None of the models provided adequate fit. Thus, a NOAEL/LOAEL approach was used to identify the POD for the MRL.

Uncertainty Factor:

- 10 for extrapolation from a LOAEL to a NOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = LOAEL ÷ UF = 5 mg / kg / day ÷ (10 × 10 × 10) = 0.005 mg / kg / day (5 μg / kg / day)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Skeletal anomalies have also been reported in the offspring of rats exposed to ≥15 mg/kg/day technical-grade pentachlorophenol (Schwetz et al. 1974) and 80 mg/kg/day technical-grade pentachlorophenol (Bernard and Hoberman 2001). Intermediate-duration oral developmental toxicity studies in rats have also reported increased fetal/neonatal mortality, malformations, and/or variations, and decreased growth (Bernard et al. 2002; Exon and Koller 1982; Schwetz et al. 1978; Welsh et al. 1987).

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Pentachlorophenol
CAS Numbers: | 87-86-5
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: An intermediate-duration oral MRL was not derived because an MRL based on the available intermediate-duration oral studies would result in an MRL that is higher than the acute-duration oral MRL.

Rationale for Not Deriving an MRL: The available intermediate-duration oral database supports identifying the liver and developing organisms as sensitive targets of toxicity. The NOAEL and LOAEL values for these endpoints are summarized in Table A-2. The liver effects include hepatocellular hypertrophy, hepatocellular degeneration, and necrosis. The developmental effects were primarily decreases in body weight, decreases in litter size, and decreases in neonatal survival. In addition to these effects, some studies have reported reproductive effects (decreases in testicular spermatid counts; Bernard et al. 2002), hematological alterations (decreases in hemoglobin and RBC levels; Knudsen et al. 1974), and alterations in immune function (Blakley et al. 1998; Kerkvliet et al. 1982, 1985a, 1985b; NTP 1989). The reproductive and hematological effects have only been observed in one study, and other studies have reported higher NOAEL values (see Table A-2 for a summary of the NOAEL and LOAEL values). The immunological effects appear to be related exposure to the contaminants in the technical-grade pentachlorophenol and have not been observed in animals exposed to pure pentachlorophenol.

The lowest LOAEL values for liver effects for the three formulation categories are 36 mg/kg/day (hepatocellular hypertrophy) observed in rats exposed to pure pentachlorophenol for 8 months (Kimbrough and Linder 1978), 50 mg/kg/day (hepatocytomegaly) in mice exposed to commercial-grade pentachlorophenol (EC-7 and DP-2) for 6 months (NTP 1989), and 1 mg/kg/day (centrilobular hepatocellular hypertrophy) in rats exposed to technical-grade pentachlorophenol for 8 months (Kimbrough and Linder 1978).

Comparison of the NOAEL and LOAEL values for hepatic effects for the 3 formulation categories identifies differences in relative hepatotoxicity. For pure pentachlorophenol, the lowest LOAEL was 36 mg/kg/day for hepatocellular hypertrophy in rats exposed for 8 months (Kimbrough and Linder 1978); the NOAEL was 6 mg/kg/day. At 67 mg/kg/day, necrosis was observed in female mice exposed for 6 months (NTP 1989). For commercial-grade pentachlorophenol, the lowest dose tested (50 mg/kg/day) resulted in necrosis in male mice exposed to EC-7 or DP-2 for 6 months (NTP 1989). The lowest LOAEL for technical-grade pentachlorophenol was 1 mg/kg/day for centrilobular hepatocellular hypertrophy in rats exposed for 8 months (Kimbrough and Linder 1978). These relative differences are highlighted in the Kimbrough and Linder (1978) study, which tested the same doses of pure and technical-grade pentachlorophenol. In rats exposed to pure pentachlorophenol, no hepatic alterations were observed at 1 or 6 mg/kg/day; at 36 mg/kg/day, centrilobular hepatocellular hypertrophy was observed. In contrast, exposure to technical-grade pentachlorophenol resulted in centrilobular hepatocellular hypertrophy at 1 mg/kg/day and marked vacuolization and periportal fibrosis at 7 and 32 mg/kg/day. Kimbrough and Linder (1978) suggested that the contaminants in the technical-grade pentachlorophenol may have been the causative agent for the low dose effects observed following intermediate-duration exposure.

Table A-2 Summary of NOAELs and LOAELs Following Intermediate-Duration Oral Exposure to Pentachlorophenol

Species, duration, (route) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference | Purity
Hepatic
Rat 8 months (F) | 6 | 36 | Centrilobular hepatocellular hypertrophy | Kimbrough and Linder 1978 | Pure (>99%)
Rat 28 days (F) | 20 | 40 | Increased liver weight, hepatocellular degeneration | NTP 1999 | Pure (99%)
Mouse 4 weeks (F) | | 41 | Increased liver weight and severe hepatocyte swelling | Umemura et al. 1996 | Pure (98.6%)
Mouse 6 months (F) | | 67 | Hepatocytomegaly, pigmentation, nuclear alterations, necrosis in males at ≥110 mg/kg/day and females at ≥67 mg/kg/day | NTP 1989 | Pure (98.6%)
Mouse 10-12 weeks (F) | | 90 | Necrosis | Kerkvliet et al. 1982 | Pure (>99%)
Mouse 6 months (F) | | 50 | Hepatocytomegaly, pigmentation, nuclear alterations, necrosis in males at 50 mg/kg/day and females at 70 mg/kg/day | NTP 1989 | EC-7 (90.4%)
Mouse 6 months (F) | | 50 | Hepatocytomegaly, pigmentation, nuclear alterations, necrosis in males at 50 mg/kg/day and females at 70 mg/kg/day | NTP 1989 | DP-2 (91.6%)
Rat 8 months (F) | | 1 | Centrilobular hepatocellular hypertrophy | Kimbrough and Linder 1978 | Technical grade (85%)
Rat 12 weeks (F) | 1.5 | 3 | Centrilobular vacuolization | Knudsen et al. 1974 | Technical grade (purity not reported)
Rat 112 days (GO) | | 10 | Increased liver weight and hepatocellular hypertrophy | Bernard et al. 2002 | Technical grade (89%)
Mouse 6 months (F) | | 50 | Hepatocytomegaly, pigmentation, nuclear alterations, necrosis in males at 50 mg/kg/day and females at 64 mg/kg/day | NTP 1989 | Technical grade (90.4%)
Mouse 10–12 weeks (F) | | 90 | Necrosis | Kerkvliet et al. 1982 | Technical grade (86%)
Developmental Effects
Rat 181 days premating, mating, through GD 20 (F) | 4 | 13 | Decreased fetal body weight and crown-rump length, increased skeletal variations, increased resorptions; fetal lethality at 43 mg/kg/day | Welsh et al. 1987 | Pure (>99%)
Rat 62 days premating, gestation, lactation (F) | 3 | 30 | Decreased litter size and neonatal survival, decreased body weight and growth | Schwetz et al. 1978 | EC-7 (90.4%)
Rat 70 days premating, gestation, lactation (GO) | | 10 | Decreased pup body weight on LD 1 and 4 in F1 pups | Bernard et al. 2002 | Technical grade (89%)
Rat 70 days premating, gestation, lactation (F) | | 50 | Decreased litter size | Exon and Koller 1982 | Technical grade (85%)
Hematological
Mouse 6 months (F) | 380 | | | NTP 1989 | Pure (98.6%)
Mouse 6 months (F) | 330 | | | NTP 1989 | EC-7 (90.4%)
Mouse 6 months (F) | 380 | | | NTP 1989 | DP-2 (91.6%)
Rat 12 weeks (F) | 1.5 | 3 | Decreases in hemoglobin and RBC levels in males | Knudsen et al. 1974 | Technical grade (purity not reported)
Rat 70 days premating, gestation, lactation (F) | 50 | | | Exon and Koller 1982 | Technical grade (85%)
Mouse 6 months (F) | 550 | | | NTP 1989 | Technical grade (90.4%)
Reproductive Effects
Rat 8 months (F) | 32M | | | Kimbrough and Linder 1978 | Pure (>99%)
Mouse 6 months (F) | 380 | | | NTP 1989 | Pure (98.6%)
Mouse 6 months (F) | 330 | | | NTP 1989 | EC-7 (90.4%)
Mouse 6 months (F) | 380 | | | NTP 1989 | DP-2 (91.6%)
Rat 70 days premating, gestation, lactation (GO) | 60F | 10 | | Bernard et al. 2002 | Technical grade (89%)
Rat 70 days premating, gestation, lactation (GO) | 10M | 30M | Decreased average testicular spermatid counts in F1 males; decreased fertility at 60 mg/kg/day | Bernard et al. 2002 | Technical grade (89%)
Rat 8 months (F) | 32M | | | Kimbrough and Linder 1978 | Technical grade (85%)
Rat 12 weeks (F) | 12M | | | Knudsen et al. 1974 | Technical grade (purity not reported)
Mouse 6 months (F) | 550 | | | NTP 1989 | Technical grade (90.4%)

(F) = feed; (GO) = gavage in oil; GD = gestation day; LD = lactation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; RBC = red blood cell

The lowest LOAEL for developmental effects was 13 mg/kg/day for decreases in fetal body weight and crown-rump length, increased skeletal variations, and increased resorptions in the offspring of rats exposed to pure pentachlorophenol (Welsh et al. 1987). No significant alteration in maternal body weight were observed at this dose level. Similar developmental effects and LOAEL values were observed in animals exposed to pure pentachlorophenol, technical-grade pentachlorophenol, and EC-7, suggesting that the pentachlorophenol was the causative agent for the developmental effects.

A comparison of the LOAEL values for hepatic effects (36 mg/kg/day) and developmental effects (13 mg/kg/day) in animals exposed to pure pentachlorophenol suggests that developmental toxicity may be a more sensitive target than hepatic effects and was selected as the critical effect. The Welsh et al. (1987) study of pure pentachlorophenol and the Bernard et al. (2002) study of technical-grade pentachlorophenol identified similar LOAEL values (13 and 10 mg/kg/day, respectively). The Welsh et al. (1987) study was selected as the principal study since it tested pure pentachlorophenol.

To identify potential PODs, BMD modeling was considered for the four developmental effects observed in the Welsh et al. (1987) study. The data for fetal body weight and crown-rump length were not amenable to modeling because the investigators did not include the standard errors of the mean. Thus, the NOAEL of 4 mg/kg/day was identified as the potential point of departure for these effects.

BMD modeling was conducted to identify potential points of departure using the incidence data listed in Table A-3 for litters with two or more resorptions and litters with fetuses having two or more skeletal variations. The data were fit to all available dichotomous models in EPA’s BMDS (version 3.1.2) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the point of departure when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. Since the endpoints were developmental toxicity, a BMR of 5% was used.

Table A-3 Incidences of Resorptions and Skeletal Variations in the Fetuses of Rats Exposed to Pentachlorophenol in the Diet

Dose (mg/kg/day) | Litters with two or more resorptions | Litters with two or more skeletal variations
0 | 13/31 | 12/28
4 | 5/11 | 1/10
13 | 13/16 | 12/16
43 | 17/17 | Not evaluated due to small number of surviving fetuses

Source: Welsh et al. 1987

At least one BMD model provided adequate fit for these endpoints. For fetal resorptions, the logistic and probit models provided adequate fit and estimated similar BMD and BMDL values; results are presented in Table A-4. The probit model was selected because it had a slightly higher AIC; the probit modeling results are presented in Figure A-1. The results of the BMD modeling for skeletal variations are presented in Table A-5. The BMDLs for the models providing adequate fit were sufficiently close; the log-logistic model was selected as it had the highest AIC. This model estimated a BMDL of 0.85 mg/kg/day; the model predictions are presented in Figure A-2.

Table A-4 Model Predictions for Litters with Two or More Resorptions of the Offspring of Rats Exposed to Pure Pentachlorophenol (Welsh et al. 1987)

Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_5_ (mg/kg/day) | BMDL_5_ (mg/kg/day)
Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_5_ (mg/kg/day) | BMDL_5_ (mg/kg/day)
Dichotomous Hill | −1 | | | −0.00 | −0.00 | −0.00 | 38.60 | ND-1 | ND-1
Gamma^c^ | 0 | 0.00 | NA | −0.00 | −0.00 | −0.00 | 36.60 | ND-2 | ND-2
LogLogistic^d^ | 0 | 0.00 | NA | −0.00 | −0.00 | −0.00 | 30.49 | ND-2 | ND-2
Multistage (1-degree)^e^ | 1 | 0.09 | 0.76 | 0.06 | 0.60 | 0.06 | 34.75 | ND-1 | ND-1
Multistage (2-degree)^e^ | 0 | 0.00 | NA | −0.00 | −0.00 | −0.00 | 36.60 | ND-2 | ND-2
Weibull^c^ | 0 | 0.00 | NA | −0.00 | −0.00 | −0.00 | 36.60 | ND-2 | ND-2
Logistic | 1 | 0.02 | 0.90 | 0.03 | 0.03 | 0.03 | 34.63 | 0.92 | 0.58
LogProbit^d^ | 0 | 0.00 | NA | −0.00 | −0.00 | −0.00 | 36.60 | ND-2 | ND-2
Probit ^f^ | 1 | 0.00 | 0.99 | 0.00 | 0.00 | −0.00 | 34.60 | 0.91 | 0.61

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk); DF = degrees of freedom; ND-1 = not determined; BMDL 10 times lower than lowest non-zero dose; ND-2 = not determined, goodness-of-fit test could not be calculated

Figure A-1 Fit of Probit Model to Data on Litters with Two or More Resorptions In Rats Exposed to Pentachlorophenol

Figure A-1 description

Table A-5 Model Predictions for Litters with Two or More Skeletal Variations in the Offspring of Rats Exposed to Pure Pentachlorophenol (Welsh et al. 1987)

Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_5_ (mg/kg/day) | BMDL_5_ (mg/kg/day)
Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_5_ (mg/kg/day) | BMDL_5_ (mg/kg/day)
Dichotomous Hill | −2 | 0.00 | 65535 | 0.00 | 0.00 | 0.00 | 32.50 | 3.73 | 0.85
Gamma^c^ | −1 | 0.00 | 65535 | 0.00 | 0.00 | 0.00 | 31.10 | 3.04 | 0.55
LogLogistic ^d^ ^,^ ^e^ | −1 | 0.00 | 65535 | −0.00 | −0.00 | −0.00 | 30.49 | 5.33 | 0.85
Multistage (1-degree)^f^ | 0 | 2.21 | NA | −1.31 | 0.70 | −1.31 | 31.10 | ND | ND
Weibull^c^ | −1 | 0.00 | 65535 | −0.00 | −0.00 | −0.00 | 30.50 | 9.25 | 0.55
Logistic | 0 | 0.00 | NA | 0.00 | 0.00 | 0.00 | 28.50 | ND | ND
LogProbit^d^ | −1 | 0.00 | 65535 | 0.00 | −0.00 | 0.00 | 30.50 | 9.87 | 1.05
Probit | 0 | 0.00 | NA | 0.00 | −0.00 | −0.00 | 28.49 | ND | ND

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected.

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit test could not be calculated

Figure A-2 Fit of LogLogistic Model to Data on Litters with 2 or More Skeletal Variations in the Offspring of Rats Exposed to Pentachlorophenol

Figure A-2 description

Comparison of the potential PODs for developmental effects identified the BMDL of 0.61 mg/kg/day for two or more fetal resorptions in a litter as the lowest potential POD. Derivation of an MRL based on the BMDL of 0.61 mg/kg/day and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) results in an intermediate-duration MRL of 0.006 mg/kg/day. This MRL is slightly higher than the acute-duration oral MRL, which is also based on developmental toxicity.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Pentachlorophenol
CAS Numbers: | 87-86-5
Date: | April 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.005 mg/kg/day (5 μg/kg/day)
Critical Effect: | Minimal chronic liver inflammation
Reference: | EPA 1997
Point of Departure: | LOAEL of 1.5 mg/kg/day
Uncertainty Factor: | 300
LSE Graph Key: | 51
Species: | Dog

MRL Summary: A chronic-duration oral MRL of 0.005 mg/kg/day (5 μg/kg/day) was derived for pentachlorophenol. The MRL is based on a LOAEL of 1.5 mg/kg/day for minimal chronic inflammation in the liver of dogs administered via capsule technical-grade pentachlorophenol for 1 year (EPA 1997) and an uncertainty factor of 300 (3 for the use of a minimal LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Six studies have evaluated the chronic toxicity of pentachlorophenol and have reported adverse health effects (summarized in Table A-6). The observed effects include decreases in body weight gain in rats exposed to pure pentachlorophenol (NTP 1999) or EC-7 (Schwetz et al. 1978) and in mice exposed to EC-7 or technical-grade pentachlorophenol (NTP 1989); hematological effects in mice exposed to technical-grade pentachlorophenol (splenic effects) (NTP 1989) and in dogs exposed to technical-grade pentachlorophenol (RBC effects) (EPA 1997); liver effects in rats exposed to pure pentachlorophenol (NTP 1999) or EC-7 (Schwetz et al. 1978), mice exposed to EC-7 or technical-grade pentachlorophenol (NTP 1989), and dogs exposed to technical-grade pentachlorophenol (EPA 1997); and adrenal gland effects in mice exposed to EC-7 (NTP 1989).

The liver alterations were selected as the critical effect based on the consistency of the finding and the lower LOAEL values, as compared to other endpoints. The liver effects consist of hepatocellular hypertrophy, increases in elevated ALT levels, chronic inflammation, and necrosis. Increases in hepatocellular adenomas and carcinomas have also been reported in the mouse studies testing technical-grade pentachlorophenol or EC-7 (NTP 1989). Liver tumors were not observed in rats exposed to pure pentachlorophenol (NTP 1999). The lowest LOAEL for liver effects was 1.5 mg/kg/day for chronic inflammation and increases in liver weight in dogs (EPA 1997). At higher doses (17 mg/kg/day), necrosis was observed in mice (NTP 1989). The available chronic duration data do not allow a comparison between the toxicity of pure pentachlorophenol and technical-grade pentachlorophenol; although a comparison of the LOAEL values suggest some differences, it is difficult to determine if these differences are due to testing different animal species.

Table A-6 Summary of NOAELs and LOAELs For Adverse Effects Following Chronic-Duration Oral Exposure to Pentachlorophenol

Species, duration (route) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference | Purity
Body weight effects
Rat; 2 years (F) | 20 | 30 | 10 and 14% decrease in body weight gain in males and females, respectively | NTP 1999 | Pure (99%)
Rat; 1 year with 1 year recovery (F) | | 60 | 17 and 22% decrease in body weight gain in males and females, respectively, at end of exposure period | NTP 1999 | Pure (99%)
Rat; 22–24 months (F) | 10 | 30 | 12% decrease in body weight gain | Schwetz et al. 1978 | EC-7 (90.4%)
Mouse; 2 years (F) | 17 | 34 | 6–12% lower body weights in females | NTP 1989 | EC-7 (90.4%)
Mouse; 2 years (F) | 17 | 35 | 5–13% lower body weights in females | NTP 1989 | Technical grade (90.4%)
Hematological effects
Mouse; 2 years (F) | 114 | | | NTP 1989 | EC-7 (90.4%)
Mouse; 2 years (F) | | 18 | Diffuse hematopoietic cells in spleen in males at ≥18 mg/kg/day and females at 35 mg/kg/day | NTP 1989 | Technical grade (90.4%)
Dog; 1 years (C) | 1.5 | 3.5 | Decreased RBC count in males at 3.5 mg/kg/day; decreased hemoglobin at 6.5 mg/kg/day; in females, decreased RBC count, hemoglobin, and hematocrit at 6.5 mg/kg/day | EPA 1997 | Technical grade (90.9%)
Hepatic effects
Rat; 2 years (F) | 10 | 20 | Cystic hepatocyte degeneration | NTP 1999 | Pure (99%)
Rat; 1 year with 1 year recovery (F) | | 60 | Centrilobular hepatocellular hypertrophy and cystic hepatocyte degeneration | NTP 1999 | Pure (99%)
Mouse; 2 years (F) | | 17 | Inflammation and necrosis | NTP 1989 | EC-7 (90.4%)
Rat; 22-24 months (F) | 10 | 30 | Elevated ALT | Schwetz et al. 1978 | EC-7 (90.4%)
Dog; 1 year (C) | | 1.5 | Increased liver weight, minimal-to-mild chronic inflammation; cytoplasmic vacuolation at 6.5 mg/kg/day and minimal necrosis at 6.5 mg/kg/day | EPA 1997 | Technical grade (90.9%)
Mouse; 2 years (F) | | 17 | Inflammation and necrosis | NTP 1989 | Technical grade (90.4%)
Endocrine effects
Rat; 2 years (F) | 30 | | No thyroid or adrenal gland alterations | NTP 1999 | Pure (99%)
Rat; 1 year with 1 year recovery (F) | 60 | | No thyroid or adrenal gland alterations | NTP 1999 | Pure (99%)
Mouse; 2 years (F) | | 18 | Adrenal gland hyperplasia in males | NTP 1989 | EC-7 (90.4%)
Mouse; 2 years (F) | | 18 | Adrenal gland hyperplasia in males | NTP 1989 | Technical grade (90.4%)
Dog; 1 year (C) | | 6.5 | No thyroid or adrenal gland alterations | EPA 1997 | Technical grade (90.4%)

ALT = alanine aminotransferase; (C) = capsule; (F) = feed; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: EPA (1997) was selected as the principal study because it identified the lowest LOAEL for the critical effect.

Summary of the Principal Study:

EPA. 1997. Data evaluation record. Pentachlorophenol. 83-1b: Fifty-two week repeated dose chronic oral study of pentachlorophenol administered via capsule to dogs. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. DP Barcode D225574. MRID 43982701.

Groups of four male and four female beagle dogs were administered, via gelatin capsule, 0, 1.5, 3.5, or 6.5 mg/kg/day technical-grade pentachlorophenol (90.9% pure) for 1 year. The following parameters were used to assess toxicity: daily clinical observations, body weight, feed intake, ophthalmoscopic examination (weeks 13 and 26), hematology and serum clinical chemistry (weeks 13, 26, 39, and 52), urinalysis (weeks 13, 26, and 39), gross necropsy, and comprehensive histopathological examination of tissues and organs.

One male and one female dogs in the 6.5 mg/kg/day group were sacrificed in extremis on study days 247 and 305, respectively. Lethargy, inappetence, emaciation, dehydration, pale mucous membranes, gastrointestinal irritation, and bleeding were observed in the 6.5 mg/kg/day group. Significant decreases in body weight gain were observed in the 6.5 mg/kg/day beginning on exposure day 95; at termination, the females weighed approximately 20% less than controls. Decreases in feed consumption were observed in the females in the 6.5 mg/kg/day group until week 41; at week 41, there was a sudden increase in feed consumption. No significant alterations in body weight were observed in males, although terminal body weight in the 6.5 mg/kg/day was 18% lower than controls. Increased feed consumption (5–20%) was observed in the males. No exposure-related ophthalmoscopic findings were observed. Significant decreases in RBC counts were observed in males at 3.5 and 6.5 mg/kg/day (15 and 22% respectively); hemoglobin was significantly decreased at 6.5 mg/kg/day (17%). In female dogs, RBC counts, hemoglobin, and hematocrit levels were significantly decreased at 6.5 mg/kg/day (10–17% for all parameters). Alterations of serum clinical chemistry parameters consisted of increases in alkaline phosphatase levels at ≥1.5 mg/kg/day, increases in ALT at ≥3.5 mg/kg/day, and increases in AST at 6.5 mg/kg/day; the only statistically significant alterations were the increases in AST (67%) and alkaline phosphatase (580%) in females at 6.5 mg/kg/day. No treatment-related alterations were observed in the urinalysis. Statistically significant increases in relative liver weight were observed in males and females at ≥1.5 mg/kg/day and increases in absolute liver weight were observed in females at ≥1.5 mg/kg/day. Increases in relative and absolute thyroid weight were also observed in females at 6.5 mg/kg/day. Histological alterations in the liver consisted of mild to moderate accumulation of pigment consistent with lipofuscin at >1.5 mg/kg/day, minimal chronic inflammation in males at >1.5 mg/kg/day and in females at >3.5 mg/kg/day, cytoplasmic vacuolation in males at >3.5 mg/kg/day, and minimal necrosis in females at 6.5 mg/kg/day (2/4 compared to 0/4 in controls). Lymphocytic mucosal inflammation was observed at >1.5 mg/kg/day.

Selection of the Point of Departure for the MRL: The LOAEL of 1.5 mg/kg/day was selected as the POD for the MRL. This dose was considered a minimal LOAEL based on the characterization of the chronic inflammation as minimal in severity. The incidences of chronic inflammation were 0/4, 4/4, 4/4, and 3/3 in the 0, 1.5, 3.5, and 6.5 mg/kg/day male dog groups, respectively, and the severity scores (lesions grades were 1=minimal, 2=mild; 3=moderate; and 4=marked) were 0, 1, 1.3, and 1.3, respectively. The incidences of chronic inflammation in the females were 2/4, 2/4, 4/4, and 3/3, respectively, with severity scores of 1, 1.5, 1.8, and 1.7, respectively. The incidence of chronic inflammation in males was not considered suitable for BMD modeling because the incidence in all treated groups was 100%, which would provide limited predictive information at the BMD response rate of 10%.

Uncertainty Factor:

- 3 for the use of a minimal LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = LOAEL ÷ UF = 1.5 mg / kg / day ÷ (3 × 10 × 10) = 0.005 mg / kg / day (5 μg / kg / day)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Studies in humans primarily exposed to pentachlorophenol via dermal contact have reported hepatic enlargement (Armstrong et al. 1969; Gordon 1956; Robson et al. 1969; Smith et al. 1996), alterations in serum ALT and AST levels (Klemmer et al. 1980), and centrilobular congestion or degeneration (Bergner et al. 1965). A number of acute- and intermediate-duration studies in laboratory animals have identified the liver as a sensitive target.

Agency Contacts (Chemical Managers): Obaid Faroon