# 9 REFERENCES

Aaron CK. 2007. Organophosphates and carbamates. In: Shannon MW, Borron SW, Burns MJ, eds. Haddad and Winchester’s clinical management of poisoning and drug overdose. Philadelphia PA: Saunders Elsevier, 1171–1184.
Abadin HG, Chou CSJ, Llados FT. 2007. Health effects classification and its role in the derivation of minimal risk levels: Immunological effects. Regul Toxicol Pharmacol 47:249–256.17194513
Abou-Donia MB. 1995. Organophosphorus pesticides. In: Chang LW, Dyer RS, Eds. Handbook of neurotoxicology. New York, NY: Marcel Dekker, 419–473.
Abou-Donia MB, Lapadula DM. 1990. Mechanisms of organophosphorus ester-induced delayed neurotoxicity: Type I and Type II. Ann Rev Pharmacol Toxicol 30:405–440.2188574
ACGIH. 2012. Parathion. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 46, 109.
Adhya TK, Barik S, Sethunathan N. 1981c. Hydrolysis of selected organophosphorus insecticides by two bacteria isolated from flooded soil. J Appl Bacteriol 50:167–172.7228819
Adhya TK, Subhakar B, Sethunathan N. 1981b. Fate of fenitrothion, methyl parathion, and parathion in anoxic sulfur-containing soil systems. Pestic Biochem Physiol 16(1):14–20.
Adhya TK, Sudhakar B, Sethunathan N. 1981a. Stability of commercial formulation of fenitrothion, methyl parathion and parathion in anaerobic soils. J Agric Food Chem 29(1):90–93.
Adigun AA, Wrench N, Seidler FJ, . 2010. Neonatal organophosphorus pesticide exposure alters the developmental trajectory of cell-signaling cascades controlling metabolism: Differential effects of diazinon and parathion. Environ Health Perspect 118(2):210–215.20123610
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
AIHA. 2011. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. http://www.aiha.org/INSIDEAIHA/GUIDELINEDEVELOPMENT/ERPG/Pages/default.aspx. April 24, 2013.
Alavanja MCR, Sandler DP, McMaster SB, . 1996. The Agricultural Health Study. Environ Health Perspect 104(4):362–369.8732939
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Fed Am Soc Exp Biol.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
AOAC. 1990a. Organophosphorus pesticide residues. Sweep codistillation method. In: Helrich K, ed. AOAC official methods of analysis. 15th ed. Arlington, VA: Association of Official Analytical Chemists, 287–289.
AOAC. 1990b. Pesticide and industrial chemical residues. In: Helrich K, ed. Official methods of analysis of the Association of Official Analytical Chemists. 15th ed. Arlington, VA: Association of Official Analytical Chemists, Inc., 274–282.
AOAC. 1990c. Organophosphorus pesticide residues. Single sweep oscillographic polarographic confirmatory method. In: Helrich K, ed. Official methods of analysis of the Association of Official Analytical Chemists. 15th ed. Arlington, VA: Association of Analytical Chemists, Inc., 289–290.
Arcury TA, Grzywacz JG, Barr DB, . 2007. Pesticide urinary metabolite levels of children in eastern North Carolina farmworker households. Environ Health Perspect 115(8):1254–1260.17687456
Arterberry JD, Durham WF, Elliott JW, . 1961. Exposure to parathion. Measurement by blood cholinesterase level and urinary p-nitrophenol excretion. Arch Environ Health 3:476–485.13862642
Atkinson JE, Bolte HF, Rubin LF, . 1994. Assessment of ocular toxicity in dogs during 6 months’ exposure to a potent organophosphate. J Appl Toxicol 14(2):145–152.8027510
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
ATSDR. 2011. Medical Management Guidelines for parathion. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/mhmi/mmg48.pdf. November 7, 2016.
ATSDR. 2015. Parathion. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources. July 6, 2016.
Atterberry TT, Burnett WT, Chambers JE. 1997. Age-related differences in parathion and chlorpyrifos toxicity in male rats: Target and nontarget esterase sensitivity and cytochrome P450-mediated metabolism. Toxicol Appl Pharmacol 147(2):411–418.9439736
Bajgar J. 2004. Organophosphates/nerve agent poisoning: Mechanism of action, diagnosis, prophylaxis, and treatment. Adv Clin Chem 38:151–216.15521192
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnes JM, Denz FA. 1951. The chronic toxicity of p-nitrophenyl diethyl thiophosphate (E. 605); a long-term feeding experiment with rats. J Hyg 49(4):430–441.14908051
Bass SW, Triolo AJ, Coon JM. 1972. Effect of DDT on the toxicity and metabolism of parathion in mice. Toxicol Appl Pharmacol 22(4):684–693.5045772
Beard JD, Umbach DM, Hoppin JA, . 2014. Pesticide exposure and depression among male private pesticide applicators in the Agricultural Health Study. Environ Health Perspect 122(9):984–991. 10.1289/ehp.1307450.24906048
Benke GM, Murphy SD. 1974. Anticholinesterase action of methyl parathion, parathion and azinphosmethyl in mice and fish: Onset and recovery of inhibition. Bull Environ Contam Toxicol 12(1):117–122.4433847
Benke GM, Murphy SD. 1975. The influence of age on the toxicity and metabolism of methyl parathion and parathion in male and female rats. Toxicol Appl Pharmacol 31(2):254–269.1129797
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Besser R, Gutmann L, Weilemann LS. 1993. Polyneuropathy following parathion poisoning. J Neurol Neurosurg Psychiatry 56(10):1135–1136.8410019
Bird SB, Sutherland TD, Gresham C, . 2008. OpdA, a bacterial organophosphorus hydrolase, prevents lethality in rats after poisoning with highly toxic organophosphorus pesticides. Toxicology 247(2–3):88–92.18378376
Bouchard MF, Chevrier J, Harley KG, . 2011. Prenatal exposure to organophosphate pesticides and IQ in 7-year old children. Environ Health Perspect 119(8):1189–1195.21507776
Boudry I, Blanck O, Cruz C, . 2008. Percutaneous penetration and absorption of parathion using human and pig skin models in vitro and human skin grafted onto nude mouse skin model in vivo. J Appl Toxicol 28(5):645–657.18041757
Boyd EM. 1969. Dietary protein and pesticide toxicity in male weanling rats. Bull World Health Organ 40(5):801–805.4898389
Bradway DE, Shafik TM, Lores EM. 1977. Comparison of cholinesterase activity, residue levels, and urinary metabolite excretion of rats exposed to organophosphorus pesticides. J Agric Food Chem 25(6):1353–1358.72085
Braeckman RA, Audenaert F, Willems JL, . 1983. Toxicokinetics of methyl parathion and parathion in the dog after intravenous and oral administration. Arch Toxicol 54(1):71–82.6639354
Brown HV, Bush BA. 1950. Parathion inhibition of cholinesterase. Arch Ind Hyg Occup Med 1:633–636.15433506
Brown RL, Farmer CN, Millar RG. 1987. Optimization of sweep codistillation apparatus for determination of coumaphos and other organophosphorus pesticide residues in animal fat. J AOAC 70(3):442–445.
Bulusu S, Chakravarty I. 1986. Subacute administration of organophosphorus pesticides and hepatic drug metabolizing enzyme activity in normal and malnourished rats. Bull Environ Contam Toxicol 36(1):73–80.3940570
Bulusu S, Chakravarty I. 1987. Effect of subacute administration of three organophosphorus pesticides on the hepatic phosphatases under various nutritional conditions. Environ Res 44(1):126–135.2820707
Buratti FM, Volpe MT, Fabrizi L, . 2002. Kinetic parameters of OPT pesticide desulfuration by c-DNA expressed human CYPs. Environ Toxicol Pharmacol 11(3–4):181–190.21782601
Buratti FM, Volpe MT, Meneguz A, . 2003. CYP-specific bioactivation of four organophosphorothioate pesticides by human liver microsomes. Toxicol Appl Pharmacol 186(3):143–154.12620367
Burmaster DE. 1982. The new pollution. Groundwater contamination. Environment 24(2):6–36.
Butler AM, Murray M. 1997. Biotransformation of parathion in human liver: Participation of CYP3A4 and its inactivation during microsomal parathion oxidation. J Pharmacol Exp Ther 280(2):966–973.9023313
Butler PA, Schutzmann RL. 1978. Fish, wildlife, and estuaries. Residues of pesticides and PCBs in estuarine fish, 1972–1976, National Pesticide Monitoring Programs. Pestic Monit J 12(2):51–59.101966
Calaf GM, Roy D. 2007a. Gene and protein expressions induced by 17β-estradiol and parathion in cultured breast epithelial cells. Mol Med 13(5–6):255–265.17622325
Calaf GM, Roy D. 2007c. Gene expression signature of parathion-transformed human breast epithelial cells. Int J Mol Med 19(5):741–750.17390078
Calaf GM, Roy D. 2007b. Human drug metabolism genes in parathion-and estrogen-treated breast cells. Int J Mol Med 20(6):875–881.17982697
Calaf GM, Echiburu-Chau C, Roy D. 2009. Organophosphorous pesticides and estrogen induce transformation of breast cells affecting p53 and c-Ha-ras genes. Int J Oncol 35(5):1061–1068.19787260
CalEPA. 2015. Summary of Pesticide Use Report data 2014 indexed by chemical. California Environmental Protection Agency, Department of Pesticide Regulation. http://www.cdpr.ca.gov/docs/pur/pur14rep/chmrpt14.pdf. August 23, 2016.
Carey AE, Douglas P, Tai H, . 1979b. Pesticide residue concentrations in soils of five United States cities, 1971- Urban soils monitoring program. Pestic Monit J 13(1):17–22.492926
Carey AE, Gowen JA, Tai H, . 1979a. Pesticide residue levels in soils and crops from 37 states, 1972. National Soils Monitoring Program (IV). Pestic Monit J 12(4):209–229.461116
Carey AE, Yang HSC, Wiersma GB, . 1980. Soils. Residual concentration of propanil, TCAB, and other pesticides in rice-growing soils in the United States, 1972. Pestic Monit J 14(1):23–25.7422467
Carman GE, Iwata Y, Pappas JL, . 1982. Pesticide applicator exposure to insecticides during treatment of citrus trees with oscillating boom and airblast units. Arch Environ Contam Toxicol 11:651–659.7165384
Carrier G, Brunet RC. 1999. A toxicokinetic model to assess the risk of azinphosmethyl exposure in humans through measures of urinary elimination of alkylphosphates. Toxicol Sci 47:23–32.10048150
Carvalho FP, Fowler SW, Readman JW. 1998. The fate and effects of agrochemical residues in tropical coastal lagoons investigated with ^14^C-labelled compounds and radiotracer techniques. Verch Internat Verein Limnol 26:1430–1432.
Casale GP, Cohen SD, DiCapua RA. 1983. The effects of organophosphate-induced cholinergic stimulation on the antibody response to sheep erythrocytes in inbred mice. Toxicol Appl Pharmacol 68(2):198–205.6857660
Casale GP, Cohen SD, DiCapua RA. 1984. Parathion-induced suppression of humoral immunity in inbred mice. Toxicol Lett 23(2):239–247.6506099
Casterline JL, Jr., Williams CH. 1971. The effect of 28-day pesticide feeding on serum and tissue enzyme activities of rats fed diets of varying casein content. Toxicol Appl Pharmacol 18(3):607–618.5569834
CDC. 2005. Third national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services.
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Centers for Disease Control and Prevention, Department of Health and Human Services.
CDC. 2015. Fourth national report on human exposure to environmental chemicals, updated tables (February 2015). Centers for Disease Control and Prevention. http://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Feb2015.pdf. December 14, 2015.
CDFA. 1988. Evaluation of ethyl parathion as a toxic air contaminant. California Department of Food and Agriculture.
Chambers JE, Ma T, Boone JS, . 1994. Role of detoxication pathways in acute toxicity levels of phosphorothionate insecticides in the rat. Life Sci 54(18):1357–1364.7514706
Chang MJW, Chen YC, Yang HJ. 1997. Comparative evaluation on the biological monitoring of exposure to parathion and its methyl analog. Arch Environ Contam Toxicol 32:422–425.9175510
Chang SK, Riviere JE. 1991. Percutaneous absorption of parathion in vitro in porcine skin: Effects of dose, temperature, humidity, and perfusate composition on absorptive flux. Fundam Appl Toxicol 17(3):494–504.1794653
Chapman RA, Cole CM. 1982. Observations on the influence of water and soil pH on the persistence of pesticides. J Environ Sci Health B17(5):487–504.
Chapman RA, Tu CM, Harris CR, . 1981. Persistence of five pyrethroid insecticides in sterile and natural, mineral and organic soil. Bull Environ Contam Toxicol 26:513–519.7236909
Chapman SK, Leibman KC. 1971. The effects of chlordane, DDT, and 3-methylcholanthrene upon the metabolism and toxicity of diethyl-4-nitrophenyl phosphorothionate (parathion). Toxicol Appl Pharmacol 18(4):977–987.5570247
Chaturvedi AK, Kuntz DJ, Rao NG. 1991. Metabolic aspects of the toxicology of mixtures of parathion, toxaphene and/or 2,4-D in mice. J Appl Toxicol 11(4):245–251.1658105
Chemnitius JM, Losch H, Losch K, . 1983. Organophosphate detoxicating hydrolases in different vertebrate species. Comp Biochem Physiol 76C:85–93.
Chen ZM, Zabik MJ, Leavitt RA. 1984. Comparative study of thin film photodegradative rates for 36 pesticides. Ind Eng Chem Prod Res Dev 23:5–11.
Chiou CT, Freed VH, Peters LJ, . 1980. Evaporation of solutes from water. Environ Int 3:231–236.
Chu W, Chan KH. 2000. The prediction of partitioning coefficients for chemicals causing environmental concern. Sci Total Environ 248(1):1–10.10807037
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Costa LG. 2008. Toxic effects of pesticides. In: Klaassen CD, ed. Casarett and Doull’s toxicology. The basic science of poisons. 7th ed. New York, NY: McGraw-Hill Medical, 883–930.
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Ann Rev Pharmacol Toxicol 44:87–110. 10.1146/annurev.pharmtox.44.101802.121424.14744240
Costa LG, Giordano G, Cole TB, . 2013. Paraoxonase 1 (PON1) as a genetic determinant of susceptibility to organophosphate toxicity. Toxicology 307:115–122.22884923
Costa LG, Schwab BW, Murphy SD. 1982. Tolerance to anticholinesterase compounds in mammals. Toxicology 25:79–97.6760465
Coupe RH, Manning MA, Foreman WT, . 2000. Occurrence of pesticides in rain and air in urban and agricultural areas of Mississippi, April-September 1995. Sci Total Environ 248:227–240.10805242
Coye MJ, Barnett PG, Midtling JE, . 1987. Clinical confirmation of organophosphate poisoning by serial cholinesterase analyses. Arch Intern Med 147:338–342.
Crosby DG. 1979. The significance of light induced pesticide transformations. In: Geissbuhler H, ed. Advances in pesticide science. Oxford: Pergamon Press, 568–576.
Davies JE, Davis JH, Frazier DW, . 1967. Disturbances of metabolism in organophosphate poisoning. Ind Med Surg 36(1):58–62.5226530
De Bleecker J, Vogelaers D, Ceuterick C, . 1992. Intermediate syndrome due to prolonged parathion poisoning. Acta Neurol Scand 86(4):421–424.1455989
Degraeve N, Moutschen J. 1984. Absence of genetic and cytogenetic effects in mice treated by the organophosphorus insecticide parathion, its methyl analogue, and paraoxon. Toxicology 32(2):177–183.6464028
De Jager AE, van Weerden TW, Houthoff HJ, . 1981. Polyneuropathy after massive exposure to parathion. Neurology 31(5):603–605.7194975
Denga N, Moldeus P, Kasilo OM, . 1995. Use of urinary p-nitrophenol as an index of exposure to parathion. Bull Environ Contam Toxicol 55(2):296–302.7579938
Dennis LK, Lynch CF, Sandler DP, . 2010. Pesticide use and cutaneous melanoma in pesticide applicators in the agricultural heath study. Environ Health Perspect 118(6):812–817.20164001
Deskin R, Rosenstein L, Rogers N, . 1979. Parathion toxicity in perinatal rats exposed in utero. Toxicol Lett 3(1):11–14.
de Solla SR, Struger J, McDaniel TV. 2012a. Detection limits can influence the interpretation of pesticide monitoring data in Canadian surface waters. Chemosphere 86:565–571.22137558
de Solla SR, Struger J, McDaniel TV. 2012b. Supplemental material to “Detection limits can influence the interpretation of pesticide monitoring data in Canadian surface water” (Chemosphere 86:565–571). Chemosphere. http://www.sciencedirect.com/science/article/pii/S0045653511010708#appd002. December 14, 2015.22137558
Diggory HJ, Landrigan PJ, Latimer KP, . 1977. Fatal parathion poisoning caused by contamination of flour in international commerce. Am J Epidemiol 106(2):145–153.888817
Dikshith TS, Datta KK. 1972. Effect of parathion on the skin of guinea-pigs. Experientia 28(2):169–171.5020343
Dikshith TS, Tandon SK, Datta KK, . 1978. Comparative response of male rats to parathion and lindane: Histopathological and biochemical studies. Environ Res 17(1):1–9.95696
Di Muccio A, Pelosi P, Camoni I, . 1996. Selective, solid-matrix dispersion extraction of organophosphate pesticide residues from milk. J Chromatogr A 754:497–506.8997741
DOE. 2016a. Protective action criteria (PAC): Chemicals with AEGLs, ERPGs, & TEELs. Definition of PACs (AEGLs, ERPGs or TEELs). Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-27-chemicals-concern-march-2012. November 1, 2016.
DOE. 2016b. Table 2: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed in alphabetical order. May 2016. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. November 1, 2016.
Draper WM, Crosby DG. 1984. Solar photooxidation of pesticides in dilute hydrogen peroxide. J Agric Food Chem 32:231–237.
Driss MR, Hennion MC, Bouguerra ML. 1993. Determination of carbaryl and some organophophorus pesticides in drinking water using on-line liquid chromatographic preconcentration techniques. J Chromatogr 639:352–358.8335721
Durham WF, Wolfe HR, Elliott JW. 1972. Absorption and excretion of parathion by spraymen. Arch Environ Health 24(6):381–387.5031564
Duysen EG, Lockridge O. 2011. Induction of plasma acetylcholinesterase activity in mice challenged with organophosphorus poisons. Toxicol Appl Pharmacol 255(2):214–220.21767560
Duysen EG, Cashman JR, Schopfer LM, . 2012. Differential sensitivity of plasma carboxylesterase-null mice to parathion, chlorpyrifos and chlorpyrifos oxon, but not to diazinon, dichlorvos, diisopropylfluorophosphate, cresyl saligenin phosphate, cyclosarin thiocholine, tabun thiocholine, and carbofuran. Chem Biol Interact 195(3):189–198.22209767
Ebbert JC, Embrey SS. 2001. Pesticides in surface water of the Yakima River Basin, Washington, 1999–2000: Their occurrence and an assessment of factors affecting concentrations and loads. Portland, OR: U.S. Department of the Interior, U.S. Geological Survey.
Ecobichon DJ. 1994. Organophosphorus ester insecticides. In: Pesticides and neurological diseases. 2nd ed. Boca Raton, FL: CRC Press, Inc., 171–249.
Ecobichon DJ, Comeau AM. 1973. Pseudocholinesterases of mammalian plasma: Physicochemical properties and organophosphate inhibition in eleven species. Toxicol Appl Pharmacol 24:92–100.4631366
Eddleston M. 2015. Insecticides: Organic phosphorus compounds and carbamates. In: Hoffman RS, Howland MA, Lewin NA, eds. Goldfrank’s toxicologic emergencies. 10^th^ ed. New York NY: McGraw-Hill Education, 1409–1424.
Edson EF. 1964. Summaries of toxicological data. No-effect levels of three organophosphates in the rat, pig and man. Food Cosmet Toxicol 2:311–316.14199205
Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in river water. Environ Sci Technol 5(6):541–544.
Eigenberg DA, Pazdernik TL, Doull J. 1983. Hemoperfusion and pharmacokinetic studies with parathion and paraoxon in the rat and dog. Drug Metab Dispos 11(4):366–370.6137345
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
Eisert R, Levsen K, Wunsch G. 1994. Element-selective detection of pesticides by gas chromatography-atomic emission detection and solid-phase microextraction. J Chromatogr A 683:175–183.
Eitzman DV, Wolfson SL. 1967. Acute parathion poisoning in children. Am J Dis Child 114(4):397–400.6047239
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604. 10.1016/j.neuro.2011.12.009.22198708
Elkner KP, Fenske RA, Gallo M. 1991. Effect of systemic exposure to parathion on the dark adapted pupil dilation of cynomolgus monkeys. J Toxicol Environ Health 32(1):75–88.1987364
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71.21782694
EPA 1977a. Evaluation of selected pesticides as chemical mutagens in vitro and in vivo studies. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600177028. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100SHSP.txt. August 8, 2016.
EPA. 1977b. The degradation of selected pesticides in soil: A review of the published literature. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development.
EPA. 1978. Teratology and acute toxicology of selected chemical pesticides administered by inhalation. Environmental health effects research series. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600178003. PB277077.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency. EPA600890066A. PB90238890.
EPA. 1993a. Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. Method 1657. The determination of organo-phosphorus pesticides in municipal and industrial wastewater. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA821R93010A.
EPA. 1993b. Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. Method 614. The determination of organophosphorus pesticides in municipal and industrial wastewater. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA821R93010A.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency. EPA630R96012.
EPA. 1998. RCRA waste minimization PBT priority chemical list. U.S. Environmental Protection Agency. Fed Regist 63 FR 60332. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2000. Ethyl parathion. R.E.D. Facts. U.S. Environmental Protection Agency. www.epa.gov/oppsrrd1/REDs/factsheets/0155fct.pdf. June 3, 2013.
EPA. 2001. Preliminary cumulative risk assessment of the organophosphorus pesticides. U.S. Environmental Protection Agency. http://www.epa.gov/opp00001/cumulative/rra-op/. June 7, 2013.
EPA. 2002. Organophosphate pesticides: Revised cumulative risk assessment. U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/cumulative/rra-op/. May 15, 2013.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2006a. Organophosphorus cumulative risk assessment-2006. Update. U.S. Environmental Protection Agency. http://www.epa.gov/oppsrrd1/cumulative/2006-op/index.htm. June 3, 2013.
EPA. 2006b. Ethyl parathion; product cancellation order. Fed Regist 71(239):74904–74905. http://www.epa.gov/fedrgstr/EPA-PEST/2006/December/Day-13/p20988.htm. July 16, 2013.
EPA. 2009a. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 74 FR 51850:51850–51862. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. April 24, 2013.
EPA. 2009c. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. April 24, 2013.
EPA. 2012a. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012b. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/drink/standards/hascience.cfm. April 24, 2013.
EPA. 2012c. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012d. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012e. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264, Appendix IX. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012f. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012g. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012h. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012i. Toxic Substances Control Act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012j. Toxic Substances Control Act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2013a. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/. April 24, 2013.
EPA. 2013b. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. April 24, 2013.
EPA. 2013c. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=124:1. April 24, 2013.
EPA. 2013d. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/mtl.html. April 24, 2013.
EPA. 2013e. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. April 24, 2013.
Erdman AR. 2004. Pesticides. In: Dart RC, ed. Medical toxicology. 3^rd^ ed. Philadelphia, PA: Lippincott Williams & Wilkins, 1475–1496.
Eskenazi B, Harley K, Bradman A, . 2004. Association of in utero organophosphate pesticide exposure and fetal growth and length of gestation in an agricultural population. Environ Health Perspect 112(10):1116–1124.15238287
Eskenazi B, Marks AR, Bradman A, . 2007. Organophosphate pesticide exposure and neurodevelopment in young Mexican-American children. Environ Health Perspect 115(5):792–798.17520070
Etzel RA, Forthal DN, Hill RH, Jr., . 1987. Fatal parathion poisoning in Sierra Leone. Bull World Health Organ 65(5):645–649.3501344
Evron T, Geyer BC, Cherni I, . 2007. Plant-derived human acetylcholinesterase-R provides protection from lethal organophosphate poisoning and its chronic aftermath. FASEB J 21(11):2961–2969.17475919
Eyer F, Meischner V, Kiderlen D, . 2003. Human parathion poisoning. A toxicokinetic analysis. Toxicol Rev 22(3):143–163.15181664
Fahrig R. 1974. Comparative mutagenicity studies with pesticides. IARC Sci Publ 10:161–181.
FAO. 1997. Parathion. Food and Agricultural Organization of the United Nations. http://www.fao.org/docrep/W5715E/w571e05.htm#parathion.
Farm Chemicals Handbook. 1987. Parathion. In: Farm chemicals handbook ’87. Meister Publishing Company, C192–C193.
Faust SD, Suffet IH. 1966. Recovery, separation, and identification of organic pesticides from natural and potable waters. In: Gunther FA, ed. Residue reviews. Residues of pesticides and other foreign chemicals in foods and feeds. New York, NY: Springer-Verlag, 44–116.
FDA. 1995. Residue monitoring. Food and Drug Administration Pesticide Program.
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. April 24, 2013.
Felsot A, Dahm PA. 1979. Sorption of organophosphorus and carbamate insecticides by soil. J Agric Food Chem 27(3):557–563.
Fenske RA, Lu C, Simcox NJ, . 2009. Strategies for assessing children’s organophosphorus pesticide exposures in agricultural communities. J Expo Anal Environ Epidemiol 10:662–671.
Finkelstein Y, Wolff M, Biegon A. 1988. Brain acetylcholinesterase after acute parathion poisoning: A comparative quantitative histochemical analysis post mortem. Ann Neurol 24(2):252–257.3178179
Firestone JA, Smith-Weller T, Franklin G, . 2005. Pesticides and risk of Parkinson disease: A population-based case-control study. Arch Neurol 62(1):91–95.15642854
Fisher SW, Lohner TW. 1987. Changes in the aqueous behavior of parathion under varying conditions of pH. Arch Environ Contam Toxicol 16:79–84.
Fjordboge AS, Baun A, Vastrup T, . 2013. Zero valent iron reduces toxicity and concentrations of organophosphate pesticides in contaminated groundwater. Chemosphere 90:627–633.23021613
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Forsyth CS, Chambers JE. 1989. Activation and degradation of the phosphorothionate insecticides parathion and EPN by rat brain. Biochem Pharmacol 38(10):1597–1603.2730675
Foxenberg RJ, Ellison CA, Knaak JB, . 2011. Cytochrome P450-specific human PBPK/PD models for the organophosphorus pesticides: Chlorpyrifos and parathion. Toxicology 285:57–66.21514354
Foxenberg RJ, McGarrigle BP, Knaak JB, . 2007. Human hepatic cytochrome P450-specific metabolism of parathion and chlorpyrifos. Drug Metab Dispos 35(2):189–193.17079358
Frank R, Braun HE, Ishida K, . 1976. Persistent organic and inorganic pesticide residues in orchard soils and vineyards of southern Ontario. Can J Soil Sci 56:463–484.
Frawley JP, Fuyat HN. 1957. Effect of low dietary levels of parathion and systox on blood cholinesterase of dogs. J Agric Food Chem 5(5):346–348.
Freed VH, Chiou CT, Schmedding DW. 1979. Degradation of selected organophosphate pesticides in water and soil. J Agric Food Chem 27(4):706–708.
Fukushima M, Katagi T. 2006. Photodegradation of fenitrothion and parathion in tomato epicuticular waxes. J Agric Food Chem 54(2):474–479.16417307
Fukuyama T, Kosaka T, Hayashi K, . 2012. Immunotoxicity in mice induced by short-term exposure to methoxychlor, parathion, or piperonyl butoxide. J Immunotoxicol 10(2):150–159.22834942
Fukuyama T, Kosaka T, Tajima Y, . 2010. Prior exposure to organophosphorus and organochlorine pesticides increases the allergic potential of environmental chemical allergens in a local lymph node assay. Toxicol Lett 199(3):347–356.20920556
Fukuyama T, Tajima Y, Ueda H, . 2011. Prior exposure to immunosuppressive organophosphorus or organochlorine compounds aggravates the T(H)1- and T(H)2-type allergy caused by topical sensitization to 2,4-dinitrochlorobenzene and trimellitic anhydride. J Immunotoxicol 8(2):170–182.21534883
Funckes AJ, Hayes GR, Jr., Hartwell WV. 1963. Urinary excretion of paranitrophenol by volunteers following dermal exposure to parathion at different ambient temperatures. J Agric Food Chem 11(6):455–457.
Furlong CE, Li WF, Brophy VH, . 2000. The PON1 gene and detoxication. Neurotoxicology 21(4):581–587.11022865
Funari R, B. DV, Schiavo L, . 2013. Detection of parathion pesticide by quartz crystal microbalance functionalized with UV-activated antibodies. Anal Chem 85(13):6392–6397.23721081
Gagne J, Brodeur J. 1972. Metabolic studies on the mechanisms of increased susceptibility of weanling rats to parathion. Can J Physiol Pharmacol 50(9):902–915.5084365
Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99.13825957
Gaines TB, Linder RE. 1986. Acute toxicity of pesticides in adult and weanling rats. Fundam Appl Toxicol 7(2):299–308.3758548
Gallo MA, Lawryk NJ. 1991. Organic phosphorus pesticides. In: Hayes WJ, Laws ER, eds. Handbook of pesticide toxicology classes of pesticides. New York: Academic Press Inc., 1040–1049, 1091–1123.
García-Repetto R, Gimenez MP, Repetto M. 2001. New method for determination of ten pesticides in human blood. J AOAC Int 84(2):342–349.11324596
García-Repetto R, Martinez D, Repetto M. 1995. Coefficient of distribution of some organophosphorous pesticides in rat tissue. Vet Hum Toxicol 37(3):226–229.7571350
Gartrell MJ, Craun JC, Podrebarac DS, . 1986a. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):123–145.3949685
Gartrell MJ, Craun JC, Podrebarac DS, . 1986b. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):146–161.3949687
Gearhart JM, Jepson GW, Clewell HJ, . 1994. Physiologically based pharmacokinetic model for the inhibition of acetylcholinesterase by organophosphate esters. Environ Health Perspect 102(11):51–60.
Gentry PR, Hack CE, Haber L, . 2002. An approach for the quantitative consideration of genetic polymorphism data in chemical risk assessment: Examples with warfarin and parathion. Toxicol Sci 70(1):120–139.12388841
Gerstl Z, Mingelgrin U. 1984. Sorption of organic substances by soils and sediments. J Environ Sci Health B19(3):297–312.
Gerstl Z, Yaron B, Nye PH. 1979. Diffusion of a biodegradable pesticide. I. In a biologically inactive soil. Soil Sci Soc Am J 43:839–842.
Gilot-Delhalle J, Colizzi A, Moutschen J, . 1983. Mutagenicity of some organophosphorus compounds at the ade6 locus of Schizosaccharomyces pombe. Mutat Res 117:139–148.6835257
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Glooschenko WA, Strachan WMJ, Sampson RCL. 1976. Residues in water. Distribution of pesticides and polychlorinated biphenyls in water, sediments, and seston of the Upper Great Lakes, 1974. Pestic Monit J 10(2):61–67.826875
Glotfelty DE, Majewski MS, Seiber JN. 1990. Distribution of several organophosphorus insecticides and their oxygen analogues in a foggy atmosphere. Environ Sci Technol 24(3):353–357.
Goldner WS, Sandler DP, Yu F, . 2013. Hypothyroidism and pesticide use among male private pesticide applicators in the Agricultural Health Study. J Occ Environ Med 55(10): 1171–1178. 10.1097/JOM.0b013e31829b290b.
Gosselin NH, Bouchard M, Brunet RC, . 2005. Toxicokinetic modeling of parathion and its metabolites in humans for the determination of biological reference values. Toxicol Mech Methods 15(1):33–52.
Gramatica P, Corradi M, Consonni V. 2000. Modelling and prediction of soil sorption coefficients of non-ionic organic pesticides by molecular descriptors. Chemosphere 41:763–777.10834380
Grob D, Garlick WL, Harvey AM. 1950. The toxic effects in man of the anticholinesterase insecticide parathion (p-nitrophenol diethyl thionophosphate). Johns Hopkins Med J 87:106–129.
Gunderson EL. 1988. FDA Total Diet Study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
Gunderson EL. 1995. FDA total diet study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem Int 78(6):1353–1362.
Guyton KZ, Loomis D, Grosse Y, . 2015. Carcinogenicity of tetrachlorvinphos, parathion, malathion, diazinon, and glyphosate. Lancet 16:490–491. 10.1016/s1470-2045(15)70134-8.
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Haber LT, Maier A, Gentry PR, . 2002. Genetic polymorphisms in assessing interindividual variability in delivered dose. Regul Toxicol Pharmacol 35(2 Pt 1):177–197.12052003
Hall RJ, Kolbe E. 1980. Bioconcentration of organophosphorus pesticides to hazardous levels by amphibians. J Toxicol Environ Health 6(4):853–860.6968357
Hankemeier T, Louter AJH, Rinkema FD, . 1995. On-line coupling of solid-phase extraction and gas chromatography with atomic emission detection for analysis of trace pollutants in aqueous samples. Chromatographia 40(3/4):119–124.
Harbison RD. 1975. Comparative toxicity of some selected pesticides in neonatal and adult rats. Toxicol Appl Pharmacol 32(2):443–446.1154405
Hartwell WV, Hayes GR, Jr., Funckes AJ. 1964. Respiratory exposure to volunteers to parathion. Arch Environ Health 8:820–825.14157576
Hayes G, Funckes AJ, Hartwell WV. 1964. Dermal exposure of human volunteers to parathion. Arch Environ Health 8:829–833.14157578
He F, Xu H, Qin F, . 1998. Intermediate myasthenia syndrome following acute organophosphates poisoning--an analysis of 21 cases. Hum Exp Toxicol 17(1):40–45.9491337
HHS. 2009. Public welfare. Protection of human subjects. U.S. Department of Health & Human Services. Code of Federal Regulations 45 CFR 46, Subpart C. http://www.hhs.gov/ohrp/humansubjects/guidance/45cfr46.html#subpartc. May 14, 2014.
Hochreiter JJ. 1982. Chemical-quality reconnaissance of the water and surficial bed material in the Delaware River estuary and adjacent New Jersey tributaries, 1980–1981. Trenton, NJ: U.S. Geological Survey, Water Resources Division.
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoffman RS, Capel PD, Larson SJ. 2000. Comparison of pesticides in eight U.S. urban streams. Environ Toxicol Chem 19(9):2249–2258.
Hoffmann U, Papendorf T. 2006. Organophosphate poisonings with parathion and dimethoate. Intensive Care Med 32(3):464–468.16479380
Hollingworth RM, Alstott RL, Litzenberg RD. 1973. Glutathione S-aryl transferase in the metabolism of parathion and its analogs. Life Sci 13(3):191–199.4750916
Holstege DM, Scharberg DL, Richardson ER, . 1991. Multiresidue screen for organophosphorus insecticides using gel permeation chromatography- silica gel cleanup. J Assoc Off Anal Chem 74(2):394–399.1646783
Hong J, Eo Y, Rhee J, . 1993. Simultaneous analysis of 25 pesticides in crops using gas chromatography and their identification by gas chromatography-mass spectrometry. J Chromatogr 639:261–271.8335720
Hopper ML. 1988. Improved method for partition of organophosphate pesticide residues on a solid phase partition column. J Assoc Off Anal Chem 71(4):731–734.3417590
Hoppin JA, Umbach DM, London SJ, . 2006. Pesticides and adult respiratory outcomes in the Agricultural Health Study. Ann N Y Acad Sci 1076:343–354.17119214
Hoppin JA, Umbach DM, London SJ, . 2009. Pesticide use and adult-onset asthma among male farmers in the Agricultural Health Study. Eur Respir J 34(6):1296–1303.19541724
House WA, Rae JE, Kimblin RT. 1992. Source-sediment controls on the riverine transport of pesticides. Brighton Crop Protection Conference- Pests and Diseases-1992, 865–870.
HSDB. 2013. Parathion. Hazardous Substances Data Bank, National Library of Medicine. http://toxnet.nlm.nih.gov. June 03, 2013.
Hsu JP, Schattenberg HJ, III, Garza MM. 1991. Fast turnaround multiresidue screen for pesticides in produce. J Assoc Off Anal Chem 74(5):886–892.1783596
Hunter CL, Stephenson MD, Tjeerdema RS, . 1995. Contaminants in oysters in Kaneohe Bay, Hawaii. Mar Pollut Bull 30(10):646–654.
Hurh E, Lee E, Lee A, . 2000. Effects of enzyme inducers or inhibitors on the pharmacokinetics of intravenous parathion in rats. Biopharm Drug Dispos 21(5):193–204.11180198
IARC. 1983. Parathion in animals. In: IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Lyon, France: International Agency for Research on Cancer, 162–163.
IARC. 2013. Agents classified by the IARC monographs. Volumes 1–107. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. April 24, 2013.
IPCS. 2005. Methyl parathion. ICSC: 0626. International Chemical Safety Cards (ICSCs). International Programme on Chemical Safety. http://www.inchem.org/documents/icsc/icsc/eics0626.htm. August 25, 2014.
IRIS. 2003. Parathion. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. April 24, 2013.
Ivens IA, Schmuck G, Machemer L. 1998. Learning and memory of rats after long-term administration of low doses of parathion. Toxicol Sci 46(1):101–111.9928673
James MO. 1994. Pesticide metabolism in aquatic organisms. In: Chemistry of plant protection. Vol. 9. Berlin Heidelberg: Springer-Verlag, 153–189.
Jan YH, Richardson JR, Baker AA, . 2015. Vitamin K3 (menadione) redox cycling inhibits cytochrome P450-mediated metabolism and inhibits parathion intoxication. Toxicol Appl Pharmacol 288(1):114–120. 10.1016/j.taap.2015.07.023.26212258
Jepson GW, Hoover DK, Black RK, . 1994. A partition coefficient determination method for nonvolatile chemicals in biological tissues. Fundam Appl Toxicol 22(4):519–524.7520010
Johnson MK. 1975. Organophosphorus esters causing delayed neurotoxic effects. Mechanism of action and structure/activity studies. Arch Toxicol 34:259–288.766733
Jury WA, Spencer WF, Farmer WJ. 1984. Behavior assessment model for trace organics in soil: III. Application of screening model. J Environ Qual 13(4):573–579.
Kacham R, Karanth S, Baireddy P, . 2006. Interactive toxicity of chlorpyrifos and parathion in neonatal rats: Role of esterases in exposure sequence-dependent toxicity. Toxicol Appl Pharmacol 210(1–2):142–149.16260018
Kadenczki L, Arpad Z, Gardi I. 1992. Column extraction of residues of several pesticides from fruits and vegetables: A simple multiresidue analysis method. J Assoc Off Anal Chem Int 751(1):53–61.
Kadoum AM, Mock DE. 1978. Herbicide and insecticide residues in trailwater pits: Water and pit bottom soil from irrigated corn and sorghum fields. J Agric Food Chem 26(1):45–50.621340
Kamataki T, Lee Lin MCM, Belcher DH, . 1976. Studies of the metabolism of parathion with an apparently homogeneous preparation of rabbit liver cytochrome P-450. Drug Metab Dispos 4(2):180–189.5264
Karanth S, Pope C. 2000. Carboxylesterase and A-esterase activities during maturation and aging: Relationship to the toxicity of chlorpyrifos and parathion in rats. Toxicol Sci 58(2):282–289.11099640
Karanth S, Olivier K, Jr., Liu J, . 2001. In vivo interaction between chlorpyrifos and parathion in adult rats: Sequence of administration can markedly influence toxic outcome. Toxicol Appl Pharmacol 177(3):247–255.11749124
Kaur R, Kaur S, Lata M. 2011. Evaluation of DNA damage in agricultural workers exposed to pesticides using single cell gel electrophoresis (comet) assay. Ind J Human Genetics 17:179–187.
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology--drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167. 10.1056/NEJMra035092.13679531
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38.7379718
Kevekordes S, Gebel T, Pav K, . 1996. Genotoxicity of selected pesticides in the mouse bone-marrow micronucleus test and in the sister-chromatid exchange test with human lymphocytes in vitro. Toxicol Lett 89(1):35–42.8952709
Kim DO, Lee SK, Jeon TW, . 2005. Role of metabolism in parathion-induced hepatotoxicity and immunotoxicity. J Toxicol Environ Health A 68(23–24):2187–2205.16326433
Kissel JC, Curl CL, Kedan G, . 2005. Comparison of organophosphorus pesticide metabolite levels in single and multiple daily urine samples collected from preschool children in Washington State. J Expo Anal Environ Epidemiol 15(2):164–171.15187987
Knaak JB, Yee K, Ackerman CR, . 1984. Percutaneous absorption and dermal dose-cholinesterase response studies with parathion and carbaryl in the rat. Toxicol Appl Pharmacol 76(2):252–263.6437015
Kojima H, Katsura E, Takeuchi S, . 2004. Screening for estrogen and androgen receptor activities in 200 pesticides by in vitro reporter gene assays using Chinese hamster ovary cells. Environ Health Perspect 112(5):524–531.15064155
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Krapac IG, Roy WR, Smyth CA, . 1995. Occurrence and distribution of pesticides in soil at agrichemical facilities in Illinois. J Soil Contam 4(3):209–226.
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuntz DJ, Rao NG, Berg IE, . 1990. Toxicity of mixtures of parathion, toxaphene and/or 2,4-D in mice. J Appl Toxicol 10(4):257–266.2391407
Kutz FW, Yobs AR, Yang HSC. 1976. National pesticide monitoring programs. In: Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, 95–136.
Kwakman PJM, Vreuls JJ, Brinkman UA, . 1992. Determination of organophosphorus pesticides in aqueous samples by on-line membrane disk extraction and capillary gas chromatography. Chromatographia 34(1/2):41–47.
Lam RHF, Brown JP, Fan AM. 1994. Chemicals in California drinking water: Source of contamination, risk assessment, and drinking water standards. In: Wang RGM, ed. Water contamination and health. New York, NY: Marcel Dekker, Inc., 15–44.
Lambropoulou DA, Albanis TA. 2003. Headspace solid-phase microextraction in combination with gas chromatography-mass spectrometry for the rapid screening of organophosphorus insecticide residues in strawberries and cherries. J Chromatogr A 993:197–203.12735453
Lankisch PG, Muller CH, Niederstadt H, . 1990. Painless acute pancreatitis subsequent to anticholinesterase insecticide (parathion) intoxication. Am J Gastroenterol 85(7):872–875.2371989
Lartiges SB, Garrigues PP. 1995. Degradation kinetics of organophosphorus and organonitrogen pesticides in different waters under various environmental conditions. Environ Sci Technol 29(5):1246–1254.22192018
Lassiter TL, Ryde IT, Levin ED, . 2010. Neonatal exposure to parathion alters lipid metabolism in adulthood: Interactions with dietary fat intake and implications for neurodevelopmental deficits. Brain Res Bull 81(1):85–91.19615431
Lassiter TL, Ryde IT, MacKillop EA, . 2008. Exposure of neonatal rats to parathion elicits sex-selective reprogramming of metabolism and alters the response to a high-fat diet in adulthood. Environ Health Perspect 116:1456–1462.19057696
LeBel GL, Williams DT, Griffith G, . 1979. Isolation and concentration of organophosphorus pesticides from drinking water at the ng/L level, using macroreticular resin. J Assoc Off Anal Chem 62(2):241–249.447594
Lee P, Rhodes SL, Sinsheimer JS, . 2013. Functional paraoxonase 1 variants modify the risk of Parkinson’s disease due to organophosphate exposure. Environ Int 56:42–47.23602893
Lee SM, Papathakis ML, Feng HC, . 1991. Multipesticide residue method for fruits and vegetables: California Department of Food and Agriculture. Fresenius J Anal Chem 339:376–383.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leoni V. 1992. Multiresidue method for quantitation of organophosphorus pesticides in vegetable and animal foods. J Assoc Off Anal Chem Int 75(3):511–518.
Lessire F, Gustin P, Delaunois A, . 1996. Relationship between parathion and paraoxon toxicokinetics, lung metabolic activity, and cholinesterase inhibition in guinea pig and rabbit lungs. Toxicol Appl Pharmacol 138(2):201–210.8658521
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levin ED, Timofeeva OA, Yang L, . 2010. Early postnatal parathion exposure in rats causes sex-selective cognitive impairment and neurotransmitter defects which emerge in aging. Behav Brain Res 208(2):319–327.20015457
Lewis RG, Lee RE, Jr. 1976. Air pollution from pesticides. In: Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, 5–51.
Liao W, Joe T, Cusick WG. 1991. Multiresidue screening method for fresh fruits and vegetables with gas chromatographic/mass spectrometric detection. J Assoc Off Anal Chem 74(3):554–565.1874703
Liu J, Gupta RC, Goad JT, . 2007. Modulation of parathion toxicity by glucose feeding: Is nitric oxide involved? Toxicol Appl Pharmacol 219(2–3):106–113.17178140
Liu J, Karanth S, Pope C. 2005. Dietary modulation of parathion-induced neurotoxicity in adult and juvenile rats. Toxicology 210(2–3):135–145.15840427
Liu Y, Shen D, Li S, . 2016. Residue levels and risk assessment of pesticides in nuts of China. Chemosphere 144:645–651.26408971
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lores EM, Bradway DE, Moseman RF. 1978. Organophosphorus pesticide poisonings in humans: Determination of residues and metabolites in tissues and urine. Arch Environ Health 33(5):270–276.81664
Luke MA, Masumoto HT, Cairns T, . 1988. Levels and incidences of pesticide residues in various foods and animal feeds analyzed by the Luke Multiresidue Methodology for fiscal years 1982–1986. J Assoc Off Anal Chem 71(2):415–420.3384794
Ma T, Chambers JE. 1994. Kinetic parameters of desulfuration and dearylation of parathion and chlorpyrifos by rat liver microsomes. Food Chem Toxicol 32(8):763–767.7520881
MacCrawford J, Hoppin JA, Alavanja MCR, . 2008. Hearing loss among licensed pesticide applicators in the Agricultural Health Study. J Occup Environ Med 50(7):817–826.18617838
Maddy KT, Fong HR, Lowe JA, . 1982. A study of well water in selected California communities for residues of 1,3-dichloropropene, chloroallyl alcohol and 49 organophosphate or chlorinated hydrocarbon pesticides. Bull Environ Contam Toxicol 29(3):354–359.7126926
Maibach HI, Feldman RJ, Milby TH, . 1971. Regional variation in percutaneous penetration in man. Pesticides. Arch Environ Health 23(3):208–211.5123154
Mamta, Rao RJ, Wani KA. 2015a. Concentration of organochlorine and organophophorus pesticides in different molluscs from Tighra reservoir, Gwalior, India. Bull Environ Contam Toxicol 95:332–339.26174029
Mamta, Rao RJ, Wani KA. 2015b. Monitoring of organochlorine and organophosphorus pesticide residues in water during different seasons of Tighra reservoir Gwalior, Madhya Pragesh, India. Environ Monit Assess 187:684. 10.1007/s10661-015-4889-4.26456838
Mansour M, Thaller S, Korte F. 1983. Action of sunlight on parathion. Bull Environ Contam Toxicol 30(3):358–364.6850122
Manthripragada AD, Costello S, Cockburn MG, . 2010. Paraoxonase 1, agricultural organophosphate exposure, and Parkinson disease. Epidemiology 21(1):87–94.19907334
Maroni . 2000. Organophosphorous pesticides. Toxicology 143:9–37.
Mattern GC, Louis JB, Rosen JD. 1991. Multipesticide determination in surface water by gas chromatography/chemical ionization/mass spectrometry/ion trap detection. J Assoc Off Anal Chem 74(6):982–986.
Maxwell DM, Lenz DE, Groff WA, . 1987. The effects of blood flow and detoxification on in vivo cholinesterase inhibition by soman in rats. Toxicol Appl Pharmacol 88:66–76.3564032
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
Medina D, Prieto A, Ettiene G, . 1999. Persistence of organophosphorus pesticide residues in Limon River waters. Bull Environ Contam Toxicol 63:39–44.10423481
Mehrani H, Asadi B, Golmanesh L. 2008. Protective effects of mecamylamine and atropine against α_4_β_2_ nicotinic receptor expression and functional toxicity in paraoxon-treated rats. Environ Toxicol Pharmacol 26: 247–254.21791372
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Milby TH, Ottoboni F, Mitchell HW. 1964. Parathion residue poisoning among orchard workers. J Am Med Assoc 189(5):351–356.
Miles JRW, Harris CR. 1978. Insecticide residues in organic soils of six vegetable growing areas in southwestern Ontario, 1976. J Environ Sci Health B13(3):199–209.
Miles JRW, Tu CM, Harris CR. 1979. Persistence of eight organophosphorus insecticides in sterile and non-sterile mineral and organic soils. Bull Environ Contam Toxicol 22:312–318.465800
Miller MA, Kasting GB. 2010. Toward a better understanding of pesticide dermal absorption: Diffusion model analysis of parathion absorption in vitro and in vivo. J Toxicol Environ Health A 73(4):284–300.20077298
Mingelgrin U, Gerstl Z. 1983. Reevaluation of partitioning as a mechanism of nonionic chemicals adsorption in soils. J Environ Qual 12(1):1–11.
Mohn G. 1973. 5-Methyltryptophan resistance mutations in Escherichia coli K-12. Mutagenic activity of monofunctional alkylating agents including organophosphorus insecticides. Mutat Res 20(1):7–15.4357387
Moody RP, Akram M, Dickson E, . 2007. In vitro dermal absorption of methyl salicylate, ethyl parathion, and malathion: First responder safety. J Toxicol Environ Health A 70(12):985–999.17497409
Moreale A, Van Bladel R. 1983. [Transport vertical de solutés vers les eaux souterraines. Une approche sur colonne de sol non perturbé]. Rev Agric 6:1669–1676. (French)
Morgan DP, Hetzler HL, Slach EF, . 1977. Urinary excretion of paranitrophenol and alkyl phosphates following ingestion of methyl or ethyl parathion by human subjects. Arch Environ Contam Toxicol 6(2–3):159–173.900999
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Moser VC. 1995. Comparisons of the acute effects of cholinesterase inhibitors using a neurobehavioral screening battery in rats. Neurotoxicol Teratol 17(6):617–625.8747743
Mota LC, Hernandez JP, Baldwin WS. 2010. Constitutive androgen receptor-null mice are sensitive to the toxic effects of parathion: Association with reduced cytochrome p450-mediated parathion metabolism. Drug Metab Dispos 38(9):1582–1588.20573718
Musshoff F, Junker H, Madea B. 2002. Simple determination of 22 organophosphorous pesticides in human blood using headspace solid-phase microextraction and gas chromatography with mass spectrometric detection. J Chromatogr Sci 40:29–34.11866384
Mutch E, Williams FM. 2006. Diazinon, chlorpyrifos and parathion are metabolised by multiple cytochromes P450 in human liver. Toxicology 224(1–2):22–32.16757081
Mutch E, Blain PG, Williams FM. 1999. The role of metabolism in determining susceptibility to parathion toxicity in man. Toxicol Lett 107(1–3):177–187.10414794
Mutch E, Daly AK, Leathart JB, . 2003. Do multiple cytochrome P450 isoforms contribute to parathion metabolism in man? Arch Toxicol 77(6):313–320.12669189
Nabb DP, Stein WJ, Hayes WJ, Jr. 1966. Rate of skin absorption of parathion and paraoxon. Arch Environ Health 12(4):501–505.5906458
Namba T, Nolte CT, Jackrel J, . 1971. Poisoning due to organophosphate insecticides. Acute and chronic manifestations. Am J Med 50(4):475–492.4324629
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NCI. 1979. Bioassay of parathion for possible carcinogenicity. National Cancer Institute. Tech Rep Ser 70:1–123.
Neal RA. 1967. Studies on the metabolism of diethyl 4-nitrophenyl phosphorothionate (parathion) in vitro. Biochem J 103(1):183–191.4382289
Needham LL, Blount B, Rogers HS, . 2000. Levels of selected nonpersistent endocrine disrupters in humans. ACS Symp Ser 747(Analysis of Environmental Endocrine Disruptors):147–157.
Nielsen P, Friis C, Gyrd-Hansen N, . 1991. Disposition of parathion in neonatal and young pigs. Pharmacol Toxicol 69(4):233–237.1956875
NIH. 2014. The Agricultural Health Study. National Institute of Health and National Institute of Environmental Health Sciences in collaboration with the U.S. Environmental Protection Agency and National Institute for Occupational Safety and Health. http://aghealth.nih.gov/. August 25, 2014.
NIOSH. 1974. Inhalation and oral studies of ethyl parathion administered acutely and sub-acutely to the rat and dog. National Institute of Occupational Safety and Health.
NIOSH. 1994. NIOSH manual of analytical methods. Method 5600 organophosphorus pesticides. National Institute of Occupational Safety and Health.
NIOSH. 2009. Phosphorothioic acid, O,O-diethyl O-(p-nitrophenyl) ester. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh-rtecs/tf456d70.html. July 26, 2013.
NIOSH. 2011. Parathion. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. April 24, 2013.
NIOSH. 2013. Phosphorothioic acid, 0,0-diethyl 0-(p-nitrophenyl) ester. National Institute for Occupational Safety and Health. http://ww.cdc.gov/niosh-rtecs/tf456d70.html. May 14, 2013.
Nishino R, Fukuyama T, Tajima Y, . 2013. Prior oral exposure to environmental immunosuppressive chemicals methoxychlor, parathion, or piperonyl butoxide aggravates allergic airway inflammation in NC/Nga mice. Toxicology 309: 1–8. 10.1016/j.tox.2013.03.018.23583882
Nishio A, Uyeki EM. 1981. Induction of sister chromatid exchanges in Chinese hamster ovary cells by organophosphate insecticides and their oxygen analogs. J Toxicol Environ Health 8(5–6):939–946.7338954
Nisse P, Forceville X, Cezard C, . 1998. Intermediate syndrome with delayed distal polyneuropathy from ethyl parathion poisoning. Vet Hum Toxicol 40(6):349–352.9830697
Noort D, Hulst AG, van Zuylen A, . 2009. Covalent binding of organophosphorothioates to albumin: A new perspective for OP-pesticide biomonitoring? Arch Toxicol 83(11):1031–1036.19575182
Norman BJ, Neal RA. 1976. Examination of the metabolism in vitro of parathion (diethyl p-nitrophenyl phosphorothionate) by rat lung and brain. Biochem Pharmacol 25(1):37–45.1252255
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council.
NRC. 2004. Executive summary and recommendations. In: Intentional human dosing studies for EPA regulatory purposes: Scientific and ethical issues. National Research Council. National Academy of Sciences, 1–20. http://www.nap.edu/catalog.php?record_id=10927. May 14, 2014.
NTP. 2011. Report on carcinogens. 12th edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. April 24, 2013.
Olivier K, Liu J, Karanth S, . 2001. Glucose feeding exacerbates parathion-induced neurotoxicity. J Toxicol Environ Health A 63:253–271.11437059
Olsson AO, Nguyen JV, Sadowski MA, . 2003. A liquid chromatography/electrospray ionization-tandem mass spectrometry method for quantification of specific organophosphorus pesticide biomarkers in human urine. Anal Bioanal Chem 376(6):808–815.12811448
O’Neil MJ, Heckelman PE, Dobbelaar PH, . 2013. Parathion. In: O’Neil MJ, Heckelman PE, Dobbelaar PH, . eds. The Merck index. An encyclopedia of chemicals drugs, and biologicals. 15th ed. Whitehouse Station, NJ: RSC Publishing, 1306.
Oneto ML, Basack SB, Kesten EM. 1995. Total and conjugated urinary paranitrophenol after an acute parathion ingestion. Sci Justice 35(3):207–211.7663993
OSHA. 1986. Chlorpyrifos (dursban), DDVP (dichlorvos), diazinon, malathion, and parathion. Occupational Safety and Health Administration, U.S. Department of Labor. http://www.osha.gov/dts/sltc/methods/organic/org062/org062.html. March 02, 2006.
OSHA. 2013a. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.119, Appendix A. http://www.osha.gov/law-regs.html. April 24, 2013.
OSHA. 2013b. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z-1. http://www.osha.gov/law-regs.html. April 24, 2013.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Ownby DR, Trimble TA, Cole KA, . 2004. Pesticide residues in water, sediment, and fish at the Sparta, IL, USA, National Guard Armory. Bull Environ Contam Toxicol 73:802–809.15669722
Padungtod C, Savitz DA, Overstreet JW, . 2000. Occupational pesticide exposure and semen quality among Chinese workers. J Occup Environ Med 42(10):982–992.11039162
Pasquet J, Mazuret A, Fournel J, . 1976. Acute oral and percutaneous toxicity of phosalone in the rat, in comparison with azinphosmethyl and parathion. Toxicol Appl Pharmacol 37(1):85–92.968909
Pauluhn J, Machemer L, Kimmerle G. 1987. Effects of inhaled cholinesterase inhibitors on bronchial tonus and on plasma and erythrocyte acetylcholine esterase activity in rats. Toxicology 46(2):177–190.3672530
Petrikovics I, Hong K, Omburo G, . 1999. Antagonism of paraoxon intoxication by recombinant phosphotriesterase encapsulated within sterically stabilized liposomes. Toxicol Appl Pharmacol 156(1):56–63.10101099
PhysProp. 2013. Parathion. http://www.syrres.com/what-we-do/databaseforms.aspx?id=386. June 05, 2013.
Pla A, Johnson MK. 1989. Degradation by rat tissues in vitro of organophosphorus esters which inhibit cholinesterase. Biochem Pharmacol 38(9):1527–1533.2719724
Plastourgou M, Hoffmann MR. 1984. Transformation and fate of organic esters in layered-flow systems: The role of trace metal catalysis. Environ Sci Technol 18(10):756–764.
Poore RE, Neal RA. 1972. Evidence for extrahepatic metabolism of parathion. Toxicol Appl Pharmacol 23:759–768.4644705
Pope CN, Chakraborti TK. 1992. Dose-related inhibition of brain and plasma cholinesterase in neonatal and adult rats following sublethal organophosphate exposures. Toxicology 73(1):35–43.1375401
Pope CN, Chakraborti TK, Chapman ML, . 1991. Comparison of in vivo cholinesterase inhibition in neonatal and adult rats by three organophosphorothioate insecticides. Toxicology 68(1):51–61.1714639
Puga FR, Rodrigues MA. 1996. Evaluation of the role of formulation on parathion toxicity. Ecotoxicol Environ Saf 35(1):38–40.8930503
Qiao GL, Riviere JE. 1995. Significant effects of application site and occlusion on the pharmacokinetics of cutaneous penetration and biotransformation of parathion in vivo in swine. J Pharm Sci 84(4):425–432.7629731
Qiao GL, Brooks JD, Baynes RE, . 1996. The use of mechanistically defined chemical mixtures (MDCM) to assess component effects on the percutaneous absorption and cutaneous disposition of topically exposed chemicals. I. Studies with parathion mixtures in isolated perfused porcine skin. Toxicol Appl Pharmacol 141(2):473–486.8975772
Qiao GL, Williams PL, Riviere JE. 1994. Percutaneous absorption, biotransformation, and systemic disposition of parathion in vivo in swine. I. Comprehensive pharmacokinetic model. Drug Metab Dispos 22(3):459–471.8070325
Quinby GE, Lemmon AB. 1958. Parathion residues as a cause of poisoning in crop workers. J Am Med Assoc 166(7):740–746.13502056
Rao PSC, Hornsby AG, Jessup RE. 1985. Indices for ranking the potential for pesticide contamination of groundwater. Proceedings of the Soil and Crop Science Society of Florida 44:1–8.
Rauh V, Arunajadai S, Horton M, . 2011. Seven-year neurodevelopmental scores and prenatal exposure to chlorpyrifos, a common agricultural pesticide. Environ Health Perspect 119(8):1196–1201.21507777
Reiler E, Jors E, Baelum J, . 2015. The influence of tomato processing on residues of organochlorine and organophosphate insecticides and their associated dietary risk. Sci Total Environ 527–528:262–269. 10.1016/j.scitotenv.2015.04.081.25965039
Reischl P, Van Gelder GA, Karas GG. 1975. Auditory detection behavior in parathion-treated squirrel monkeys (Saimiri sciureus). Toxicol Appl Pharmacol 34(1):88–101.812210
Reiter L, Talens G, Woolley D. 1973. Acute and subacute parathion treatment: Effects on cholinesterase activities and learning in mice. Toxicol Appl Pharmacol 25(4):582–588.4741779
Reiter LW, Talens GM, Woolley DE. 1975. Parathion administration in the monkey: Time course of inhibition and recovery of blood cholinesterases and visual discrimination performance. Toxicol Appl Pharmacol 33(1):1–13.808881
Renhof M. 1984. Parathion. Study for embryotoxic effects on rats after oral administration. Report no. 12909. Wuppertal-Elberfeld: Bayer Institute of Toxicology.
Renhof M. 1985. Parathion. Study for embryotoxic effects on rabbits after oral administration. Report no. 13288. Wuppertal-Elberfeld: Bayer Institute of Toxicology.
RePORTER. 2013. Parathion. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. August 28, 2013.
Rider JA, Moeller HC, Puletti EJ, . 1969. Toxicity of parathion, systox, octamethyl pyrophosphoramide, and methyl parathion in man. Toxicol Appl Pharmacol 14(3):603–611.4306871
Roy RR, Wilson PD, Laski RR, . 1997. Monitoring of domestic and imported apples and rice by the U.S. Food and Drug Administration Pesticide Program. J Assoc Off Anal Chem Int 80(4):883–894.
Rupa DS, Rita P, Reddy PP, . 1988. Screening of chromosomal aberrations and sister chromatid exchanges in peripheral lymphocytes of vegetable garden workers. Hum Toxicol 7(4):333–336.3410481
Sabljić A, Güsten H, Verhaar H, . 1995. QSAR modelling of soil sorption. Improvements and systematics of log KOC vs. log KOW correlations. Chemosphere 31(11–12):4489–4514.
Saffih-Hdadi K, Bruckler L, Barriuso E. 2003. Modeling of sorption and biodegradation of parathion and its metabolite paraoxon in soil. J Environ Qual 32:2207–2211.14674543
Sakellarides TM, Siskos MG, Albanis TA. 2003. Photodegradation of selected organophosphorus insecticides under sunlight in different natural waters and soils. Int J Environ Anal Chem 83(1):33–50.
Saltzman S, Mingelgrin U. 1984. Nonbiological degradation of pesticides in the unsaturated zone. Ecol Stud 47:153–161.
Sanders PF, Seiber JN. 1983. A chamber for measuring volatilization of pesticides from model soil and water disposal systems. Chemosphere 12(7/8):999–1012.
Sanders PF, Seiber JN. 1984. Organophosphorus pesticide volatilization. Model soil pits and evaporation ponds. ACS Symposium Series. Treatment and disposal of pesticide wastes 259:279–295.
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286. 10.1016/j.tins.2008.03.003.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3(10.3389/fphar.2012.00046):Article 46. 10.3389/fphar.2012.00046.
Schattenberg HJ, III, Hsu JP. 1992. Pesticide residue survey of produce from 1989 to 1991. J AOAC Int 75(5):925–933.
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schulze JA, Manigold DB, Andrews FL. 1973. Pesticides in water. Pesticides in selected western streams, 1968–1971. Pestic Monit J 7(1):73–84.
Schuurmann G, Ebert R, Kuhne R. 2006. Prediction of the sorption of organic compounds into soil organic matter from molecular structure. Environ Sci Technol 40(22):7005–7011.17154008
Seiber JN, Woodrow JE. 1984. Airborne residues and human exposure. Stud Environ Sci 24:133–146.
Seiber JN, Glotfelty DE, Lucas AD, . 1990. A multiresidue method by high performance liquid chromatography-based fractionation and gas chromatographic determination of trace levels of pesticides in air and water. Arch Environ Contam Toxicol 19:583–592.2386412
Seiber JN, Wilson BW, McChesney MM. 1993. Air and fog deposition of four organophosphate insecticides used on dormant orchards in the San Joaquin Valley, California. Environ Sci Technol 27(10):2236–2243.
Senanayake N, Karalliedde L. 1987. Neurotoxic effects of organophosphorus insecticides. N Engl J Med 316:761–763.3029588
Sethunathan N, Siddaramappa R, Rajaram KP, . 1977. Parathion: Residues in soil and water. Residue Rev 68:91–122.337436
Sharom MS, Miles JRW, Harris CR, . 1980. Behavior of 12 insecticides in soil and aqueous suspensions of soil and sediment. Water Res 14:1095–1100.
Shehata-Karam H, Monteiro-Riviere NA, Guthrie FE. 1988. In vitro penetration of pesticides through human newborn foreskin. Toxicol Lett 40(3):233–239.3354007
Sigma-Aldrich. 2014. Parathion. 45607 Fluka. Sigma-Aldrich Co., LLC. http://www.sigmaaldrich.com/catalog/product/fluka/45607?lang=en&region=US. August 25, 2014.
Simcox NJ, Fenske RA, Wolz SA, . 1995. Pesticides in household dust and soil: Exposure pathways for children of agricultural families. Environ Health Perspect 103(12):1126–1134.8747019
Simmon VF, Poole DC, Newell GW. 1976. In vitro mutagenic studies of twenty pesticides. Toxicol Appl Pharmacol 37:109.
Slotkin TA. 2011. Does early-life exposure to organophosphate insecticides lead to prediabetes and obesity? Reprod Toxicol 31(3):297–301.20850519
Slotkin TA, Bodwell BE, Ryde IT, . 2008. Exposure of neonatal rats to parathion elicits sex-selective impairment of acetylcholine systems in brain regions during adolescence and adulthood. Environ Health Perspect 116(10):1308–1314.18941570
Slotkin TA, Lassiter TL, Ryde IT, . 2009c. Consumption of a high-fat diet in adulthood ameliorates the effects of neonatal parathion exposure on acetylcholine systems in rat brain regions. Environ Health Perspect 117(6):916–922.19590683
Slotkin TA, Levin ED, Seidler FJ. 2006a. Comparative developmental neurotoxicity of organophosphate insecticides: Effects on brain development are separable from systemic toxicity. Environ Health Perspect 114(5):746–751.16675431
Slotkin TA, Levin ED, Seidler FJ. 2009a. Developmental neurotoxicity of parathion: Progressive effects on serotonergic systems in adolescence and adulthood. Neurotoxicol Teratol 31(1):11–17.18773955
Slotkin TA, Tate CA, Ryde IT, . 2006b. Organophosphate insecticides target the serotonergic system in developing rat brain regions: Disparate effects of diazinon and parathion at doses spanning the threshold for cholinesterase inhibition. Environ Health Perspect 114(10):1542–1546.17035140
Slotkin TA, Wrench N, Ryde IT, . 2009b. Neonatal parathion exposure disrupts serotonin and dopamine synaptic function in rat brain regions: Modulation by a high-fat diet in adulthood. Neurotoxicol Teratol 31(6):390–399.19616088
Spencer WF, Shoup TD, Clisth MM, . 1979. Vapor pressures and relative volatility of ethyl and methyl parathion. J Agric Food Chem 27(2):273–278.
Srivastava SP, Agarwal DK, Mushtaq M, . 1976. Interaction of di-2-ethylhexyl phthalate (DEHP) with parathion in rats. Chemosphere 5(3):177–181.
Stamper CR, Balduini W, Murphy SD, . 1988. Behavioral and biochemical effects of postnatal parathion exposure in the rat. Neurotoxicol Teratol 10(3):261–266.3211105
Stanley CW, Barney JE, Helton MR, . 1971. Measurement of atmospheric levels of pesticides. Environ Sci Technol 5(5):430–435.
Starks SE, Gerr F, Kamel F, . 2012a. Neurobehavioral function and organophosphate insecticide use among pesticide applicators in the Agricultural Health Study. Neurotoxicol Teratol 34(1):168–176. 10.1016/j.ntt.2011.08.014.21907279
Starks SE, Hoppin JA, Kamel F, . 2012b. Peripheral nervous system function and organophosphate pesticide use among licensed pesticide applicators in the Agricultural Health Study. Environ Health Perspect 120(4): 515–520.22262687
Starling AP, Umbach DM, KAmel F, . 2014. Pesticide use and incident diabetes among wives of farmers in the Agricultural Health Study. Occup Environ Med 71(9):629–635. 10.1136/oemed-2013-101659.24727735
Steiniger D, Lu G, Butler J, . 2010. Determination of multiresidue pesticides in green tea by using a modified QuEChERS extraction and ion-trap gas chromatography/mass spectrometry. J AOAC Int 93(4):1169–1179.20922949
Stewart DKR, Chisholm, Regab MTH. 1971. Long term persistence of parathion in soil. Nature 229(5279):7.4922798
Sullivan JB, Krieger GR. 2001. Clinical environmental health and toxic exposures. Philadelphia, PA: Lippincott Williams & Wilkins, 1053.
Sultatos LG. 1986. The effects of phenobarbital pretreatment on the metabolism and acute toxicity of the pesticide parathion in the mouse. Toxicol Appl Pharmacol 86(1):105–111.3764930
Sultatos LG. 1990. A physiologically based pharmacokinetic model of parathion based on chemical-specific parameters determined in vitro. J Am Coll Toxicol 9(6):611–619.
Sultatos LG. 1994. Mammalian toxicology of organophosphorus pesticides. J Toxicol Environ Health 43:271–289.7966438
Sultatos LG, Minor LD. 1986. Factors affecting the biotransformation of the pesticide parathion by the isolated perfused mouse liver. Drug Metab Dispos 14(2):214–220.2870897
Swoboda AR, Thomas GW. 1968. Movement of parathion in soil columns. J Agric Food Chem 16(6):923–927. 10.1021/jf60160a018.
Tafuri J, Roberts J. 1987. Organophosphate poisoning. Ann Emerg Med 16:193–202.3541700
Tamura H, Yoshikawa H, Gaido KW, . 2003. Interaction of organophosphate pesticides and related compounds with the androgen receptor. Environ Health Perspect 111(4):545–552.12676613
Tang J, Rose RL, Chambers JE. 2006. Metabolism of organophosphorus and carbamate pesticides. In: Gupta RC, ed. Toxicology of organophosphate and carbamate compounds. Burlington, MA: Elsevier Academic Press, 127–143.
Tateishi T, Nakura H, Asoh M, . 1997. A comparison of hepatic cytochrome P450 protein expression between infancy and postinfancy. Life Sci 61(26):2567–2574.9416779
Tessari JD, Spencer DL. 1971. Air sampling for pesticides in the human environment. J Assoc Off Anal Chem 54(6):1376–1382.5151704
Thomas JA, Schein LG. 1974. Effect of parathion on the uptake and metabolism of androgens in rodent sex accessory organs. Toxicol Appl Pharmacol 29:53–58.4283680
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton NJ: Princeton Scientific Publishing, 365–394.
Timofeeva OA, Sanders D, Seemann K, . 2008. Persistent behavioral alterations in rats neonatally exposed to low doses of the organophosphate pesticide, parathion. Brain Res Bull 77(6):404–411.18817854
Tomlin CDS. 2010. Parathion. In: The e-pesticide manual. 15th ed. British Crop Production Council.
Toyoda M, Adachi K, Ida T, . 1990. Simple analytical method for organophosphorus pesticide residues in milk. J Assoc Off Anal Chem 73(5):770–772.2273003
TRI14 2015. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. October 21, 2015.
Triolo AJ, Coon JM. 1966. The protective effect of aldrin against the toxicity of organophosphate anticholinesterases. J Pharmacol Exp Ther 154(3):613–623.4288901
Tsachalinas D, Logaras, Paradelis A. 1971. Observations on two hundred forty six cases of acute poisoning with parathion in Greece. Eur J Toxicol 4:46–49.5092667
Tsuda T, Aoki S, Inoue T, . 1995. Accumulation of IBP, parathion and EPN by killifish: Comparison of individual and mixed pesticides. Comp Biochem Physiol C 111(1):19–22.
USDA. 2016. Pesticide data program. Annual summary, calendar year 2014. U.S. Department of Agriculture. https://www.ams.usda.gov/sites/default/files/media/2014%20PDP%20Annual%20Summary.pdf. February 25, 2016.
USGS. 2002a. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory. Determination of organophosphate pesticides in filtered water by gas chromatography with flame photometric detection. Water-resource investigation report 02-4071. U.S. Geological Survey, U.S. Department of the Interior.
USGS. 2002b. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory. Determination of organophosphate pesticides in whole water by continuous liquid-liquid extraction and capillary-column gas chromatography with flame photometric detection. U.S. Geological Survey Method 0-3402-03. U.S. Geological Survey, U.S. Department of the Interior.
USGS. 2002c. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory. Determination of organophosphate pesticides in bottom sediment by gas chromatography with flame photometric detection. Water-resources investigation report 02-4222. U.S. Geological Survey, U.S. Department of the Interior.
USGS. 2007. Pesticides in the nation’s streams and ground water, 1992-2001. U.S. Geological Survey, National Water-Quality Assessment Program.
van den Beukel I, van Kleef RG, Oortgiesen M. 1998. Differential effects of physostigmine and organophosphates on nicotinic receptors in neuronal cells of different species. Neurotoxicology 19(6):777–787.9863767
van der Merwe D, Brooks JD, Gehring R, . 2006. A physiologically based pharmacokinetic model of organophosphate dermal absorption. Toxicol Sci 89(1):188–204.16221965
Velasco A, Hernández S, Ramírez M, . 2014. Detection of residual organochlorine and organophosphorus pesticides in agricultural soil in Rio Verde region of San Luis Potosi, Mexico. J Environ Sci Health B 49(7):498–504. 10.1080/03601234.2014.896670.24813984
Veronesi B, Pope C. 1990. The neurotoxicity of parathion-induced acetylcholinesterase inhibition in neonatal rats. Neurotoxicology 11(4):609–626.2087286
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Villeneuve DC, Grant DL, Phillips WE, . 1971. Effects of PCB administration on microsomal enzyme activity in pregnant rabbits. Bull Environ Contam Toxicol 6(2):120–128.5005161
Villeneuve DC, vanLogten MJ, denTonkelaar EM, . 1978. The combined effect of food restriction and parathion exposure in rats. Arch Environ Contam Toxicol 7(1):37–45.666365
Vogtmann H, Fragstein PV, Draeger P. 1983. The degradation of agrochemicals during composting. Second International Symposium Bet Degan, Israel, 357–377.
Wade MJ. 1979. Organophosphorus pesticides in the marine environment: Their transport and fate. Diss Abst Int 40:4704–4705.
Waldron AC. 1974. Pesticide movement from cropland into Lake Erie. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development.
Wallace KB, Dargan JE. 1987. Intrinsic metabolic clearance of parathion and paraoxon by livers from fish and rodents. Toxicol Appl Pharmacol 90:235–242.3629599
Wan MT, Szeto S, Price P. 1994. Organophosphorus insecticide residues in farm ditches of the Lower Fraser Valley of British Columbia. J Environ Sci Health B29(5):917–949.
Wan MT, Szeto SY, Price P. 1995. Distribution and persistence of azinphos-methyl and parathion in chemigated cranberry bogs. J Environ Qual 24:589–596.
Ware GW, Morgan DP, Estesen BJ, . 1973. Establishment of reentry intervals for organophosphate-treated cotton fields based on human data. I. Ethyl- and methyl parathion. Arch Environ Contam Toxicol 1(1):48–59.4775398
Ware GW, Morgan DP, Estesen BJ, . 1974. Establishment of reentry intervals for organophosphate-treated cotton fields based on human data. II. Azodrin, ethyl and methylparathion. Arch Environ Contam Toxicol 2(2):117–129.4851905
Weitman SD, Vodicnik MJ, Lech JJ. 1983. Influence of pregnancy on parathion toxicity and disposition. Toxicol Appl Pharmacol 71(2):215–224.6636186
Weitman SD, Vodicnik MJ, Lech JJ. 1986. Mechanism of enhanced parathion-paraoxon toxicity during pregnancy in the mouse. Fundam Appl Toxicol 6(1):155–161.3710020
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Wester RC, Maibach HI. 1985. In vivo percutaneous absorption and decontamination of pesticides in humans. J Toxicol Environ Health 16:25–37.4068054
Wester RM, Tanojo H, Maibach HI, . 2000. Predicted chemical warfare agent VX toxicity to uniformed soldier using parathion in vitro human skin exposure and absorption. Toxicol Appl Pharmacol 168(2):149–152.11032770
WHO. 2005. The WHO recommended classification of pesticides by hazard and guidelines to classification 2004. Geneva, Switzerland: World Health Organization.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 24, 2013.
WHO. 2011. Guidelines for drinking-water quality. 4th Edition. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/publications/2011/dwq_guidelines/en/index.html. April 24, 2013.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York NY: Academic Press, 1–247.
Williams PL, Carver MP, Riviere JE. 1990. A physiologically relevant pharmacokinetic model of xenobiotic percutaneous absorption utilizing the isolated perfused porcine skin flap. J Pharm Sci 79(4):305–311.2352140
Wiltrout RW, Ercegovich CD, Ceglowski WS. 1978. Humoral immunity in mice following oral administration of selected pesticides. Bull Environ Contam Toxicol 20(3):423–431.708932
Winterlin W, Seiber JN, Craigmill A, . 1989. Degradation of pesticide waste taken from a highly contaminated soil evaporation pit in California. Arch Environ Contam Toxicol 18:734–747.
Wishahi A, Aboul-Dahab YW, Sherif Y, . 1958. Parathion poisoning (phosphorus compound): A report on 22 children in an outbreak. Arch Pediatr 75(9):387–396.
Wolfe HR. 1976. Field exposure to airborne pesticides. In: Air pollution pesticides and agricultural processes. Cleveland, OH: CRC Press, 137–163.
Wolfe HR, Durham WF, Armstrong JF. 1967. Exposure of workers to pesticides. Arch Environ Health 14:622–633.6024487
Wolfe HR, Durham WF, Armstrong JF. 1970. Urinary excretion of insecticide metabolites. Excretion of para-nitrophenol and DDA as indicators of exposure to parathion. Arch Environ Health 21(6):711–716.5478556
Wolfe HR, Staiff DC, Armstrong JF, . 1973. Persistence of parathion in soil. Bull Environ Contam Toxicol 10(1):1–9.
Woodrow JE, Crosby DG, Mast T, . 1978. Rates of transformation of trifluralin and parathion vapors in air. J Agric Food Chem 26(6):1312–1316.
Woodrow JE, Crosby DG, Seiber JN. 1983. Vapor-phase photochemistry of pesticides. Residue Rev 85:111–125.
Xu LC, Liu L, Ren XM, . 2008. Evaluation of androgen receptor transcriptional activities of some pesticides in vitro. Toxicology 243(1–2):59–65.17980950
Yang L, Li H, Zeng FQ, . 2012. Determination of 49 organophosphorus pesticide residues and their metabolites in fish, egg, and milk by dual gas chromatography- dual pulse flame photometric detection with gel permeation chromatography cleanup. J Agric Food Chem 60:1906–1913. 10.1021/jf2043828.22300587
Yao Y, Harner T, Blanchard P, . 2008. Pesticides in the atmosphere across Canadian agricultural regions. Environ Sci Technol 42(16):5931–5937.18767647
Yaron B. 1975. Chemical conversion of parathion on soil surfaces. Soil Sci Soc Am Proc 39:639–643.
Yasoshima M, Masuda Y. 1986. Effect of carbon disulfide on the anticholinesterase action of several organophosphorus insecticides in mice. Toxicol Lett 32(3):179–184.3775801
Yess NJ, Gunderson EL, Roy RR. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J Assoc Off Anal Chem Int 76(3):492–507.
Zabik JM, Seiber JN. 1993. Atmospheric transport of organophosphate pesticides from California’s Central Valley to the Sierra Nevada Mountains. J Environ Qual 22:80–90.
Zegers BN, Hogenboom AC, Dekkers SEG, . 1994. Packed capillary supercritical fluid chromatography of organophosphorus pesticides: Selective detection and applications. J Microcol Sep 6(1):55–62.
Zepp RG, Baughman GL. 1978. Prediction of photochemical transformation of pollutants in the aquatic environment. In: Hutzinger O, Van Lelyveld IH, Zoeteman BCJ, eds. Aquatic pollutants. Transformation and biological effects. Oxford: Pergamon Press 237–263.
Zhang HX, Sultatos LG. 1991. Biotransformation of the organophosphorus insecticides parathion and methyl parathion in male and female rat livers perfused in situ. Drug Metab Dispos 19(2):473–477.1676657
Zhao X, Hwang HM. 2009. A study of the degradation of organophosphorus pesticides in river waters and the identification of their degradation products by chromatography coupled with mass spectrometry. Arch Environ Contam Toxicol 56(4):646–653.18752016
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372