# PEER REVIEW

A peer review panel was assembled for parathion. The panel consisted of the following members:

1. Dr. Edward Levin, Psychology and Behavioral Sciences, School of Medicine, Duke University, Durham, North Carolina;
2. Dr. Falicia Edwards, Center for Environmental Health, College of Science, Engineering and Technology, Jackson State University, Jackson, Mississippi; and
3. Dr. Asa Bradman, Center for Environmental Research and Children’s Health (CERCH), School of Public Health, University of California, Berkeley, Berkeley, California.

These experts collectively have knowledge of parathion’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.