# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an intermediate-duration inhalation MRL of 20 ng/m^3^ for parathion based on a NOAEL of 0.01 mg/m^3^ for neurological effects in rats (NIOSH 1974). The MRL was derived by dividing the duration-adjusted NOAEL by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

ATSDR has derived an intermediate-duration oral MRL of 0.009 mg/kg/day for parathion based on a NOAEL of 0.09 mg/kg/day for neurological effects in humans (Rider et al. 1969). The MRL was derived by dividing the NOAEL by an uncertainty factor of 10 (for human variability).

IARC has classified parathion as a Group 3 carcinogen (not classifiable as to its carcinogenicity to humans) (IARC 2013). The World Health Organization (WHO) has not established any air quality guidelines for parathion (WHO 2010). A water quality guideline value was not established for parathion because it occurs in drinking water at concentrations well below those of health concern (WHO 2011).

OSHA has established an enforceable permissible exposure limit (PEL) of 0.1 mg/m^3^ for parathion (OSHA 2013b). OSHA has required employers of workers who are occupationally exposed to parathion to institute engineering controls and work practices to reduce and maintain employee exposure at or below the PEL. NIOSH has established a recommended exposure limit (REL) of 0.05 mg/m^3^ and an immediately dangerous to life or health (IDLH) value of 10 mg/m^3^ (NIOSH 2013). The American Conference of Governmental Industrial Hygienists (ACGIH) has recommended a threshold limit value (TLV) of 0.05 mg/m^3^ for an 8-hour workday (ACGIH 2012).

The Department of Energy (DOE) has established protective action criteria (PAC-1, -2, and -3) values of 0.15, 1.5, and 2.0 mg/m^3^, respectively, for airborne parathion when responding to potential releases for use in community emergency planning (DOE 2016b). These values represent increasing severity of effects (mild, irreversible, and life-threatening) for a 1-hour exposure.

EPA has classified parathion as a Group C carcinogen (possible human carcinogen) (IRIS 2003) and ACGIH (2012) has classified parathion as an A4 carcinogen (not classified as to human carcinogenicity). The National Toxicology Program (NTP) has not classified parathion as a human carcinogen (NTP 2011). EPA has not derived an oral reference dose (RfD) or a chronic inhalation reference concentration (RfC) for parathion (IRIS 2003).

EPA has designated parathion as a hazardous air pollutant (HAP) under the Clean Air Act (CAA) (EPA 2013b). Parathion is on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986” and has been assigned a reportable quantity (RQ) limit of 10 pounds (EPA 2012f). Parathion is also considered to be an extremely hazardous substance (EPA 2012g). The RQ represents the amount of a designated hazardous substance which, when released to the environment, must be reported to the appropriate authority.

The international and national regulations, advisories, and guidelines regarding parathion in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Parathion

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 3^a^ | IARC 2013
WHO | Air quality guidelines | No data | WHO 2010
WHO | Drinking water quality guidelines | No data^b^ | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA)^c,d^ | 0.05 mg/m^3^ | ACGIH 2012
AIHA | ERPG-1, -2, -3 | No data | AIHA 2011
DOE | PAC-1^e^ | 0.15 mg/m^3^ | DOE 2016b
DOE | PAC-2 | 1.5 mg/m^3^
DOE | PAC-3 | 2.0 mg/m^3^
EPA | AEGL-1^f^ | Not recommended due to insufficient data | EPA 2013a
EPA | AEGL-2
EPA | 10-minutes | 2.8 mg/m^3^
EPA | 30-minutes | 1.9 mg/m^3^
EPA | 60-minutes | 1.5 mg/m^3^
EPA | 4-hours | 0.96 mg/m^3^
EPA | 8-hours | 0.48 mg/m^3^
EPA | AEGL-3
EPA | 10-minutes | 3.6 mg/m^3^
EPA | 30-minutes | 2.5 mg/m^3^
EPA | 60-minutes | 2.0 mg/m^3^
EPA | 4-hours | 1.3 mg/m^3^
EPA | 8-hours | 0.63 mg/m^3^
EPA | Hazardous air pollutant | Yes | EPA 2013b; 42 USC 7412
EPA | NAAQS | No data | EPA 2013e
NIOSH | REL (10-hour TWA)^g^ | 0.05 mg/m^3^ | NIOSH 2011
NIOSH | IDLH | 10 mg/m^3^
OSHA | PEL (8-hour TWA) for general industry^h^ | 0.1 mg/m^3^ | OSHA 2013b; 29 CFR 1910.1000, Table Z-1
OSHA | Highly hazardous chemicals | No data | OSHA 2013a; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2012a; 40 CFR 116.4
EPA | Drinking water contaminant candidate list | No data | EPA 2009a; 74 FR 51850
EPA | Drinking water standards and health advisories | No data | EPA 2012b
EPA | National primary drinking water standards | No data | EPA 2009b
EPA | National recommended water quality criteria for freshwater | | EPA 2009c
EPA | Criteria maximum concentration (acute) | 0.065 μg/L
EPA | Criterion continuous concentration (chronic) | 0.013 μg/L
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 10 pounds | EPA 2012d; 40 CFR 117.3
c. Food
FDA | EAFUS^i^ | No | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | A4^j^ | ACGIH 2012
ACGIH | BEI
ACGIH | Total p-nitrophenol in urine (end of shift end) | 0.5 mg/g creatinine
ACGIH | Cholinesterase activity in red blood cells (discretionary) | 70% of individual’s baseline
EPA | Carcinogenicity classification | Group C^k^ | IRIS 2003
EPA | RfC | No data
EPA | RfD | No data
EPA | Identification and listing of hazardous waste | P089 | EPA 2012c; 40 CFR 261, Appendix VIII
EPA | Inert pesticide ingredients in pesticide products approved for nonfood use only | No data | EPA 2013c
EPA | Master Testing List | No data | EPA 2013d
EPA | RCRA waste minimization PBT priority chemical list | No data | EPA 1998; 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | Yes | EPA 2012e; 40 CFR 264, Appendix IX
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity pursuant to Section 311 (b)(2) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA | 10 pounds | EPA 2012f; 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | 01/01/1987 | EPA 2012h; 40 CFR 372.65
EPA | Extremely hazardous substances and its threshold planning quantity | | EPA 2012g; 40 CFR 355, Appendix A
EPA | Reportable quantity | 10 pounds | EPA 2012g; 40 CFR 355, Appendix A
EPA | Threshold planning quantity | 100 pounds | EPA 2012g; 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | No data | EPA 2012i; 40 CFR 712.30
EPA | TSCA health and safety data reporting | No data | EPA 2012j; 40 CFR 716.120
NTP | Carcinogenicity classification | No data | NTP 2011

a Group 3: Unclassifiable as to carcinogenicity to humans.

b A guideline value was not established for parathion because it occurs in drinking-water at concentrations well below those of health concern (WHO 2011).

c lnhalable fraction and vapor; material exerts sufficient vapor pressure such that it may be present in both particles and vapor phases, with each contributing a significant portion of the dose at the TLV-TWA concentration (ACGIH 2012).

d Skin designation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, by contact with vapors, liquids, and solids (ACGIH 2012).

e PAC-1: mild, transient health effects; PAC-2: irreversible or other serious health effects that could impair the ability to take protective action; PAC-3: life-threatening health effects (DOE 2016a).

f AEGL-1: the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic, nonsensory effects; however, these effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2: the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting, adverse health effects or an impaired ability to escape; AEGL-3: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening adverse health effects or death (EPA 2013a).

g Skin designation indicates the potential for dermal absorption; skin exposure should be prevented as necessary through the use of good work practices, gloves, coveralls, goggles, and other appropriate equipment (NIOSH 2011).

h Skin designation.

i The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

j A4: Not classified as a human carcinogen.

k Group C: possible human carcinogen.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; BEI = biological exposure indices; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization