# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of parathion is located in Table 4-1.

In the United States, parathion was sold in the form of emulsion concentrates, wettable powders, granules, dusts, aerosols, and oil sprays (Farm Chemicals Handbook 1987). In 1991, parathion became a restricted use pesticide and was formulated as Parathion EC and Ethyl Methyl Parathion 6-3, which were liquid, emulsifiable concentrates and applied using aerial equipment. Manufacture of parathion for manufacturing use products was discontinued as of September 2000, and manufacture of all end use products were discontinued effective December 31, 2002 (EPA 2000). Internationally, parathion may be formulated as an aerosol, capsule suspension, dustable powder, emulsifiable concentrate, granule, and wettable powder. Formulations range from a 1% dust to an 83.5% concentrate. The technical-grade material is 98% pure (FAO 1997).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of parathion is located in Table 4-2.

Table 4-1 Chemical Identity of Parathion

Characteristic | Information | Reference
Chemical name | O,O-Diethyl O-(4-nitrophenyl) phosphorothioate | HSDB 2013
Synonyms(s) | O,O-Diethyl-O-4-nitrophenyl phosphorothioate; O,O-diethyl O-p-nitrophenyl thiophosphate; parathion, ethyl parathion; others | HSDB 2013
Registered trade name(s) | Alkron, Aileron, Aphamite, Bladen, Corothion, Etilon, Folidol, E-605, Fostox E, Geofos, Kriss, Niram, Orthophos, Panthion, Paramar, Paraphos, Parathene, Parawet, Penncap-E, Phoskil, Rhodiatox, SNP, Soprathion, Stathion, Thiophos, Vitrex, others | FAO 1997
Registered trade name(s) | PESTANAL^®^ | Sigma Aldrich 2014
Chemical formula | C_10_H_14_NO_5_PS | HSDB 2013
Chemical structure | [image] | PhysProp 2013
Identification numbers:
CAS registry | 56-38-2 | HSDB 2013
NIOSH RTECS | TF 4550000 | NIOSH 2009
EPA hazardous waste | P089 | HSDB 2013
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | UN 2783 Organophosphorus pesticides; IM06.1 Organophosphorus pesticides; solid | HSDB 2013
HSDB | 197 | HSDB 2013
NCI | C00226 | NCI 1979

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS=Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Parathion

Property | Information | Reference
Molecular weight | 291.26 | HSDB 2013
Color | Pale yellow (pure); dark brown (technical grade liquid generally in an organic solvent); colorless to white (formulated solid) | FAO 1997; IPCS 2005
Physical state | Liquid (pure); solid (formulated) | HSDB 2013; IPCS 2005
Melting point | 6.1°C | Tomlin 2010
Boiling point | 375°C at 760 mm Hg | O’Neil et al. 2013
Density: at 25°C/4°C | 1.26 | HSDB 2013
Odor | Garlic-like Phenol-like | HSDB 2013
Odor threshold: | | HSDB 2013
Water | 4.00×10^−2^ mg/L
Air | 0.470 mg/m^3^
Taste threshold | No data
Solubility:
Water at 20°C | 11 mg/L | Tomlin 2010
Organic solvent(s) | Miscible in alcohols, esters, ethers, ketones, aromatic hydrocarbons, and animal and vegetable oils; practically insoluble in petroleum ether, kerosene, and usual spray oils | HSDB 2013
Partition coefficients:
Log K_ow_ | 3.83 | Tomlin 2010
Log K_oc_ | Eight soil types, 2.48–2.69; four soil types, 2.98–3.23; average for four soils, 4.019 | Gerstl and Mingelgrin 1984; Sharom et al. 1980
Vapor pressure at 20 °C | 6.68×10^−6^ mm Hg | HSDB 2013
Henry’s law constant | 2.98−10^−7^ atm-m^3^/mol | PhysProp 2013
Autoignition temperature | No data | HSDB 2013
Flashpoint | 120–160°C until flammable impurities removed | HSDB 2013
Flammability limits | Not highly flammable | HSDB 2013
Explosive limits | Decomposes upon heating and residues can explode | HSDB 2013

FAO = Food and Agriculture Organization; HSDB = Hazardous Substances Data Bank; NIOSH = National Institute for Occupational Safety and Health