# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Parathion Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Parathion
CAS Numbers: | 56-38-2
Date: | January 2017
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 9
Species: | Rat

[underlined: Minimal Risk Level]: 20 [ ] mg/kg/day [X] ng/m^3^

[underlined: Reference]: NIOSH. 1974. Inhalation and oral toxicity 13 studies of ethyl parathion administered acutely and subacutely to the rat and dog. National Institute of Occupational Safety and Health Report No. 00134578. Aberdeen Proving Ground, MD: Edgewood Arsenal, Toxicology Division .

[underlined: Experimental design]: Groups of male rats (20/group) were exposed whole-body to 0, 0.01, 0.1, or 0.74 mg parathion aerosol/m^3^ 7 hours/day, 5 days/week for 6 weeks. It should be noted that since the rats were not prevented from grooming themselves, ingestion of some amount of parathion may have occurred. Blood samples obtained from 71 rats were assayed for red blood cell and plasma cholinesterase and served as baseline controls. Ten rats per exposure group and control group were sacrificed at various times during the exposure period and during a 6-week post-exposure period to collect blood samples. The rats were observed for clinical signs and were weighed before blood sampling and sacrifice.

[underlined: Effect noted in study and corresponding doses]: No clinical signs were seen in rats exposed to 0.01 or 0.1 mg parathion/m^3^. Some rats in the high-concentration group showed signs of parathion toxicity, including tremors and ataxia. Blood collected from the high-dose group after the last exposure showed no significant alteration in hematocrit. Body weight was not significantly altered by exposure to parathion. In the low-exposure group, red blood cell AChE activity was maximally decreased by approximately 30% on exposure weeks 4 and 5; no data were available for week 3. On exposure week 6, red blood cell AChE activity in the low-exposure group had recovered to 97.3% of control levels. In the mid-exposure group, the maximum decrease in red blood cell AChE was 43% and occurred on week 1. During the rest of the exposure period, red blood cell cholinesterase activity was 60–70% of pretest levels, suggesting that a steady state had been achieved. Red blood cell AChE activity during the first and second week of the post-exposure period was 82 and 84.4% of controls, indicating that recovery was in progress. In the high-exposure group, red blood cell AChE activity achieved its maximal depression on week 5 of exposure, reaching 15% of controls. In general, enzyme activities recovered during the 6-week post-dosing period. Changes in plasma cholinesterase activity paralleled red blood cell changes, recovered faster and exceeded control levels by week 1 or 2 post-exposure. Since the exposure level of 0.1 mg parathion/m^3^ induced a level of depression of red blood cell AChE activity that appeared to achieve steady state at approximately 60–70% of controls during exposure, and no clinical signs were observed at this exposure level, 0.1 mg/m^3^ constitutes a less serious LOAEL for neurological effects in rats; the exposure concentration of 0.01 mg parathion/m^3^ is a NOAEL.

Since only means without deviation parameters were reported for red blood cell AChE values, dose-responses using benchmark dose approaches cannot be constructed to estimate points of departure from the rat data. Therefore, a NOAEL/LOAEL approach will be used and the NOAEL of 0.01 mg parathion/m^3^ for red blood cell AChE in rats is the point of departure for MRL derivation.

[underlined: Exposure concentration and end point used for MRL derivation]: 0.01 mg/m^3^; NOAEL for neurological effects (red blood cell AChE inhibition).

[ X ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: A human equivalent dose could not be determined because the study did not provide information regarding information about particle size.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes (7 hours/24 hours) x (5 days/7 days).

[underlined: Other additional studies or pertinent information that lend support to this MRL]: A 6-week inhalation study in dogs also established a NOAEL of 0.01 mg/m^3^ for red blood cell AChE activity (NIOSH 1974). In that study, male beagle dogs (6/group) were exposed to parathion aerosol at concentrations of 0, 0.001, 0.01, or 0.2 mg/m^3^ 7 hours/day, 5 days/week for 6 weeks and were held for an additional 6-week post-exposure period. Blood samples obtained from the dogs at various times during the exposure and post-exposure periods were assayed for red blood cell AChE and plasma cholinesterase. Blood samples were taken pre-exposure so that each dog served as its own control. No clinical signs were observed in the dogs. Exposure to parathion did not affect body weight gain in the dogs. No significant effects on levels of red blood cell AChE activity were observed at the low-exposure level. Exposure to 0.01 mg parathion/m^3^ reduced red blood cell AChE activity by 21% by the end of the second week of exposure, but levels recovered to 14% of pre-exposure values by the third week of exposure and to 100% of pretest levels during the remaining of the exposure period. In the high-exposure group, red blood cell AChE activity was reduced between 26 and 46% during the first 5 weeks of exposure and inhibition reached a maximum of 41% of pre-exposure levels on week 6 of exposure. Slow recovery was evident during the post-exposure period. Plasma cholinesterase activity was inhibited to a greater extent during the exposure period, but seemed to recover faster during the post-exposure period. Based on the fact that red blood cell AChE activity was depressed over 20% (21%) only on week 2 of exposure in the 0.01 mg/m^3^ group, this exposure level is considered a NOAEL for neurological effects in dogs in an intermediate-duration study; the LOAEL is 0.2 mg/parathion/m^3^.

[underlined: Agency Contacts (Chemical Managers)]: Sam Keith

## Parathion Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Parathion
CAS Numbers: | 56-38-2
Date: | January 2017
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 50
Species: | Human

[underlined: Minimal Risk Level]: 0.009 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Rider JA, Moeller HC, Puletti EJ, . 1969. Toxicity of parathion, systox, octamethyl pyrophosphoramide, and methyl parathion in man. Toxicol Appl Pharmacol 14(3):603–611 4306871 .

[underlined: Experimental design]: Five male volunteers* were administered 3, 4.5, 6, or 7.5 mg parathion/day in a capsule (0.04, 0.06, 0.09, and 0.11 mg/kg/day, assuming 70 kg body weight) for approximately 30 days; two additional subjects served as controls. In a pretest period of 30 days, blood was collected to establish baseline levels of plasma cholinesterase and red blood cell AChE. The subjects were also monitored during a post-test period of about 30 days. At the beginning of the pretest period, routine blood counts, urinalysis, and prothrombin time were performed, and these were repeated at the end of each test period.

[underlined: Effect noted in study and corresponding doses]: Doses of 0.04 or 0.06 mg parathion/kg/day did not affect the levels of either enzyme. Administration of 0.09 mg parathion/kg/day caused a slight depression of plasma cholinesterase (data not provided). Doses of 0.11 mg parathion/kg/day induced a 27% decrease in the plasma enzyme in one subject on day 4. On day 9, two subjects showed 36 and 32% inhibition of the plasma enzyme. On day 16, the levels of plasma cholinesterase in these two subjects were 50 and 52% of pretest levels and parathion dosing was discontinued. In the other three subjects, plasma cholinesterase levels were 97, 82, and 69% of pretest levels. On day 16, the mean levels of plasma cholinesterase in the five exposed subjects was reduced by 28% from the control value. On day 23, plasma cholinesterase activity in a third exposed subject was 54% of his pretest level and dosing was also discontinued. Therefore, of the five dosed subjects, three had the treatment discontinued by day 23 (two on day 16 and one on day 23). In the two subjects who received parathion during 35 days, the lowest plasma cholinesterase levels were 86 and 78% of their pretest values.

Red blood cell AChE activity in the three subjects who discontinued parathion dosing achieved maximal inhibition levels of 63, 78, and 86% of pretest levels. In the two subjects who completed the test period, there was no significant effect on red blood cell AChE activity. By the end of the post-test period, both enzymes had returned to pretest levels. No information was provided regarding blood counts, urinalysis, or prothrombin test results. Based on a >20% inhibition of red blood cell AChE activity in two out of five subjects for 16 days, the dose of 0.11 mg parathion/kg/day is a LOAEL for neurological effects; the next lower dose, 0.09 mg parathion/kg/day, is a NOAEL.

Benchmark dose analysis cannot be performed because the data were not presented as means plus or minus a measure of dispersion. The intermediate-duration oral MRL for parathion is derived by dividing the NOAEL of 0.09 mg parathion/kg/day by an uncertainty factor of 10 (to account for human variability); this yields an MRL of 0.009 mg parathion/kg/day (9 μg/kg/day).

[underlined: Dose and end point used for MRL derivation]: 0.09 mg/kg/day; NOAEL for neurological effects (inhibition of red blood cell AChE activity).

[ X ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Edson (1964) identified a NOAEL of 0.1 mg parathion/kg/day (the highest dose tested) for red blood cell AChE activity in female volunteers administered the pesticide orally for 6 weeks. The available intermediate-duration oral studies in animals suggest that significant inhibition (>20%) of red blood cell AChE occurs with repeated doses ≥0.1 mg parathion/kg/day. In a study in dogs, red blood cell AChE activity was depressed approximately 25% with doses of 0.047 mg parathion/kg/day for 12 weeks, but appeared to increase to near 90% of pretest values on week 16 of exposure (Frawley and Fuyat 1957). Another study in dogs showed that a constant inhibition of the enzyme of >20% could be achieved only with repeated doses of 0.5 mg parathion/kg/day (NIOSH 1974). Two studies in rats dosed for several weeks identified LOAELs of 0.1 mg parathion/kg/day for red blood cell AChE; the NOAELs were 0.024 and 0.05 mg parathion/kg/day (Ivens et al. 1998; NIOSH 1974).

*Note: ATSDR endorses the highest ethical standards in conducting human dosing studies. Thus, it should be noted that the Rider et al. (1969) study raises ethical concerns about human subjects’ protection and would not be approved today based on the current human subject protection regulations (HHS 2009). The participants in the study were prisoners in San Quentin State prison and the California Medical Facility in Vacaville, raising questions about their ability to make a truly voluntary and uncoerced decision whether or not to participate in the study. The study report provides no detailed information regarding consent procedures other than to state that the participants were volunteers. ATSDR believes that the use of the study is consistent with the recommendations by the NRC (2004).

- Recommendation 7-2 states that: “The cholinesterase inhibition studies that already have been submitted to EPA, if determined to be scientifically valid and justified for EPA’s regulatory purposes, may be considered for use in risk assessment and standard setting if they were not unethically conducted (see Recommendation 5-7.)”
- Recommendation 5-7 states that: “EPA should accept scientifically valid studies conducted before its new rules are implemented unless there is clear and convincing evidence that the conduct of those studies was fundamentally unethical (e.g., the studies were intended to seriously harm participants or failed to obtain informed consent.)”

Although there is limited information about the consent procedures used in this study, the information that is provided about the participants being volunteers suggests that there is no clear and convincing evidence that the conduct of this study was fundamentally unethical.

- Recommendation 4-1 further states that: “EPA should consider a human dosing study intended to reduce the interspecies uncertainty factor (for example, a study of a biomarker such as cholinesterase inhibition) as conferring a societal benefit only if it was designed and conducted in a manner that would improve the scientific accuracy of EPA’s extrapolation from animal to human data.”

As discussed above, the available intermediate-duration oral studies suggest that in humans, rats, and dogs, significant inhibition (>20%) of red blood cell AChE activity occurs with repeated doses ≥0.1 mg parathion/kg/day. The human study by Rider et al. provides a basis for an MRL that improves the accuracy of the value based on the animal data alone, and eliminates the interspecies uncertainty factor. Any human dosing study must have a useful purpose and convey a benefit to participants and/or society (NRC 2004). ATSDR believes that the Rider et al. (1969) study provides a benefit to society in that the data provide the basis for a health guidance value (i.e., MRL) that can be used to protect exposed populations to parathion.

[underlined: Agency Contacts (Chemical Managers)]: Sam Keith