# 8 REFERENCES

*Cited in text

*Abrams J. 1980. Nitrate tolerance and dependance. Am Heart J 99:113–123.6766045
*ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH, 502.
*ACGIH. 1994. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1994- 1995. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
Air Force. 1980. Acute and chronic propylene glycol dinitrate exposure in the monkey. Brooks Air Force Base, TX: U.S. Air Force School of Aerospace Medicine, Aerospace Medical Division. Document no. AD A1054675.
Air Force. 1981a. Respiratory toxicology: Annual technical report 1981. Contract no. F33615-80-C-0152. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD A1076728.
Air Force. 1981b. Toxic hazards research unit: Annual technical report 1981. Contract no. F33615-80-C-0512. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD-110 587/3.
Air Force. 1982a. Analysis of orthochloronitrobenzene in Otto fuel II by high pressure liquid chromatography. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD A7763054.
*Air Force. 1982b. Evaluation of the toxicokinetic study of 1,2-propanediol dinitrate (PGDN) in the dog. Contract no. F33615-80-C-0512. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. All6 506/7.
Air Force. 1982c. Toxic ,hazards research unit: Annual technical report 1982. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Research Division, Air Force Systems Command. Document no. AD-A121 71713.
Air Force. 1983. Toxic hazards research unit: Annual technical report 1983. Contract no. F 33615-80-C-0512. Wright-Patterson Air Force Base, OH: Air Force Aerospace Medical Research Laboratory, Aerospace Medical Research Division, Air Force Systems Command. Document no. AD A1361708.
*Air Force. 1985a. One-year inhalation toxicity study of otto fuel II. Wright-Patterson Air Force Base, OH: Harry G. Armstrong Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD A163162.
Air Force. 1985b. Toxic hazards research unit: Annual technical report 1985. Wright-Patterson Air Force Base, OH: Harry G. Armstrong Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD A161558.
Air Force. 1986. Toxic hazards research unit: Annual technical report 1986. Wright-Patterson Air Force Base, OH: Harry G. Armstrong Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. Document no. AD A183 116.
*Akimoto H, Bandow H, Sakamaki F, . 1980. Photooxidation of the propylene-nitrogen oxide-air system studied by long-path Fourier transform IR spectrometry. Environ Sci Technol 14:172–179.
*Akimoto H, Hoshino M, Inoue G, . 1978. Formation of propylene glycol 1,2-dinitrate in the photooxidation of propylene-nitrogen oxides-air system. J Environ Sci Health A13:677–686.
*American Cyanamid. 1982. Material safety data sheet on 2-nitrodiphenylamine. American Cyanamid Company. Wayne, NJ. MSDS no. 0404-01.
*Andersen ME, Mehl RG. 1979. A comparison of the toxicology of triethylene glycol dinitrate and propylene glycol dinitrate. Am Ind Hyg Assoc J 34:526–532.
Andersen ME, Smith RA. 1973. Mechanism of the oxidation of human and rat hemoglobin by propylene glycol dinitrate. Biochem Pharmacol 22:3247–3256.4769598
*Army. 1976. Aquatic field surveys at Iowa, Radford and Jolict Army ammunition plants. Contract no. DAMD17-75-C-5046. Washington, DC: U.S. Army Medical Research and Development Command. Document no. AD A0366777.
*Army. 1979. Problem definition study on TAX (I-acetylhexahydro-3,5-dinitro- 1,3,5-triazine), SEX (1-acetylhexahydro-3,5,7-trinitro-1,3,5,6-tetrazocine), lead salicylate and lead beta-resorcylate 2-nitrodiphenylamine and ethyl centralite. Contract no. DAMD17-77-C-7057. Frederick, MA: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A0997494.
*Army. 1981a. Biodegradation of nitrate esters used as military propellants - a status report. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A149665/2.
*Army. 1981b. Decomposition of glycols from nitrate ester propellants. Natick, MA: U.S. Army Natick Research and Development Laboratories. Document No. AD101607.
*Army. 1986a. Database assessment of pollution control in the military explosives and propellants production industry. Contract no. DE-AC05-840R21400. Frederick, MD: U.S. Army Medical Research and Development Command, Fort De&k.
*Army. 1986b. High-performance liquid chromatography of propellants: I. Analysis of Ml, M6, and M10 propellants. Dover, NJ: U.S. Army Armament Research and Development Center. Document no. AD A168206.
*Askarova YN, Muryseva EN. 1975. [Allergenic properties of lubricants and some of their ingredients in the production of glass fiber.] Sb Nauchn Tr Bashk Gos Med Inst 19:10–13. (Russian)
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry, Atlanta, GA.
*ATSDR. 1990. Public health advisory for Caldwell Systems, Inc., Caldwell County, Lenoir, North Carolina. Agency for Toxic Substances and Disease Registry, Atlanta, GA. July 25, 1990.
*ATSDR. 1991. Case studies in environmental medicine: Nitrate/nitrite toxicity. Atlanta, GA: Agency for Toxic Substances and Disease Registry. October.
*ATSDR. 1992. The 1989 and 1990 biennial report. Agency for Toxic Substances and Disease Registry, Atlanta, GA. U.S. Department Public Health Services. DHHS, 7.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Baughman GL, Perenich TA. 1988. Fate of dyes in aquatic systems: I. Solubility and partitioning of some hydrophobic dyes and related compounds. Environmental Toxicology and Chemistry 7:183–200.
*Beard RR, Noe JT. 1981. Aromatic nitro and amino compounds. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. 3rd ed. Vol. IIa. New York, NY: John Wiley and Sons, 2413–2489.
*Bender EC. 1983. Analysis of smokeless powders using UV/TEA detection. Proceedings of the International Symposium on the Analysis and Detection of Explosives. Washington, DC: U.S. Department of Justice, Federal Bureau of Investigation, 309–320.
“Bergens A. 1987. Determination of nitrodiphenylamines by liquid chromatography and dual-electrode amperometric detection, J Chromatogr 410:437–446.
*Bogo V, Hill TA, Nold J. 1987. Motor performance effects of propylene glycol dinitrate in the rat J Toxic01 Environ Health 22:17–27.
*Bratin K, Kissinger PT, Briner RC, . 1981. Determination of nitro aromatic, nitramine, and nitrate ester explosive compounds in explosive mixtures and gunshot residue by liquid chromatography and reductive electrochemical detection. Analytical Chimica Acta 130:295–311.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company, 57, 68, 191–192.
*Carmichael P, Lieben J. 1963. Sudden death in explosives workers. Arch Environ Health 7:50–65.
*Castle L, Mercer AJ, Startin JR, . 1988. Migration from plasticized films into foods: 3. Migration of phthalate, sebacate, citrate and phosphate esters from films used for retail food packaging. Food Addit Contam 5:9–20.3356285
*Chemlist. 1991. American Petroleum Institute. Central Abstracting and Indexing Services, New York, New York. July 25, 1991.
*Clark DG, Litchfield MH. 1967. Metabolism of ethylene glycol dinitrate and its influence on the blood pressure of the rat. Br J Ind Med 24:320–325.6073091
*Clark DG, Litchfield MH. 1969. Toxicity, metabolism, and pharmacologic properties of propylene glycol 1,2-dinitrate. Toxic01 Appl Pharmacol 15: 175184.
*Cooper JR, Lee LH, Macys DA. 1993. Developmental toxicity of otto fuel II in the rat and rabbit. J Appl Tox 13(4):235–239.
*Cotran RS, Kumar V, Robbins SL. 1989. Robbins pathologic basis of disease. 4th ed. Philadelphia: W.B. Saunders Company, 663–666, 1048–1050.
*Crater W deC. 1929. The vapor pressures of glycerol trinitrate and certain glycol dinitrates. Industrial and Engineering Chemistry 21:674–676.
*Dahl DB, Lott PF. 1987. Gunshot residue determination by means of gunpowder stabilizers using high-performance liquid chromatography with electrochemical detection and analysis of metallic residues by graphite furnace atomic absorption spectrophotometry. Microchemical Journal 35:347–359.
*Dean JA, ed. 1974. Lange’s handbook of chemistry. 11 th ed. New York, NY: McGraw-Hill Book Co., 7-302 to 7-303.
*Dietrich MJ, Randall TL, Canney PJ. 1985. Wet air oxidation of hazardous organics in wastewater. Environmental Progress 4:171–177.
*Dimagl U, Kaplan B, Jacewicz M, . 1989. Continuous measurement of cerebral cortical blood flow by laser-doppler flowmetry in a rat stroke model. J Cereb Blood Flow Metab 9(3):589 596.2674168
DNA. 1975. Effects of propylene glycol 1,2-dinitrate on rhesus monkey visual evoked response and Sidman avoidance task. Bethesda, MD: Armed Forces Radiobiology Research Institute, Defense Nuclear Agency. Document no. AD A023770.
DNA. 1976. Effects of chronic inhalation of propylene glycol 1,2-dinitrate on the conditioned avoidance behavior of primates. Bethesda, MD: Armed Forces Radiobiology Research Institute, Defense Nuclear Agency. Document no. AD A026841.
*Donovan JW. 1990. Nitrates, nitrites and other sources of methemoglobinemia. In: Haddad LM, Winchester JF, eds. Poisoning and drug overdose. 2nd ed. Philadelphia, PA: WB Saunders Co., 1419–1431.
*DOT. 1989a. Hazardous materials. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
*DOT. 1989b. Hazardous materials. Department of Transportation. Federal Regulations 54 (185):39501–39505.
*Douse JMF. 1985. Trace analysis of explosives at the low nanogram level in handswab extracts using columns of Amberlite XAD-7 porous polymer beads and silica capillary column gas chromatography with thermal energy analysis and electron-capture detection. J Chromatogr 328:155–165.
*DREA. 1986. Determination of PGDN (propylene glycol dinitrate) in aqueous solution. Canada: National Defence Research and Development Branch, Defence Research Establishment Atlantic. Document no. AD A173001.
*Dykes EWH, Alley BJ. 1974. Gas-liquid chromatographic determination of nitrate esters, stabilizers, and plasticizers in nitrocellulose-base propellants and nitroglycerin in pharmaceuticals. Patented January 1, 1974. United States Patent Office, Washington, DC. U.S. patent no. 3,872,900.
*Ellenhorn MJ, Barceloux DG, eds. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 844–851.
EPA. 1982. Chemical Information Rules: Chemical lists and reporting period.: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. Washington DC. 40 CFR 712.30. Code of Federal Regulations.
*EPA. 1984a. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates. Vol. 1: Analysis results from 17 drinking water, 16 advanced waste treatment and 3 process blank concentrates. Contract no. 68-03-2548. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory, Office of Research and Development.
*EPA. 1984b. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates. Vol. 2: Computer-printed tabulations of compound identiFication results for large-volume concentrates. Contract no. 68-03-2548. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory, Office of Research and Development.
*EPA. 1986. Graphic Exposure and Modelling System (GEMS). U.S. Environmental Protection Agency, Exposure Evaluation Branch, Office of Toxic Substances. Washington, DC. (Database)
*EPA. 1990. Interim methods for determination of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. EPA/600/8-88/066F.
*Erk SD, Jarboe CH, Newton PE, . 1982. Gas chromatographic determination of 1,2propanediol dinitrate in blood. J Chromatogr 240:117–123.7096511
*Fine DA, Miles MH. 1983. The reduction of propylene glycol dinitrate, nitroglycerin, dinitrotoluene and trinitrotoluene on silver electrodes. Analytical Chimica Acta 153:141–147.
*Forman SA. 1988. A review of propylene glycol dinitrate toxicology and epidemiology. Toxicol Lett 43:51–65.3051528
*Forman SA, Helmkamp JC, Bone CM. 1987. Cardiac morbidity and mortality associated with occupational exposure to 1,2-propylene glycol dinitrate. J Occup Med 29:445–450.3598736
*Godin CS, He J, Drerup JM, . 1994. Effect of propylene glycol 1,2-dinitrate on cerebral blood flow in rats: a potential biomarker for vascular headache? [accepted for publication by Toxicology Letters]
*Godin CS, Kimmel EC, Drerup JM, . 1993. Effect of exposure route on measurement of blood pressure by tail cuff in F-344 rats exposed to OTTO fuel II. Tox Letters 66:147–155.
*Goldfrank LR, Weisman RS, Flomenbaum NE, . 1990. Goldfrank’s toxicological emergencies. Norwalk, CT: Appleton & Lange, 210, 394–398.
*Green S, Auletta A, Fabricant Y, . 1985. Current status of bioassays in genetic toxicology - the dominant lethal assay. A report of the U.S. Environmental Protection Agency Gene-Tox Program. Mutat Res 154:49–67.3889623
*HazDat. 1994. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Horvath EP, Ilka RA, Boyd J, . 1981. Evaluation of the neurophysiologic effects of 1,2-propylene glycol dinitrate by quantitative ataxia and oculomotor function tests. Am J Ind Med 2:365–378.6980592
*Hoshino M, Ogata T, Akimoto H, . 1978. Gas phase reaction of nitrogen pentoxide with propylene. Chem Lett 12:1367–1370.
*HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Jones RA, Strickland JA, Siegel J. 1972. Toxicity of propylene glycol 1,2-dinitrate in experimental animals. Toxicol Appl Pharmacol 22:128–137.4624647
*Kalin M, Kylin B. 1969. Organic nitrate explosives as monoamine oxidase inhibitors: Studies in vitro. Arch Environ Health 18:311–314.5006452
*Kessick MA, Characklis WG, Elvey W. 1978. Treatment of wastewater from torpedo refueling facilities. Proc Ind Waste Conf 32:442–449.
*Klausmeier RE. 1986. Deterioration of vinyl resin systems - the current plasticizer deterioration study. Dev Ind Microbiol 9:218–221.
*Klausmeier RE, Jones WA. 1960. Microbial degradation of plasticizers. Dev Ind Microbiol 2:47–53.
*Klausmeier RE, Osmon JL. 1976. Biodegradation of plastics by actinomycetes. In: Proceedings of the International Biodegradation Symposium. London: Applied Science Publishers, 3:815–818.
*Kleindienst TE, Shepson PB, Edney EO, . 1985. The mutagenic activity of the products of propylene photooxidation. Environ Sci Technol 19:620–627.22148305
*Komarova EN. 1976. [Toxic properties of some additive for plastics.] Plast Massy Issue 12:30–31. (Russian)
*Komarova EN. 1979. [Materials on the toxicology of dibutyl phthalate, dioctyl phthalate, dibutyl sebacate, and butyl stearate.] Khim Prom-St Ser Toksikol Sanit Khim Plastmass Issue 3:12–15. (Russian)
*Komura S. 1974. Effects of ethylene glycol dinitrate and related compounds on ethanol preference and ethanol metabolism. Acta Pharmacol Toxicol 35:145–154.
*Kononova SD, Korolev AM, Eremenko LT, . 1972. Mutagenic effect of some esters of nitric acid on bacteriophage T4B. Sov Genet 8:635–640.
*Kylin B, Englund A, Erhner-Samuel H, . 1966. A comparative study on the toxicology of nitroglycerine, nitroglycerol, and propylene glycol dinitrate. In: Proceedings of the 15th International Congress on Occupational Health, Vienna, Austria, September 19-24, 1966. Vienna: Verlag der Wiener Medizinischen Akademie, 3:191–195.
Lide DR, ed. 1991. CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, 3–458.
*Litchfield MH. 1968. The determination of the di- and mononitrates of ethylene glycol and 1,2-propylene glycol in blood by calorimetric and gas-chromatographic methods. Analyst 93:653–659.5685007
*Litchfield MH. 1971. Review article: Aspects of nitrate ester metabolism. J Pharm Sci 60:1599–1607.5002526
*Luoma GA, Yee LK, Tumham BD. 1987. Method and apparatus for detecting the presence and concentration of vapours in gaseous fluids. Patented September 29, 1987, Consumer and Corporate Affairs Canada. Canadian patent no. 1227357.
*Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Company.
Mallette FS, Von Haam E. 1952a. Studies on the toxicity and skin effects of compounds used in the rubber and plastics industries: I. Accelerators, activators and antioxidants. AMA Archives of Industrial Hygiene and Occupational Medicine 5:311–317.14914199
*Mallette FS, Von Haam E. 1952b. Studies on the toxicity and skin effects of compounds used in the rubber and plastics industries: II. Plasticizers. AMA Archives of Industrial Hygiene and Occupational Medicine 6:231–237.14952047
*Mattsson JL, Young RW, Curran CR, . 1981. Acule and chronic propylene glycol dinitrate exposure in the monkey. Aviat Space Environ Med 52:340–345.7259692
*McCallum JJ. 1989. Piezoelectric devices for mass and chemical measurements: An update. Analyst 114:1173–1189.
*McGregor DB, Riach CG, Hastwell RM, . 1980. Genotoxic activity in microorganisms of tetryl, 1,3-dinitrobenzene and 1,3,5-trinitrobenzene. Environ Mutagen 2:531–541.7030731
Morimoto Y, Kobayashi S, Seki T, . 1989. [Preparation of isosorbide dinitrate cataplasms.] Yakuzaigaku 49:241–246. (Translation in progress)
*Morton W. 1977. Occupational habituation to aliphatic nitrates and the withdrawal hazards of coronary disease and hypertension. J Occup Med 19:197–201.402446
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1992. National Air Toxics Information Clearinghouse. Data base report on federal, state, local, and EPA air toxics activities. U.S. Environmental Protection Agency, Research Triangle Park, NC. EPA-453/R-92-008.
Navy. 1973. Experimental human exposure to propylene glycol dinitrate. Report for the Department of the Navy, Bureau of Medicine and Surgery. Document no. AD 766977.
*Navy. 1976a. Applied polarography for analysis of ordnance materials: Part 1. Determination and monitoring for 1,2-propylene glycol dinitrate in effluent water by single-sweep polarography. China Lake, CA: Naval Weapons Center. Document no. AD A026468
*Navy. 1976b. Applied polarography for analysis of ordnance materials: Part 2. An inexpensive solid-state field polarograph with digital and analog output. China Lake, CA: Naval Weapons Center. Document no. AD A 030038.
*Navy. 1977a. Carbon treatment of otto fuel wastewater: A laboratory study. Silver Spring, MD: Naval Surface Weapons Center. Document no. AD A040986.
Navy. 1977b. Studies on bacterial degradation of ordnance wastes. In: Young GA, compiler. Proceedings of the Second Conference on the Environmental Effects of Explosives and Explosions (13-14 October 1976). Dahlgren, VA and Silver Spring, MD: Research and Technology Department, Naval Surface Weapons Center. Report no. NSWC/WOLTR 77-36.
*Navy. 1979. Applied polarography for analysis of ordnance materials: Part 3. Field tests of NWC digital polarograph and pollution monitoring system. China Lake, CA: Naval Weapons Center. Document no. AD A064424.
Navy. 1982a. Evaluation of the health risks of ordinance disposal waste in drinking water. Contract no. ONR N00014-80-C-0161. Washington, DC: Department of the Navy. Document no. PB83-153635.
*Navy. 1982b. Mutagenicity evaluation of otto fuel number 2 in the Ames Salmonella/microsome plate test: Segment report. Arlington, VA: Department of the Navy, Office of Naval Research. Document no. AD A112227.
*Navy. 1984a. Voltammetric analysis of ordnance materials: Part 1. Detection and quantitation of nitrate esters and various nitro compounds in water by voltammetry. China Lake, CA: Naval Weapons Center. Document no. AD A142269.
*Navy. 1984b. Voltammetric analysis of ordnance materials: Part 2. A portable digital voltammeter for use with a silver wire working electrode. China Lake, CA: Naval Weapons Center. Document no. AD A152480.
Navy. 1985. Morbidity and mortality associated with exposure to otto fuel II in the U.S. Navy 1966-1979. Bethesda, MD: Naval Medical Research and Development Command, Naval Medical Command, National Capital Region. Document no. AD A148726
*Nickerson M. 1975. Vasodilator drugs. In: Goodman LS, Gilman A, eds. The pharmacological basis of therapeutics. 5th ed. New York, NY: MacMillan Publishing Co., Inc., 727–743.
*NIOSH. 1992. Recommendations for occupational safety and health. Compendium of policy documents and statements. Cincinnati, OH: National Institute on Occupational Safety and Health. DHHS no. 92-100. p.116.
*NOES. 1991. Dibutyl sebacate. National Occupational Exposure Survey. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. Cincinnati, OH. September 11, 1991.
*Northrop DM, Martire DE, MacCrehan WA. 1991. Separation and identification of organic gunshot and explosive constituents by micellar electrokinetic capillary electrophoresis. Anal Chem 63:1038–1042.
*NRC. 1982. Evaluation of the health risks of ordnance disposal waste in drinking water. Washington, DC: National Research Council. Report no. NRC-TOX-P897. NTIS no. PB83-153635.
OSHA. 1989a. OSHA safety and health standards for general industry. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 1989b. U.S. Department of Labor. Occupational Safety and Health Administration. Federal Register 54:2920–2960.
*Osmon JL, Klausmeier RE, Jaminson EI. 1972. Rate-limiting factors in biodeterioration of plastics. In: Walters AH, Hueck van der Plas EH, eds. Proceedings of the 2nd International Biodeterioration Symposium, Lunteren, Netherlands, September 13-18, 1971. New York, NY: Halsted Press, 66–75.
*OTA. 1990. Neurotoxicity: identifying and controlling poisons of the nervous system. Office of Technical Assessment, Washington, DC. OTA-BA-438.
*Parker JO. 1985. Efficacy of nitrogycerin patches: fact or fancy? Ann Intern Med 102:548–550.3919628
*Pharmackon. 1988. The effect of organic nitrates upon the blood pressure and heart rate of spontaneously hypertensive aortic intubated male rats when administered intra-arterially. Waverly, PA: Pharmackon Laboratories.
*Rivera JC. 1974. Otto fuel II: Health hazards and precautions. U.S. Navy Medicine 63:7–10.4620116
*RTECS. 1994. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC.
*Saeki Y, Sato A, Sato Y, . 1989. Stimulation of the rostral ventrolateral medullary neurons increases cortical blood flow via activation of the intracerebral pathway. Neurosci Lett 107:26 32,2559371
*SANSS. 1994. Chemical Information System (CIS). Structure and Nomenclature Search System.
*Sax NI, Lewis RJ. 1989a. Dangerous properties of industrial materials. 7th ed. New York, NY: Van Nostrand Reinhold, 2:1126.
*Sax NI, Lewis RJ. 1989b. Dangerous properties of industrial materials. 7th ed. New York, NY: Van Nostrand Reinhold, 3:2903–2904.
Schafer EW Jr, Bowles WA Jr. 1985. Acute oral toxicity and repellency of 933 chemicals to house and deer mice. Arch Environ Contam Toxicol 14:111–129.3977403
Schefer W. 1975. [Water polluting chemicals.] Umwelthygiene 1:13–17. (German)
Shepson PB, Kleindienst TE, Edney EO, . 1985. The mutagenic activity of the products of ozone reaction with propylene in the presence and absence of nitrogen dioxide. Environ Sci Technol 19:1094–1098.22288757
*Shishido J, Yoshii K, Takubo Y, . 1984. Studies on an automated survey system of environmental chemicals by gas chromatography-mass spectrometry-computer: II. Three dimensional mass chromatography. Chemosphere 13:331–338.
*Smith CC. 1953. Toxicity of butyl stearate, dibutyl sebacate, dibutyl phthalate, and methoxyethyl oleate. AMA Archives of Industrial Hygiene and Occupational Medicine 7:310–318.13039587
*Smith LL, Carrazza J, Wong K. 1983. Treatment of wastewaters containing propellants and explosives. Journal of Hazardous Materials 7:303–316.
*SRI. 1991. SRI International. 1991 Directory of chemical producers. Menlo Park, CA: SRI International, 884.
*Stahl WH, Pessen H. 1953. The microbiological degradation of plasticizers. I. Growth on esters and alcohols. Appl Microbial 1:30–35.
*Stewart RD, Peterson JE, Newton PE, . 1974. Experimental human exposure to propylene glycol dinitrate. Toxic01 Appl Pharmacol 30:377–395.
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 342–345.
*Thomas Publishing Company. 1990a. Thomas register of American manufacturers: Products and services section. New York, NY: Thomas Publishing Company, 4:7342.
Thomas Publishing Company. 1990b. Thomas register of American manufacturers: Company profiles section. New York, NY: Thomas Publishing Company, 16:344.
*Tomkins BA, Manning DL, Griest WH, . 1985. Selective detection of 1,2propylene glycol dinitrate, 1-propylene glycol mononitrate and 2-propylene glycol mononitrate using gas chromatography/thermal energy analyzer or liquid chromatography/electrochemical detection. Analytical Chimica Acta 169:69–78.
Tuominen J, Wickstrom K, Pyysalo H. 1986. Determination of polycyclic aromatic compounds by gas-liquid chromatography-selected ion monitoring technique. J High Resolut Chromatogr Commun 9:469–471.
*Turnham BD, Yee LK, Luoma GA. 1985. Coated piezoelectric quartz crystal monitor for determination of propylene glycol dinitrate vapor levels. Anal Chem 57:2120–2124.
*Van H, Deyrup CA, eds. 1991. OPD chemical buyers directory: 1992. 79th Annual edition. New York, New York: Schnell Publishing Company, Inc.
Van Lierop JBH, Van Veen RM. 1988. Determination of plasticizers in fat by gas chromatography-mass spectrometry. J Chromatogr 477:230–238.
*Via JC, Taylor LT. 1992. Chromatographic analysis of nonpolymeric single base propellant components. J Chromatogr Sci 30: 106–110.
Welch JF, Siegwarth JD. 1989. Method for processing of organic compounds. Patented August 29, 1989. U.S. Patent Office, Washington, DC. Patent no. 4861497.
Wendt TM, Cornell JH, Kaplan AM. 1978. Microbial degradation of glycerol nitrates. Appl Environ Microbial 36:693–699.
*Wickstrom K, Pyysalo H, Plaami-Heikkila S, . 1985. Polycyclic aromatic compounds (PAC) in leaf lettuce. Z Lebensm Unters Forsch 183: 182–185.
*Wild D, King M, Gocke E, . 1983. Study of artificial flavoring substances for mutagenicity in the SalmoneIla/microsome, BASC and micronucleus tests. Food Chem Toxicol 21:707–719.6420251
Williams DF. 1981. The toxicology of additives in medical plastics. In: Williams DF, ed. Systemic aspects of biocompatibility. Boca Raton, FL: CRC Press, 2:145–157.
Wyman JF, Gray BH, Lee LH, . 1985. Interspecies variability in propylene glycol dinitrate-induced methemoglobin formation. Toxic01 Appl Pharmacol 81:203–212.
*Wyman JF, Guard HE, Coleman WM III. 1984. Environmental chemistry of 1,2-propanediol dinitrate: Azeotrope formation, photolysis and biodegradability. Arch Environ Contam Toxicol 13:647–652.6517615