# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding Otto Fuel II and its major components in air, water, and other media are summarized in Table 7-1.

ATSDR has derived three MRL values for propylene glycol dinitrate, the major component of Otto Fuel II. An acute inhalation MRL of 0.003 ppm was derived for propylene glycol dinitrate based on altered visual evoked responses in humans (Stewart et al. 1974). An intermediate and chronic inhalation MRL of 0.00004 ppm was derived for propylene glycol dinitrate based on decreased levels of hematocrit, hemoglobin, red blood cells, and reticulocytes and increased levels of methemoglobin in dogs (Air Force 1985a). There is no EPA reference dose (RfD) or reference concentration (RfC) for Otto Fuel II or its major components.

Under the Hazardous Materials Transportation Act, Otto Fuel II is designated as a hazardous substance subject to special requirements for packaging, labeling, and transportation (DOT 1989a, 1989b).

Table 7-1 Regulations and Guidelines Applicable to Otto Fuel II and Its Components

Agency | | Description | Information | Reference
[underlined: NATIONAL]
Regulations:
a. | Other:
a. | DOT | Hazardous Material Transportation Act: Class A explosive (high explosive); designated as a hazardous substance subject to special requirements for packaging, labeling, and transportation (explosive torpedo) | Yes | DOT 1989a (49 CFR 172.101); DOT 1989b
Guidelines:
a. | Air
a. | ACGIH | TLV TWA (skin designation) | | ACGIH 1994
a. | ACGIH | Propylene glycol dinitrate | 0.05 ppm; (0.34 mg/m^3^)
a. | NIOSH | REL - TWA (skin designation) | | NIOSH 1992
a. | NIOSH | Propylene glycol dinitrate | 0.05 ppm; (0.3 mg/m^3^)
[underlined: STATE]
Regulations and Guidelines:
a. | Air.
a. | | Acceptable Ambient Air Concentrations | | NATICH 1992
a. | | Propylene glycol dinitrate
a. | CT | 8 hr avg. time | 6.00 µg/m^3^
a. | FL- Pinellas | 8 hr avg. time | 3.0 µg/m^3^
a. | FL-Pinellas | 24 hr avg. time | 7.20×10^−1^ µg/m^3^
a. | ND | 8 hr avg. time | 3.40×10^−3^ mg/m^3^
a. | NV | 8 hr avg. time | 7.0×10^−3^ mg/m^3^
a. | TX | 30 min avg. time | 3.00 µg/m^3^
a. | TX | Annual avg. time | 3.00×10^−1^ µg/m^3^
a. | VA | 24 hr avg. time | 57.0 µg/m^3^
a. | WA/SW | 24 hr avg. time | 1.00 µg/m^3^

ACGIH = American Conference of Governmental and Industrial Hygienists; DOT = Department of Transportation; NATICH = National Air Toxics Information Clearinghouse; NIOSH = National Institute of Occupational Safety and Health; REL = Recommended Exposure Level; TLV = Threshold Limit Value; TWA = Time Weighted Average