# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of Otto Fuel II and its components is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of Otto Fuel II and its components is located in Table 3-2.

TABLE 3-1 Chemical Identity of Otto Fuel II and Its Components^a^

Characteristic | Otto fuel II | Propylene glycol dinitrate^b^ | 2-Nitrodiphenylamine^c^ | Dibutyl sebacate
Synonym(s) | No data | PGDN; 1,2-propylene glycol dinitrate; 1,2-propanediol, dinitrate; propylene dinitrate; isopropylene nitrate; methylnitroglycol; propylene | 2-nitrobenzenamine, 2-nitro-N-phenyl; [underlined: o]-nitro-N-phenylaniline; [underlined: o]-nitro-diphenylamine^b^ | Bis ([underlined: n]-butyl) sebacate; butyl sebacate; decanedioic acid, dibutyl ester; sebacic acid, dibutyl ester; dibutyl decanedioate; di-[underlined: n]-butylsebacate^a^; dibutylester kyseliny
Registered trade name(s) | No data | No data | Sudan yellow 1339; C.I. 10335^b^ | Kodaflex DBS; Staflex DBS; PX 404; Monoplex DBS; Polycizer DBS^f^
Chemical formula | Not applicable | C_3_H_6_N_2_O_6_^g^ | C_12_H_10_N_2_O_2_^b^ | C_18_H_34_O_4_^f^
Chemical structure | Not applicable | [image] ^c^ | [image] ^b^ | [image] ^h^
Identification numbers:
CAS registry | 106602-80-6 | 6423-43-4^i^ | 119-75-5^b^ | 109-43-3
NIOSH RTECS | No data | TY 6300000^h^ | No data | VS 1150000
EPA hazardous waste | No data | No data | No data | 878212204; 878221572; 878221503^j^
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data | No data
HSDB | No data | No data | No data | 309
NCI | No data | No data | No data | No data

a All information obtained from HSDB 1994 except where noted

b Forman 1988

c Army 1979

d NRC 1982

e RTECS 1994

f Sax and Lewis 1989a

g ACGIH 1986

h SANSS 1994

i Sax and Lewis 1989b

j Chemlist 1991

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Otto Fuel II and Its Components^a^

Property | Otto fuel II | Propylene glycol dinitrate | 2-Nitrodiphenylamine | Dibutyl sebacate
Molecular weight | No data | 166.1^b^ | 214.23^c^ | 314.52^d^
Color | Reddish-orange^e^ | Colorless^f^ | Orange^g^ | Clear^d^
Physical state | Oily liquid^e^ | Liquid^f^ | Solid (orthorhombic crystals)^c^ | Liquid^d^
Melting point | −27.7 °C^h^ | −27.7° C^f^ | 75–76 °C^c^ | −10 °C
Boiling point | Decomposes at 121 °C^h^ | Decomposes at 121 °C^f^; 92 °C (10 mmHg)^f^ | 223 °C (20 mmHg)^c^ | 180 °C (3 mmHg)^d^; 344–345 °C (pressure unspecified)
Density | 1.232 g/mL (25 °C)^h^ | 1.232 g/mL (25 °C)^f^ | 1.366 g/mL^c^ | 0.936 g/mL (20 °C)^d^
Odor | Distinctive^h^ | Disagreeable^f^ | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Insoluble^h^ | 0.13 g/100 mL^f^ | Insoluble^i^ | Insoluble
Organic solvent(s) | Alcohols; benzene carbon tetrachloride; hexane; chloroform; toluene; dibutyl phthalate; acetone; trichloroethylene^h^ | No data | Ethanol, 2 g/100 mL (25 °C)^c^; Methanol, 2.4 g/100 mL (20 °C)^c^; Acetone, 43.6 g/100 mL (20 °C)^c^; Benzene, 51.7 g/100 mL (20 °C)^c^ | Ether
Partition coefficients:
Log K_ow_ | No data | No data | 0.49^c^ | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 0.0877 mm Hg (25 °C)^h^ | 0.09844 mm Hg (25 °C)^j^ | 0.00001 mm Hg (25 °C)^k^ | 3 mm Hg (180 °C)
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | 121 °C^l^ | No data | No data | No data
Flashpoint | 130 °C^h^,^g^ | No data | No data | 178 °C
Flammability limits | Monopropellant^l^ | No data | No data | Slight potential when exposed to heat or flame
Conversion factors | No data | 1 ppm = 7.14 mg/m^3^ ^m^ | No data | No data
Explosive limits | No data | No data | No data | No data

a All information obtained from HSDB 1994 unless otherwise noted

b Sax and Lewis 1989b

c Army 1979

d Sax and Lewis 1989a

e Forman 1988

f ACGIH 1986

g Dean 1974

h Air Force 1985a

i American Cyanamid 1982

j Crater 1929

k Baughman and Perenich 1988

l Rivera 1974