# CHAPTER 8 REFERENCES

* Cited in text

*Abe S, Sasaki M. 1977. Chromosome aberrations and sister chromatid exchanges in Chinese hamster cells exposed to various chemicals. J Nat1 Cancer Inst 58:1635–1641.
*ACGIH. 2016. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, February 28, 2017.
*Agrelo C, Amos H. 1981. DNA repair in human fibroblasts. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:528–532.
*AIHA. 2015. Current ERPG Values (2015). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2015%20ERPG%20Levels.pdf. March 22, 2016.
*Althaus FR, Pitot HC. 1983. A rapid technique for the quantitation of DNA-repair synthesis in the hepatocyte/DNA-repair test for chemical carcinogens. Ann NY Acad Sci 407:463–466.
*Althaus FR, Lawrence SD, Sattler GL, . 1982. Chemical quantification of unscheduled DNA synthesis in cultured hepatocytes as an assay for the rapid screening of potential chemical carcinogens. Cancer Res 42 3010–3015.7093950
*Appel KE, Gorsdorf S, Scheper T, . 1987a. Qtochrome p-450 dependent denitrosation of diphenylnitrosamine: A possible bioactivation pathway. In: Benford DJ, Bridges JW, Gibson GG, eds. Drug metabolism: From molecules to man. Philadelphia, PA: Taylor and Francis, Inc., 644–650.
*Appel KE, Gorsdorf S, Scheper T, . 1987b. Enzymatic denitrosation of diphenylnitrosamine: activation or inactivation? Arch Toxicol 60:204–208.3619641
*Appel KE, Gorsdorf S, Scheper T, . 1987c. Metabolic denitrosation of diphenylnitrosamine: A possible bioactivation pathway. J Cancer Res Clin Oncol 113:131–136.3031080
*Appel KE, Ruf HH, Mahr B, . 1979. Binding of nitrosoamines to cytochrome P-450 of liver microsomes. Chem Biol Interact 28:17–33 227615
*Appel KE, Ruhl CS, Spiegelhalder B, . 1984. Dinitrosation of diphenylnitrosamine in vivo. Toxicol Lett 23:353–358.6523527
*Araki A, Muramatsu M, Matsushima T. 1984. Comparison of mutagenicities of N-nitrosamines on Salmonella tvphimurium Tal100 and Escherichia coli WP2 UVRA/PKMO1 using rat and hamster liver S9 mix. Gann 75:8–16.6373472
*Argus MF, Hoch-Ligeti C. 1961. Comparative study of the carcinogenic activity of nitrosamines. J Natl Cancer Inst 27:695–701.13684183
Ashby J, Tennant RW. 1988. Chemical structure, Salmonella mutagenicity and extent of carcinogenicity as indicators of genotoxic carcinogenesis among 222 chemicals tested in rodents by the U.S. NCI/NTP. Mutat Res 204:17–115.3277047
Atawodi SE, Maduagwu EN. 1987. Interaction of N-nitrosodiphenylamine (NDPA) with rat bile. West Afr J Biol Appl Chem 32:26–29.
*Atawodi SE, Maduagwu EN. 1990. Pharmacokinetics of biliary excretion of N-nitrosodiphenylamine (NDPA) in animals of different species. Eur J Drug Metab Pharmacokinet 15:27–29.2384114
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 2017. N-Nitrosodiphenylamine. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Ayanaba A, Alexander M. 1973. Microbial formation of nitrosamines in vitro. Appl Microbial 25:862–868
*Banerjee S, Yalkowsky SH, Valvani SC. 1980. Water solubility and octanol/water partition coefficients of organic limitations of the solubility partition coefficient correlation. Environ Sci Technol 14:1227–1229.
*Barnes D, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barnhart RR. 1982. Rubber compounding. In: Grayson M and Eckroth D, eds., Kirk-Othmer concise encyclopedia of chemical technology. New York, NY: John Wiley and Sons, 5392.
*Barrows ME, Petrocelli SR, Macek KJ, . 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochiros). In: Haque R, ed., Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
Beck JC, Sterling GP, Hay-Kaufman ML, . 1981. Unscheduled DNA synthesis testing of six promutagens using an autoradiography approach. Environ Mutagen 3:315.
Bellar TA, Budde WL. 1988. Determination of nonvolatile organic compounds in aqueous environmental samples using liquid chromatography/mass spectrometry. Anal Chem 60:2076–2083.
Bennett GF. 1989. Impact of toxic chemicals on local wastewater treatment plant and the environment. Environ Geol Water Sci 13:201–212.
*Boyland E, Carter RL, Gorrod JW, . 1968. Carcinogenic properties of certain rubber additives. Eur J Cancer Clin Oncol 4:233–239.
*Bradley MO, Dysart G, Fitzsimmons K, . 1982. Measurements by filter elution of DNA single and double-strand breaks in rat hepatocytes: Effects of nitrosamines and gamma-irradiation. Cancer Res 42:2592–2597.7083152
*Brambilla G, Carlo P, Finollo R, . 1987. Dose-response curves for liver DNA fragmentation induced in rats by sixteen N-nitroso compounds as measured by viscometric and alkaline elution analyses. Cancer Res 47:3485–3491.3581083
Camanzo J, Rice CP, Jude DJ, . 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan USA tributaries and embayments, 1983. J Great Lakes Res 13:296–309.
*Cardy RH, Lijinsky W, Hildebrandt PK. 1979. Neoplastic and nonneoplastic urinary bladder lesions induced in Fischer 344 rats and BGC3F1 hybrid mice by N-nitrosodiphenylamine. Ecotoxicol Environ Safety 3:29–35.540547
*CELDS. 1990. Computer-environmental legislative data systems. University of Illinois, Urbana, IL. November 28, 1990.
*Clayton GD, Clayton FE, eds. 1978. Patty’s industrial hygiene and toxicology. Vol 1: General principles. New York, NY: John Wiley and Sons, Inc. XV–XVII.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131 3843496
*Clive D, Johnson KO, Spector JFS, . 1979. Validation and characterization of the L517SY/TK+/mouse lymphoma mutagen assay system. Mutat Res 59:61–108.372791
*CLPSD. 1989. Contract Laboratory Statistical Database. U.S. Environmental Protection Agency. July 1989.
*Crebelli R, Falcone E, Aquilina G, . 1984. In vitro mutagenicity of rubber chemicals and their nitrosation products. Toxicol Lett 23:307–313.6395447
Daniel MR, Dehnel JM. 1981. Cell transformation test with baby hamster kidney cells. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:626–637.
*Degirmenci E, Onon Y, Kawara O, . 2000. Genotoxicity analysis and hazardousness prioritization of a group of chemicals. Water Sci Technol 42:125–131.
DeVault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 1:437–594.
*DNR. 1987. Order of the state of Wisconsin natural resources board: Repealing, renumbering, renumbering and amending, amending, repealing and recreating, and creating rules. Section 27, Chapter NR 105. Surface Water Quality Criteria for Toxic Substances. Department of Natural Resources, Madison, Wisconsin.
*Dodd DE, Pluta LJ, Sochaski MA, . 2013. Subchronic urinary bladder toxicity evaluation of N-nitrosodiphenylamine in Fischer 344 rats. J Appl Toxicol 33(5):383–389. 10.1002/jat.2798.22893110
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. February 28, 2017.
Drevon C, Kuroki T, Montesano R. 1978. Microsome-mediated mutagenesis of a Chinese hamster cell line by various chemicals. Mutat Res 53:181–182.
*Druckrey H, Preussmann R, Ivankovic S, . 1967. [Organotropic carcinogenic effects of 65 different N-nitroso compounds on BD-rats.] Z Krebsforsch 69:103–201. (German)4230610
Dunkel VG, Pienta RJ, Sivak A, . 1981. Comparative neoplastic transformation responses of Balb/3T3 cells, Syrian hamster embryo cells, and Rauscher murine leukemia virus-infected Fischer 344 rat emhryo cells to chemical carcinogens. J Natl Cancer Inst 67:1303–1315.6947113
*Eichelberger JW, Kerns EH, Olynyk P, . 1983. Precision and accuracy in the determination of organics in water by fused silica capillary column gas chromatography/mass spectrometry and packed column gas chromatography/mass spectrometry. Anal Chem 55:1471–1479.
*Eisenreich SJ, Looney BB, Thornton DJ. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
El-Yazigi A, Martin CR. Improved analysis of cyclophosphamide by capillary gas chromatography with thermionic (nitrogen-phosphorus) specific detection and silica sample purification. J Chromatogr 374:177 3949926
Enslein K, Tuzzeo TM, Borgstedt HH, . 1987. Prediction of rat oral LD_50_ from Daphnia magna LC50 and chemical structure. In: Kaiser LE. ed. Quantitative Structure Activity Relationship (QSAR) in Environmental Toxicology: II. Proceedings of the 2nd International Workshop on QSAR in Environmental Toxicology, McMaster University, Hamilton, Ontario, Canada, June 9-13, l986, 91–106.
*EPA. 1979. Water-related environmental fate of 129 priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water and Waste Management, Office of Water Planning and Standards. EPA440479029B. 2:100-1 to 100-5.
EPA. 1990a. Ambient water quality criteria for nitrosamines. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA440580064.
*EPA. 1980b. Guidelines and methodology used in the preparation of health effects assessment chapters of the ambient water quality criteria documents. U.S. Environmental Protection Agency. Federal Register 45:79347–79357.
EPA. 1981a. Chemical hazard information profile: N-Nitrosodiphenylamine. Washington, DC: U.S. Environmental Protection Agency. (Draft)
EPA. 1981b. Treatability manual. Vol 1. Treatability Data. Washington, DC: U.S. Environmental Protection Agency. EPA600880042.
*EPA. 1982a. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440481014.
EPA. 1982b. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater: Purgeable halocarbons - Method 607. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA600482057. 1–10.
*EPA. 1985a. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.
*EPA. 1985b. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Federal Register 50:3474–13522.
EPA. 1985c. Health and environmental effects profile for N,N-diphenylamine. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. ECAO-CIN-P118.
EPA. 1985d. Notification requirements: Reportable quantity adjustments. Final rule and proposed rule. U.S. Environmental Protection Agency. Federal Register 50:13456–13522.
EPA. 1986a. Guidelines for carcinogenic risk assessment. U.S. Environmental Protection Agency. Federal Register 51:33992–34003.
*EPA. 1986b. Health and environmental effects profile for nitrosamines. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. ECAO-CIN-P180. 69
EPA. 1986c. Reference values for risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. ECAOCIN477.
EPA. 1987a. Graphical Exposure Modeling System (GEMS). Personal computer version, April. Research Triangle Park, NC: U.S. Environmental Protection Agency.
*EPA. 1987b. Ground-water monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264, Appendix IX.
*EPA. 1987c. List (phase 1) of hazardous constituents for ground-water monitoring. U.S. Environmental Protection Agency. Federal Register 52:25942–25952.
*EPA. 1987d. Organic chemicals and plastics and synthetic fibers category effluent limitations guidelines, pretreatment standards, and new source performance standards. U.S. Environmental Protection Agency. Federal Register 52:42522–42568.
*EPA. 1987e. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Federal Register 52:21152–21208.
*EPA. 1988. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.
*EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA60088066F.
*EPA. 1989b. Toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 401.15.
*EPA. 1990. Health effects assessment summary tables. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Assessment and Criteria Office.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA 816-F-09-0004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. October 10, 2017
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/aegl/access-acute-exposure-guideline-levels-aegls-values#chemicals. February 28, 2017.
*Evans EL, Mitchell AD. 1981. Effects of 20 coded chemicals on sister chromatid exchange frequencies in cultured Chinese hamster cells. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:538–550.
*Fajen JM, Carson GA, Rounbehler DP, . 1979. N-Nitrosamines in the rubber and tire industry. Science 205:1262–1264.472741
*Fajen JM, Fine DH, Rounbehler DP. 1980. N-Nitrosamines in the factory environment. IARC Sci Publ 31:517–528.
Fang Y, Ding JH, Liu SL. 1981. A sensitive gas chromatograph detector for nitrosamines. Analytical Letters 14:977–984.
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. February 28, 2017.
*Fine DH, Rose R, Rounbehler DP, . 1976. Analysis of nonionic nonvolatile N-nitroso compounds in foodstuffs. J Agric Food Chem 24:1069–1071. 70965595
*Friedman MA, Staub J. 1976. Inhibition of mouse testicular DNA synthesis by mutagens and carcinogens as a potential simple mammalian assay for mutagenesis. Mutat Res 37:67–76.967187
*FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Washington, DC: Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee.
*Garman JR, Freund T, Lawless EW. 1987. Testing for groundwater contamination at hazardous waste sites. J Chromatogr Sci 25:328–337.
*Gerstle RW. 1988. Emissions of trace metals and organic compounds from sewage sludge incineration. In: Proceedings of the Annual Meeting of APCA, Dallas TX, June 19-24, 1988. 81:1–15.
*Great Lakes Water Quality Board. 1983. An inventory of chemical substances identified in the Great Lakes ecosystem. Vol. 1. Summary. Report to the Great Lakes Water Quality Board. Windsor, Ontario, Canada, 1–195.
*Green MHL. 1981. A differential killing test using an improved repairing deficient strain on Escherichia coli. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:183–194.
Gurka DF, Billets S, Brasch JW, . 1985. Tetrachlorodibenzodioxin isomer differentiation by microdiffuse reflectance fourier transform infrared spectrometry at the low nanogram level. Anal Chem 57:1975–1979.
Hansch C, Leo AJ. 1985. Medchem project. Issue No. 26. Claremont, CA: Pomona College.
*Hari S, Nishikawa J, Horiguchi K, . 2006. Anti-androgenic activity of N-nitrosodibenzylamine, N-nitrosodiphenylamine and N-nitrosodicyclohexylamine. J Health Sci 52(5):522–531. 10.1248/jhs.52.522.
*Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2:249–272.24264296
*HAZDAT. 1992. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. October 30, 1992.
Holder JW. 1987. Review of toxicological profile on N-nitrosodiphenylamine. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Cancer Assessment Group.
HSDB. 1987. Hazardous Substance Data Bank. Oak Ridge, TN: Oak Ridge National Laboratory. May 1987.
*HSDB. 1990. Hazardous Substance Data Bank. Bethesda, MD: National Library of Medicine, National Toxicology Information Program. May 14, 1990.
*HSDB. 1992. Hazardous substance data bank. Bethesda, MD: National Library of Medicine, National Toxicology Information System. June 1992. 71
*IARC. 1982a. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man. Vol. 27: Some aromatic amines, anthroquinones and nitroso compounds and inorganic fluorides used in drinking water and dental preparations. N-Nitrosodiphenylamine. Lyon, France: World Health Organization, International Agency for Research on Cancer, 213–225.
IARC. 1982b. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man. Vol. 28: The rubber industry. Lyon, France: World Health Organization, International Agency for Research on Cancer, 255.
* IARC. 1987. IARC monographs on the evaluation of the carcinogenic risks to humans. Suppl 7: Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Lyon, France: World Health Organization, International Agency for Research on Cancer, 67.
*IARC. 2017. Agents classified by the IARC Monographs, Volumes 1–117. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. February 28, 2017.
*Ichinotsubo D, Mower H, Mandel M. 1981. Mutagen testing of a series of paired compounds with the Ames Salmonella testing system. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:298–301.
*Innes JRM, Ulland BM, Valeria MG, . 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice: A preliminary note. J Nat1 Cancer Inst 42:1101–1114.
IRIS. 1987. Integrated Risk Information System. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office.
*IRIS. 1990. Integrated Risk Information Systems. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office.
*IRIS. 2002. N-Nitrosodiphenylamine; CASRN 86-30-6. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0178_summary.pdf. May 11, 2017.
IRPTC. 1987. IRPTC data profile on diphenylnitrosamine. Geneva, Switzerland: United Nations Environment Programme, International Register of Potentially Toxic Chemicals.
*Ishidate M, Odashima S. 1977. Chromosome tests with 134 compounds on Chinese hamster cells in vitro - A screening for chemical carcinogens. Mutat Res 4837–354.
Isnard P, Lambert S. 1988. Estimating bioconcentration factors from octanol-water partition coefficient and aqueous solubility. Chemosphere 17:21–34.
*Iversen OH. 1980. Tumorigenicity of N-nitroso-diethyl, -dimethyl and -diphenyl-amines in skin painting experiments: A study utilizing the tetrazolium test and skin application on hairless mice. Eur J Cancer 16:695–698.
*Jagannath DR, Vultaggio DM, Brusick DJ. 1981. Genetic activity of 42 coded compounds in the mitotic gene conversion assay using Saccharomyces cerevisiae strain D4. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:456–467.
*Jones CA, Huberman E. 1980. A sensitive hepatocyte-mediated assay for the metabolism of nitrosamines to mutagens for mammalian cells. Cancer Res 40:406–411.7188682
Jones CA, Dunkel VC, Huberman E. 1980. The relationship between metabolism of nitrosamines to mutagens for mammalian cells and liver carcinogenesis. Proceedings of the American Association for Cancer Research 21:76.
*Jotz MM, Mitchell AD. 1981. Effects of 20 coded chemicals on the forward mutation frequency at the thymidine kinase locus in L5178Y mouse lymphoma cells. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:580–593.
*Kada T. 1981. The DNA-damaging activity of 42 coded compounds in the ret-assay. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:175–182.
Karickhoff SW. 1985. Pollutant sorption in environmental systems. In: Neely WB, Glau GE, eds. Environmental exposure from chemicals. Boca Raton, FL: CRC Press, Inc., 13–54.
*Kassinova GV, Koval’tsova SV, Marfin, SV, . 1981. Activity of 40 coded compounds in differential inhibition and mitotic crossing-over assays in yeast. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:434–455.
*Khudoley VV, Mizgireuv I, Pliss GB. 1987. [The study of mutagenic activity of carcinogens and other chemical agents with Salmonella typhimurium assays: Testing of 126 compounds.] Arch Geschwulstforsch 57:453–462. (German)3435224
*Knasmuller S, Szakmary A, Kehrer M. 1990. Use of differential DNA-repair host mediated assays to investigate the biotransformation of xenobiotics in Drosophila melanopaster. I. Genotoxic effects of nitrosamines. Chem-Biol Interactions 17–29.
Korhonen A, Hemminki K, Vainio H. 1983. Toxicity of rubber chemicals towards three-day chicken embryos. Scand J Work Environ Health 9:115–119.6648408
*Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kubo T, Urano K, Utsumic H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554.
Kubrina LN, Yakubovich LM, Vanin AF. 1988. [Release of nitric oxide from organic nitroso compounds in animals.] Izv Akad Nauk SSSR 844–850. (Russian)
*Kuroki T, Drevon C, Montesano R. 1977. Microsome-mediated mutagenesis in V79 Chinese hamster cells by various nitrosamines. Cancer Res 37:1044–1050.321116
Layer RW, Kehe HJ. 1978. Amines, aromatic (diarylamines). In: Grayson M and Eckroth D, eds. Kirk-Othmer concise encyclopedia of chemical technology. New York, NY: John Wiley and Sons, 331, 336.
Leifer Z, Hyman J, Rosenkranz HS. 1981. Determination of genotoxic activity using DNA polymerasedeficient and proficient E. coli. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:127–139.
Lijinsky W. 1987. Carcinogenicity and mutagenicity of N-nitroso compounds. Mol Toxicol 1:I07–120. 73
*Lindahl-Kiessling K, Karlberg I, Olofsson A-M. 1989. Induction of sister-chromatid exchanges by direct and indirect mutagens in human lymphocytes, co-cultured with intact rat liver cells: Effect of enzyme induction and preservation of the liver cells by freezing in liquid nitrogen. Mutat Res 211:77–88.2922003
*Loprieno N. 1981. Screening of coded carcinogenic/noncarcinogenic chemicals by a forward-mutation system with the yeast Schizosaccharomvces pombe. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:424–433
*Lyman WJ, Reehl WF, RosenbIatt DH. 1982. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill, 4–9, 15–16, 15–29.
*Magee PN, Montesano R, Preussman R. 1976. N-nitroso compounds and related carcinogens. Washington, DC: American Chemical Society Monographs 173:491–625.
*Mallik MAB, Tesfai K 1981. Transformation of nitrosamines in soil and in vitro by soil microorganisms. Bull Environ Contam Toxicol 27:115–121.7296028
*Mamber SW, Bryson V, Katz SE. 1983. The Escherichia coli WP2/WP100 ret assay for detection of potential chemical carcinogens. Mutat Res 119:135–144.6338367
Marchand M. 1989. [Contamination of a continental waters by organic micropollutants.] J Water Science 2:229–264. (French)
*Martin CN, McDermid AC. 1981. Testing of 42 coded compounds for their ability to induce unscheduled DNA repair synthesis in HeLa cells. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:533–537.
*Matsushima T, Tadamoto Y, Shirai A, . 1981. Reverse mutation test on 42 coded compounds with E. coli WP2 system. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:387–395.
*Matthews EJ, Spalding JW, Tennant RW. 1993. Transformation of BALB/c-3T3 cells: IV. Rank-ordered potency of 24 chemical responses detected in a sensitive new assay procedure. Environ Health Perspect 101 Suppl 2:319–345.8243401
*McFee AF, Jauhar PP, Lowe KW, . 1989. Assays of three carcinogen/non-carcinogen chemical pairs for in vivo induction of chromosome aberrations, sister chromatic exchanges and micronuclei. Environ Mol Mutagen 14:207–220.2583129
McGregor DB, Riach CG, Hastwell RM, . 1980. Genotoxic activity in microorganisms of tetryl, 1,3-dinitrobenzene and 1,3,5-trinitrobenzene. Environ Mutagen 2:531–541.7030731
*McQueen CA, Kreiser DM, Hurley PM, . 1983. The hepatocyte primary culture (HPC)/DNA repair test using mouse and hamster cells. Environ Mutagen 5:1–8
*Mejstrik V, Drzkova L, Jandera J, . 1989. Determination of volatile and nonvolatile nitrosamines in air. Chemical Industry 39:206–207. (Czech) 74
Mirvish SS. 1975. Formation of N-nitroso compounds: chemistry, kinetics, and in vivo occurrence. Toxicol Appl Pharmacol 31:325–351.238307
+Mishra NK, Wilson CM, Pant KJ, . 1978. Simultaneous determination of cellular mutagenesis and transformation by chemical carcinogens in Fisher rat embryo cells. J Toxicol Environ Health 4:79–91.633413
*Nagao M, Takahashi Y. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:302–313.
Nakahama T, Urakubo G. 1987. Degradation of N-nitrosamines by enteric bacteria and Pseudomonas aeruginosa. Journal Food Hygienic Society Japan 28:136–141.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1991. National Air Toxics Information Clearinghouse. Data base report on state, local, and EPA air toxics activities. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Washington, DC. January 1, 1991.
+NCI. 1968. Evaluation of carcinogenic, teratogenic and mutagenic activities of selected pesticides and industrial chemicals. Vol. 1. Carcinogenic Study. Bethesda, MD: U.S. Department of Health, Education, and Welfare, Public Health Service, National Institute of Health, National Cancer Institute. NTIS PB 223
*NCI. 1979. Bioassay of N-nitrosodiphenylamine for possible carcinogenicity. Bethesda, MD: U.S. Department of Health, Education, and Welfare, Public Health Service, National Institute of Health, National Cancer Institute. DHEW Pub1 (NIH) 79-1720.
*Negishi T, Shiotani T, Fujikawa K, . 1991. The genotoxicities of N-nitrosamines in Drosophila melanogaster in vivo: The correlation of mutagenicity in the wing spot test with the DNA damages detected by the DNA-repair test. Mutat Res 252(2):119–128.1901957
Nicola RM, Branchflower R, Pierce D. 1987. Chemical contaminants in bottomfish. J Environ Health 49:342–347.
*NIOSH. 1982. Health hazard evaluation--determination report no. Sl-045B. Uniroyal, Incorporated, Mishawaka, IN. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1983. N-Nitroso compounds in the factory environment. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHHS (NIOSH) publication no. 83-114.
*NIOSH. 1984. Health hazard evaluation--determination report no. 79-109. Kelly Springfield Tire Company, Cumberland, MD. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 2016. NIOSH pocket guide to chemical hazards. Index of Chemical Abstracts Service Registry Numbers (CAS No.). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgdcas.html. May 11, 2017.
*Nishie K, Norred W, Wasserman A, . 1972. Phototoxicity and differential hepatotoxicity as biological indicators of nitrosamine activity. Toxicol Appl Pharmacol 23:680–691.4630166
*Nishihara T, Nishikawa J, Kanayama T, . 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci 46(4):282–298. 10.1248/jhs.46.282.
*NOES. 1990. National Occupational Exposure Survey (1981-1983). U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH. July 1, 1990.
*NTP. 2016. Report on Carcinogens, Fourteenth Edition. CASRN Index in MS Excel. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. May 11, 2017.
*Oberly TJ, Bewsey BJ, Probst GS. 1984. An evaluation of the L-517SY TK+/− mouse lymphoma forward mutation assay using 42 chemicals. Mutat Res 125:291–306.6700611
*OHM/TADS. 1990. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. September, 1986.
*OSHA. 2016a. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000 https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2016b. Subpart D Occupational health and environment controls. Section 1926.55 - Gases, vapors, fumes, dusts, and mists. Appendix A to Part 1926.55 - threshold limit values of airborne contaminants for construction. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.55 https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
*OSHA. 2016c. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1000 https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol7/pdf/CFR-2016-title29-vol7-sec1915-1000.pdf. March 6, 2017.
*Ohshima H, Bereziat JC, Bartsch H. 1982. Measurement of endogenous N-nitrosation in rats and humans by monitoring urinary and faecal excretion of N-nitrosamino acids. IARC Sci Publ 41:397–411.
*Perry PE, Thomson EJ. 1981. Evaluation of the sister chromatid exchange method in mammalian cells as a screening system for carcinogens. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:560–569.
Pienta RJ, Kawalek JC. 1981. Transformation of hamster embryo cells by aromatic amines. Natl Cancer Inst Monogr 58:243–251.
*Phelps JB, Garriott ML, Hoffman WP. 2002. A protocol for the in vitro micronucleus test. II. Contributions to the validation of a protocol suitable for regulatory submissions from an examination of 10 chemicals with different mechanisms of action and different levels of activity. Mutat Res 521(1–2):103–112.12438008
*Preussman R, Stewart BW. 1984. N-Nitroso carcinogens. Washington, DC: American Chemical Society Monographs 182:643–828.
Pristera F. 1953. Analysis of propellants by infrared spectroscopy. Anal Chem 25:844–866.
*Probst GS, McMahon RE, Hill LE, . 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: Comparisons with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
*Pylypiw HM Jr, Harrington GW. 1981. Determination of N-nitroso-N-methylaniline in whole blood, serum, and urine. Anal Chem 53:2365–2367.7316215
*Raineri R, Poiley JA, Andrews AW, . 1981. Greater effectiveness of hepatocyte and liver S9 preparations from hamsters than rat preparations in activating N-nitroso compounds to metabolites mutagenic to Salmonella. J Nat1 Cancer Inst 67:1117–1122.
*Rhoades JW, Hosenfeld JM, Taylor JM, . 1980. Comparison of analyses of wastewaters using various detectors. IARC Sci Publication 31:377–387.
*Rosenkranz HS, Hyman J, Leifer Z. 1981. DNA polymerase deficient assay. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:210–218.
RTECS. 1984. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC.
*Rundell JO, Guntakatta M, Matthews EJ. 1983. Criterion development for the application of BALB/C3T3 cells to routine testing for chemical carcinogenic potential. In: Waters MD, ed. Environmental science research: Short-term bioassays in the analysis of complex environmental mixtures III. New York, NY: Plenum Press, 27:309–324.
Sadtler. 1961. Sadtler standard spectra. Philadelphia, PA: Sadtler Research Laboratories.
*Salamone MF, Heddle JA, Katz M. 1981. Mutagenic activity of 41 compounds in the in vivo micronucleus assay. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:686–697.
SANSS. 1987. Structure and Nomenclature Search System. Baltimore, MD: Chemical Information Systems, Inc.
Sax NI, Lewis RJ, eds. 1989. Dangerous properties of industrial materials. Volume II, 7th edition. New York, NY: Van Nostrand Reinhold, 1484.
*Schrenk D, Schwarz M, Tennekes HA, . 1982. A novel pathway of nitrosamine metabolism in liver microsomes: Denitrosation of nitrosamines by cytochrome P 450. In: Snyder R, ed. Advances in experimental medicine and biology: Biological reactive intermediates. II: B chemical mechanisms and biological effects. New York, NY: Plenum Press, 136:1157–1164.
*Schut HA, Castonguay A. 1984. Metabolism of carcinogenic amino derivatives in various species and DNA alkylation by their metabolites. Drug Metab Rev 15:753–839.6437779
*Sharma KS, Kumari S, Goel VK. 1986. Organic photochemistry. Part II. Photolysis of N-nitrosodiphenylamines and N-nitrosocarbazole. Indian J Chem [B] 25B:435–436.
*Sharp DC, Parry JM. 1981a. Induction of mitotic gene conversion by 41 coded compounds using the yeast culture JD1. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:491–501.
*Sharp DC, Parry JM. 1981b. Use of repair-deficient strains of yeast to assay the activity of 40 coded compounds. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of shortterm tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:502–516.
*Sheweita SA, Mostafa MH. 1996a. N-Nitroso compounds induce changes in carcinogen-metabolizing enzymes. Cancer Lett 106(2):243–249.8844979
*Sheweita SA, Mostafa MH. 1996b. N-Nitrosamines and their effects on the level of glutathione, glutathione reductase and glutathione S-transferase activities in the liver of male mice. Cancer Lett 99(1):29–34.8564926
*Shimada T, Iwasaki M, Martin MV, . 1989. Human liver microsomal cytochrome p-450 enzymes involved in the bioactivation of procarcinogens detected by umu gene response in Salmonella tvphimurium TA 1535-pSK1002. Cancer Res 49:3218–3228.2655891
Simmon VF. 1979. In vitro mutagenicity assays of chemical carcinogens and related compounds with Salmonella typhimurium. J Natl Cancer Inst 62:901–909.372658
*Sina JF, Bean CL, Dysart GR, . 1983. Evaluation of the alkaline elutiom/rat hepatocyte assay as a predictor of carcinogenic/mutagenic potential. Mutat Res 113:357–391.6877265
*Snyder RD, Matheson DW. 1985. Nick translation -- a new assay for monitoring DNA damage and repair in cultured human fibroblasts. Environ Mutagen 7:267–279.3899625
Spiegelhalder B, Preussmann R. 1982. Nitrosamines and rubber. IARC Sci Publ 41:231–243
SRI. 1986. 1986 Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 968.
*SRI. 1990. 1990 Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 947.
*Straif K, Weiland SK, Bungers M, . 2000. Exposure to high concentrations of nitrosamines and cancer mortality among a cohort of rubber workers. Occup Environ Med 57(3):180–187.10810100
*Swarm RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
*Tabak HH, Quave SA, Maschni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Cont Fed 53:1503–1518.
*Tatsumi K, Yamada H, Kitamura S. 1983. Reductive metabolism of N-nitrosodiphenylamine to the corresponding hydrazine derivative. Arch Biochem Biophys 226:174–181.6639050
*Taylor R, Son PN. 1982. Rubber chemicals. In: Grayson M and Eckroth D, eds. Kirk-Othmer concise encyclopedia of chemical technology. New York, NY: John Wiley and Sons, 20:355–359.
*Topham JC. 1981. Evaluation of some chemicals in the sperm morphology assay. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:718–720.
*TRI16. 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 29, 2017.
Tricker AR, Spiegelhalder B, Preussmann R. 1989. Environmental exposure to preformed nitroso compounds. Cancer Surv 8:251–272.2696580
*Tsuchimoto T, Matter BE. 1981. Activity of coded compounds in the micronucleus test. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:705–711.
*Tweats DJ. 1981. Activity of 42 coded compounds in a differential killing test using Escherichia coli strains WP2, WP7 and CM871. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:199–209.
USITC. 1978a. Imports of benzenoid chemicals and products, 1977. Washington, DC: U.S. International Trade Commission. USITC Publication 900, 28.
USITC. 1978b. Synthetic organic chemicals: United States production and sales, 1977. Washington, DC: U.S. International Trade Commission. USITC Publication 920, 235.
USITC. 1979. Synthetic organic chemicals: United States production and sales, 1978. Washington, DC: U.S. International Trade Commission. USITC Publication 1001, 213.
USITC. 1980. Synthetic organic chemicals. United States production and sales, 1979. Washington, DC: U.S. International Trade Commission. USITC Publication 1099, 175.
USITC. 1981. Synthetic organic chemicals. United States production and sales, 1980. Washington, DC: U.S. International Trade Commission. USITC Publication 1183, 175.
*USITC. 1983. Imports of benzenoid chemicals and products, 1982. Washington, DC: U.S. International Trade Commission. USITC Publication 1401, 27.
USITC. 1984. Synthetic organic chemicals. United States production and sales, 1983. Washington, DC: U.S. International Trade Commission. USITC Publication 1588, 154.
*USITC. 1985. Synthetic organic chemicals. United States production and sales, 1984. Washington, DC: U.S. International Trade Commission. USITC Publication 1745, 149, 152.
*USITC. 1986. Synthetic organic chemicals. United States production and sales, 1985. Washington, DC: U.S. International Trade Commission. USITC Publication 1892, 153, 156.
*USITC. 1987. Synthetic organic chemicals. United States production and sales, 1986. Washington, DC: U.S. International Trade Commission. USITC Publication 2009, 118–120
*USITC. 1988, Synthetic organic chemicals. United States production and sales, 1987. Washington, DC: U.S. International Trade Commission. USITC Publication 2118, 9-2 to 9-4.
*Vogel E, Blijleven WGH, Kortselius MJH, . 1981. Mutagenic activity of 17 coded compounds in the sex-linked recessive lethal test in Drosophila melanogaster. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:660–665.
*Wagner ED, Hsu KM, Lagunas A, . 2012. Comparative genotoxicity of nitrosamine drinking water disinfection byproducts in Salmonella and mammalian cells. Mutat Res 741(1–2):109–115. 10.1016/j.mrgentox.2011.11.006.22108029
*Wakabayashi K, Nagao M, Kawachi T, . 1981. Co-mutagenic effect of norharmon with N-nitrosamine derivatives. Mutat Res 80:1–7.7010130
*Wakabayashi K, Nagao M, Kawachi T, . 1982. Mechanism of appearance of mutagenicity of N-nitrosodiphenylamine with norharmon. IARC Sci Pub1 41:695–707.
Weast RC, ed. 1985. CRC handbook of chemistry and physics. 66th ed. Boca Raton, FL: CRC Press, Inc., C-250.
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Zhilova NA, Kasparov AA. 1966. [Comparative toxicological characteristics of antiscorchings: phthalic anhydride and N-nitrosodiphenylamine (Vulkalent A).] Gig Tr Prof Zabol 10:60–62. (Russian)
*Zielenska M, Guttenplan JB. 1988. Mutagenic activity and specificity of N-nitrosomethylaniline and N-nitrosodiphenylamine in Salmonella. Mutat Res 202:269–276.3054528
Zimmermann FK, Scheel I. 1981. Induction of mitotic gene conversion in strain D7 of Saccharomvces cerevisiae by 42 coded compounds. In: De Serres FJ, Ashby J, eds. Progress in mutation research: Evaluation of short-term tests for carcinogens: Report of the international collaborative program. New York, NY: Elsevier, 1:481–490.