# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Obaid Faroon, DVM, Ph.D.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Fernando Llados, Ph.D.
  Lisa Ingerman, Ph.D., DABT
  Laura McIlroy, B.A
- SRC, Inc., North Syracuse, NY