# VERSION HISTORY

Date | Description
December 1988 | Final toxicological profile released
April 1993 | Updated final toxicological profile released
September 2017 | Update of data in Chapters 2, 3, and 7