# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information on the chemical identity of N-Nitrosodiphenylamine is provided in Table 4-1.

Table 4-1 Chemical Identity of N-Nitrosodiphenylamine

Characteristic | Information | Reference
Chemical name | N-Nitrosodiphenylamine | HSDB 1990
Synonym(s) and registered trade name(s) | Benzenamine; diphenyl- nitrosamine; diphenylamine, N-nitroso; N-nitroso-N-phenylaniline; diphenyl-N-nitrosamine; N,N-diphenyl- nitrosamine; NDPA:, NDPHA; nitrous diphenylamide; Retarder J; Redax; Vulkalent A; Vultrol; Vulcatard A; Curetard A; Delac J; Naugard TJB; TJB | OHM/TADS 1990
Chemical formula | C_12_H_10_N_2_O | HSDC 1990
Chemical structure | [image] | IARC 1982a
Identification numbers:
CAS Registry | 86-30-6 | HSDB 1990

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information on the physical and chemical properties of N-Nitrosodiphenylamine is provided in Table 4-2.

Table 4-2 Physical and Chemical Properties of N-Nitrosodiphenylamine

Property | Information | Reference
Molecular weight | 198.23 | HSDB 1990
Color | Orange-brown; yellow | HSDB 1990
Physical state | Amorphous solid; plates | HSDB 1990
Melting point | 66.5°C | HSDB 1990
Boiling point | No data
Density at 25°C | 1.23 g/cm^3^ | IARC 1982a
Odor | No data
Odor threshold:
Water | No data
Air
Solubility:
Water at 25°C | 40 mg/L | EPA 1982a
Organic solvents | Miscible with acetone, benzene, ethanol, ethylene dichloride | HSDB 1990
Partition coefficients:
Log K_ow_ | 2.57–3.13 | Banerjee et al. 1980
Log K_oc_ | 2.92–3.26 | Lyman et al. 1982
Vapor pressure at 25°C | 0.1 mmHg | HSDB 1990
Henry’s law constant at 25°C | 6.6x10^-4^ atm-m^3^/mol | EPA 1982a
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | 1 mg/L=123.5 ppm; 1 ppm=8.1 mg/m^3^ at 25°C, 760 mmHg | Clayton 1978
Explosive limits | No data