# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## N-Nitrosodiphenylamine Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodiphenylamine
CAS Numbers: | 86-30-6
Date: | April 1993
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies were located.

Agency Contact (Chemical Manager): Obaid Faroon, DVM, Ph.D.

## N-Nitrosodiphenylamine Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodiphenylamine
CAS Numbers: | 86-30-6
Date: | April 1993
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies were located.

Agency Contact (Chemical Manager): Obaid Faroon, DVM, Ph.D.

## N-Nitrosodiphenylamine Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodiphenylamine
CAS Numbers: | 86-30-6
Date: | April 1993
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were located.

Agency Contact (Chemical Manager): Obaid Faroon, DVM, Ph.D.

## N-Nitrosodiphenylamine Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodiphenylamine
CAS Numbers: | 86-30-6
Date: | April 1993
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The acute oral toxicity of N-nitrosodiphenylamine has been examined in a dietary exposure study in rats (Dodd et al. 2013) and in a mouse gavage study (Nishie et al. 1972); both studies only examined a limited number of potential toxicity targets. Dodd et al. (2013) reported diffuse hyperplasia in the urinary bladder of rats exposed to 183 mg/kg/day for 2 weeks. Nishie et al. (1972) reported that no histological alterations were observed in the livers of mice administered 350 mg/kg/day N-nitrosodiphenylamine for 4 days. The urinary bladder has been identified as the most sensitive target following intermediate- and chronic-duration oral exposure; however, the observed hyperplasia was not considered a suitable basis for an MRL because the lesion was considered preneoplastic.

Agency Contact (Chemical Manager): Obaid Faroon, DVM, Ph.D.

## N-Nitrosodiphenylamine Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodiphenylamine
CAS Numbers: | 86-30-6
Date: | April 1993
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: Two studies have evaluated the oral toxicity of N-nitrosodiphenylamine following intermediate-duration oral exposure (Dodd et al. 2013; NCI 1979). Both studies have examined a limited number of endpoints. Dodd et al. (2013) reported diffuse hyperplasia in the urinary bladder of rats exposed via the diet to 123 mg/kg/day N-nitrosodiphenylamine for at least 4 weeks. NCI (1979) reported decreases in body weight gain in rats exposed to 200 mg/kg/day via the diet for 8–11 weeks. Although the identification of the urinary bladder as a sensitive target of toxicity is supported by chronic-duration oral studies, the observed hyperplasia was considered a pre-neoplastic lesions and was not considered suitable for derivation of an MRL.

Agency Contact (Chemical Manager): Obaid Faroon, DVM, Ph.D.

## N-Nitrosodiphenylamine Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodiphenylamine
CAS Numbers: | 86-30-6
Date: | April 1993
Date: | March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: The chronic-duration oral database for N-nitrosodiphenylamine consists of a study of rats and mice exposed via the diet for 100 weeks (Cardy et al. 1979; NCI 1979). The observed effects included urinary bladder epithelial hyperplasia and corneal opacities in rats exposed to 50 mg/kg/day, urinary bladder squamous metaplasia in rats exposed to 200 mg/kg/day, and decreases in body weight and inflammation and epithelial hyperplasia in the urinary bladder of mice exposed to 301 mg/kg/day. No other adverse effects were reported in the wide range of tissues examined. These data, supported by similar findings following acute and intermediate oral exposure, suggested that the urinary bladder is the most sensitive target of toxicity. The epithelial hyperplasia was not considered a suitable basis for an MRL because the lesion was considered preneoplastic.

Agency Contact (Chemical Manager): Obaid Faroon, DVM, Ph.D.