# CHAPTER 8 REFERENCES

Abanobi SE, Farber E, Sarma DS. 1979. Persistence of DNA damage during development of liver angiosarcoma in rats fed dimethylnitrosamine. Cancer Res 39(5):1592–1596.570883
Abdu SB, Al-Bogami FM. 2019. Influence of resveratrol on liver fibrosis induced by dimethylnitrosamine in male rats. Saudi J Biol Sci 26(1):201–209. 10.1016/j.sjbs.2017.09.003.30622427
Abe S, Sasaki M. 1982. Induction of sister-chromatid exchanges by indirect mutagens/carcinogens in cultured rat hepatoma and esophageal tumor cells and in Chinese hamster Don cells co-cultivated with rat cells. Mutat Res 93(2):409–418. 10.1016/0027-5107(82)90154-3.
Abusallout I, Hua G. 2016. Photolytic dehalogenation of disinfection byproducts in water by natural sunlight irradiation. Chemosphere 159:184–192. 10.1016/j.chemosphere.2016.05.090.27289205
Adair GM, Carver JH. 1983. Induction and expression of mutations at multiple drug-resistance marker loci in Chinese hamster ovary cells. Environ Mutagen 5(2):161–175. 10.1002/em.2860050206.6574908
Adami HO, Trolle Andersen I, Heide-Jørgensen U, 2021. Ranitidine use and risk of upper gastrointestinal cancers. Cancer Epidemiol Biomarkers Prev 30(12):2302–2308. 10.1158/1055-9965.Epi-21-0831.34620629
Alaneme FO, Maduagwu EN. 2004. Pharmacokinetics of biliary excretion of N-nitrosodimethylamine in rats fed diets containing levels of protein. Malawi Med J 16(1):6–8.27528980
Aleksandrov VA. 1974. [Embryotoxic and transplacental oncogenic action of symmetrical dialkylnitrosamines on the progeny of rats]. Bull Exp Biol Med 78:1308–1310. (Russian)
Althoff J, Pour P, Grandjean C, 1977. Transplacental effects of nitrosamines in Syrian hamsters. III. Dimethyl- and dipropylnitrosamine. Z Krebsforsch Klin Onkol Cancer Res Clin Oncol 90(1):79–86. 10.1007/bf00306022.145751
Amacher DE, Paillet SC. 1983. The activation of procarcinogens to mutagens by cultured rat hepatocytes in the L5178Y/TK mutation assay. Mutat Res 113(1):77–88. 10.1016/0165-1161(83)90242-x.6828044
Anderson LM. 1988. Increased numbers of N-nitrosodimethylamine-initiated lung tumors in mice by chronic co-administration of ethanol. Carcinogenesis 9(9):1717–1719. 10.1093/carcin/9.9.1717.3409476
Anderson ER, Shah YM. 2013. Iron homeostasis in the liver. Compr Physiol 3(1):315–330. 10.1002/cphy.c120016.23720289
Anderson LM, Giner-Sorolla A, Ebeling D. 1978. Effects of imipramine, nitrite, and dimethylnitrosamine on reproduction in mice. Res Commun Chem Pathol Pharmacol 19(2):311–327.644123
Anderson LM, Harrington GW, Pylypiw HM, 1986. Tissue levels and biological effects of N-nitrosodimethylamine in mice during chronic low or high dose exposure with or without ethanol. Drug Metab Dispos 14(6):733–739.2877835
Anderson LM, Hagiwara A, Kovatch RM, 1989. Transplacental initiation of liver lung neurogenic and connective tissue tumors by N-nitroso compounds in mice. Fundam Appl Toxicol 12(3):604–620.2731672
Anderson LM, Carter JP, Logsdon DL, 1992a. Characterization of ethanol's enhancement of tumorigenesis by N-nitrosodimethylamine in mice. Carcinogenesis 13(11):2107–2111. 10.1093/carcin/13.11.2107.1423883
Anderson LM, Koseniauskas R, Burak ES, 1992b. Reduced blood clearance and increased urinary excretion of N-nitrosodimethylamine in patas monkeys exposed to ethanol or isopropyl alcohol. Cancer Res 52(6):1463–1468.1540953
Anderson LM, Souliotis VL, Chhabra SK, 1996. N-Nitrosodimethylamine-derived O(6)-methylguanine in DNA of monkey gastrointestinal and urogenital organs and enhancement by ethanol. Int J Cancer 66(1):130–134. 10.1002(SICI)1097-0215(19960328)66:1<130::AID-IJC22>3/.0.CO;2-G.8608956
Anderson LM, Diwan BA, Fear NT, 2000. Critical windows of exposure for children's health: cancer in human epidemiological studies and neoplasms in experimental animal models. Environ Health Perspect 108(suppl 3):573–594. 10.1289/ehp.00108s3573.10852857
Andrae U, Schwarz LR. 1981. Induction of DNA repair synthesis in isolated rat hepatocytes by 5-diazouracil and other DNA damaging compounds. Cancer Lett 13(3):187–193. 10.1016/0304-3835(81)90017-3.6271392
Andrae U, Jahnel P, Greim H. 1979. Induction of DNA repair synthesis in human lymphoblastoid cells by metabolically activated chemicals as short-term test for DNA-damaging compounds [abstract]. Mutat Res 64:125.
Annola K, Heikkinen AT, Partanen H, 2009. Transplacental transfer of nitrosodimethylamine in perfused human placenta. Placenta 30(3):277–283. 10.1016/j.placenta.2008.12.012.19215982
Arai M, Aoki Y, Nakanishi K, 1979. Long-term experiment of maximal non-carcinogenic dose of dimethylnitrosamine for carcinogenesis in rats. Gann 70(4):549–558.510853
Araki A, Muramatsu M, Matsushima T. 1984. Comparison of mutagenicities of N-nitrosamines on Salmonella typhimurium TA100 and Escherichia coli WP2 uvrA/pKM101 using rat and hamster liver S9. Gann 75(1):8–16.6373472
Asakura S, Sawada S, Daimon H, 1994. Effects of dietary restriction on induction of unscheduled DNA synthesis (UDS) and replicative DNA synthesis (RDS) in rat liver. Mutat Res 322(4):257–264. 10.1016/0165-1218(94)90101-5.7523919
Asakura S, Daimon H, Sawada S, 1998. A short-term assessment of tumor-promotion activity in the livers of rats treated with two genotoxic methylating agents: Dimethylnitrosamine and methylnitrosourea. Toxicol Lett 98(3):155–167. 10.1016/s0378-4274(98)00112-x.9788584
Ashby J, Short JM, Jones NJ, 1994. Mutagenicity of o-anisidine to the bladder of lacI-transgenic B6C3F1 mice: Absence of 14C or 32P bladder DNA adduction. Carcinogenesis 15(10):2291–2296.7955069
Atkinson R, Carter WP L. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84(5):437–470. 10.1021/cr00063a002.
Atkinson AJ, Fischer N, Donovan S, 2020. Purification and removal of the low molecular weight fraction of polyDADMAC reduces N-nitrosodimethylamine formation during water treatment. Environ Sci 6(9):2492–2498. 10.1039/d0ew00392a.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2019. N-Nitrosodimethylamine. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. April 13, 2020.
Ayanaba A, Alexander M. 1974. Transformation of methylamines and formation of a hazardous product, dimethylnitrosamine, in samples of treated sewage and lake water. J Environ Qual 3(1):83–89. 10.2134/jeq1974.00472425000300010022x.
Bakke JP, Mirsalis JC. 1984. Measurement of unscheduled DNA synthesis (UDS) in fetal and maternal liver following in vivo exposure to genotoxic agents [abstract]. Environ Mutagen 6:446.
Bamborschke S, O'Connor PJ, Margison GP, 1983. DNA methylation by dimethylnitrosamine in the Mongolian gerbil (Meriones unguiculatus): indications of a deficient, noninducible hepatic repair system for O6-methylguanine. Cancer Res 43(3):1306–1311.6825100
Barbin A, Béréziat JC, Bartsch H. 1983. Evaluation of DNA damage by the alkaline elution technique in liver, kidneys and lungs of rats and hamsters treated with N-nitrosodialkyl-amines. Carcinogenesis 4(5):541–545. 10.1093/carcin/4.5.541.6850984
Barnes JM, Magee PN. 1954. Some toxic properties of dimethylnitrosamine. Br J Ind Med 11(3):167–174. 10.1136/oem.11.3.167.13182155
Barnes DG, Dourson M. 1988. Reference dose (RfD): description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Bartsch H, Malaveille C, Camus AM, 1980. Validation and comparative studies on 180 chemicals with S. typhimurium strains and V79 Chinese hamster cells in the presence of various metabolizing systems. Mutat Res 76(1):1–50. 10.1016/0165-1110(80)90002-0.6993936
Bauknecht T, Vogel W, Bayer U, 1977. Comparative in vivo mutagenicity testing by SCE and micronucleus induction in mouse bone marrow. Hum Genet 35(3):299–307. 10.1007/bf00446622.139356
Baxter ED, Slaiding IR, Travers V. 2007. Current incidence of N-nitrosodimethylamine in beers worldwide. Food Addit Contam 24(8):807–811. 10.1080/02652030701278354.17613067
Bean CL, Bradt CI, Hill R, 1994. Chromosome aberrations: persistence of alkylation damage and modulation by O6-alkylguanine-DNA alkyltransferase. Mutat Res 307(1):67–81. 10.1016/0027-5107(94)90279-8.7513826
Beebe LE, Kim YE, Amin S, 1993. Comparison of transplacental and neonatal initiation of mouse lung and liver tumors by N-nitrosodimethylamine (NDMA) and 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone (NNK) and promotability by a polychlorinated biphenyls mixture (Aroclor 1254). Carcinogenesis 14(8):1545–1548. 10.1093/carcin/14.8.1545.8353839
Bellec G, Dreano Y, Lozach P, 1996. Cytochrome P450 metabolic dealkylation of nine N-nitrosodialkylamines by human liver microsomes. Carcinogenesis 17(9):2029–2034. 10.1093/carcin/17.9.2029.8824531
Bermudez E, Mirsalis JC, Eales HC. 1982. Detection of DNA damage in primary cultures of rat hepatocytes following in vivo and in vitro exposure to genotoxic agents. Environ Mutagen 4(6):667–679. 10.1002/em.2860040606.6819133
Bhattacharyya K. 1965. Foetal and neonatal responses to hepatotoxic agents. J Pathol Bacteriol 90(1):151–161.5843936
Bianchini F, Wild CP. 1994. Effect of route of administration of environmental methylating agents on 7-methylguanine formation in white blood cells and internal organs: implications for molecular epidemiology. Cancer Lett 87(2):131–137. 10.1016/0304-3835(94)90213-5.7812931
Blanco JG, Harrison PL, Evans WE, 2000. Human cytochrome P450 maximal activities in pediatric versus adult liver. Drug Metab Dispos 28(4):379–382.10725303
Blazak W, Stewart B, DiBiasio-Erwin D, 1985. Induction of sister chromatid exchanges (SCE) by dimethylnitrosamine (DMN) in Chinese hamster cells co-cultured with primary human hepatocytes (PHH) [abstract]. Environ Mutagen 7:32.
Blount JL, Woodruff RC, Hudson SJ. 1985. Interaction between mobile DNA-element-induced lethal mutations and chemical mutagens in the hybrid dysgenic system of Drosophila melanogaster. Mutat Res 149(1):33–40. 10.1016/0027-5107(85)90006-5.2983200
Boeing H, Schlehofer B, Blettner M, 1993. Dietary carcinogens and the risk for glioma and meningioma in Germany. Int J Cancer 53(4):561–565. 10.1002/ijc.2910530406.8436429
Bolognesi C, Rossi L, Santi L. 1988. A new method to reveal the genotoxic effects of N-nitrosodimethylamine in pregnant mice. Mutat Res 207(2):57–62. 10.1016/0165-7992(88)90042-5.3340094
Boniol M, Koechlin A, Boyle P. 2017. Meta-analysis of occupational exposures in the rubber manufacturing industry and risk of cancer. Int J Epidemiol 46(6):1940–1947. 10.1093/ije/dyx146.29025048
Bontoyan WR, Law MW, Wright DP. 1979. Nitrosamines in agricultural and home-use pesticides. J Agric Food Chem 27(3):631–635. 10.1021/jf60223a009.447935
Boothe DM, Jenkins WL, Green RA, 1992. Dimethylnitrosamine-induced hepatotoxicosis in dogs as a model of progressive canine hepatic disease. Am J Vet Res 53(3):411–420.1595969
Boothe DM, Cullen JM, Calvin JA, 1994. Antipyrine and caffeine dispositions in clinically normal dogs and dogs with progressive liver disease. Am J Vet Res 55(2):254–261.8172417
Borlakoglu JT, Scott A, Henderson CJ, 1993. Expression of P450 isoenzymes during rat liver organogenesis. Int J Biochem 25(11):1659–1668. 10.1016/0020-711x(93)90525-j.8288035
Bosan WS, Shank RC, MacEwen JD, 1987. Methylation of DNA guanine during the course of induction of liver cancer in hamsters by hydrazine or dimethylnitrosamine. Carcinogenesis 8(3):439–444. 10.1093/carcin/8.3.439.3815739
Bradley MO, Dysart G, Fitzsimmons K, 1982. Measurements by filter elution of DNA single- and double-strand breaks in rat hepatocytes: effects of nitrosamines and gamma-irradiation. Cancer Res 42(7):2592–2597.7083152
Brain KR, Walters KA, James VJ, 1995. Percutaneous penetration of dimethylnitrosamine through human skin in vitro: application from cosmetic vehicles. Food Chem Toxicol 33(4):315–322. 10.1016/0278-6915(94)00146-f.7737604
Braithwaite I, Ashby J. 1988. A non-invasive micronucleus assay in the rat liver. Mutat Res 203(1):23–32.3340090
Brambilla G, Carlo P, Finollo R. 1992. Effect of ten thiocompounds on rat liver DNA damage induced by a small dose of N-nitrosodimethylamine. Arch Toxicol 66(4):286–290. 10.1007/bf02307175.1514928
Brambilla G, Cavanna M, Pino A, 1981. Quantitative correlation among DNA damaging potency of six N-nitroso compounds and their potency in inducing tumor growth and bacterial mutations. Carcinogenesis 2(5):425–429. 10.1093/carcin/2.5.425.7023730
Brambilla G, Carlo P, Finollo R, 1987. Dose-response curves for liver DNA fragmentation induced in rats by sixteen n-nitroso compounds as measured by viscometric and alkaline elution analyses. Cancer Res 47(13):3485–3491.3581083
Braunstein LZ, Kantor ED, O'Connell K, 2021. Analysis of ranitidine-associated n-nitrosodimethylamine production under simulated physiologic conditions. JAMA Netw Open 4(1):e2034766. 10.1001/jamanetworkopen.2020.34766.33512515
Brendler SY, Tompa A, Hutter KF, 1992. In vivo and in vitro genotoxicity of several N-nitrosamines in extrahepatic tissues of the rat. Carcinogenesis 13(12):2435–2441. 10.1093/carcin/13.12.2435.1473254
Brewer WS, Draper AC, Wey SS. 1980. The detection of dimethylnitrosamine and diethylnitrosamine in municipal sewage sludge applied to agricultural soils. Environ Pollut B Chem Phys 1(1):37–43. 10.1016/0143-148x(80)90019-1.
Bringezu F, Simon S. 2022. Salmonella typhimurium TA100 and TA1535 and E. coli WP2 uvrA are highly sensitive to detect the mutagenicity of short Alkyl-N-Nitrosamines in the Bacterial Reverse Mutation Test. Toxicol Rep 9:250–255. 10.1016/j.toxrep.2022.02.005.35198408
Brodberg RK, Mitchell MJ, Smith SL, 1987. Specific reduction of N,N-dimethylnitrosamine mutagenicity in Drosophila melanogaster by dimethyl sulfoxide. Environ Mol Mutagen 10(4):425–432.3119334
Brunnemann KD, Masaryk J, Hoffmann D. 1983. Role of tobacco stems in the formation of N-nitrosamines in tobacco and cigarette mainstream and sidestream smoke. J Agric Food Chem 31(6):1221–1224. 10.1021/jf00120a020.
Butler-Howe LM, Boothe HW, Boothe DM, 1993. Effects of vena caval banding in experimentally induced multiple portosystemic shunts in dogs. Am J Vet Res 54(10):1774–1783.8250407
Butterworth BE, Templin MV, Constan AA, 1998. Long-term mutagenicity studies with chloroform and dimethylnitrosamine in female lacI transgenic B6C3F1 mice. Environ Mol Mutagen 31(3):248–256. 10.1002(sici)1098-2280(1998)31:3<248::aid-em6>3/.0.co;2-g.9585263
Bysshe SB. 1982. Bioconcentration factor in aquatic organisms. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw Hill Book, Co., 5–6.
Camus AM, Bereziat JC, Shuker DE, 1990. Effects of a high fat diet on liver DNA methylation in rats exposed to N-nitrosodimethylamine. Carcinogenesis 11(12):2093–2095. 10.1093/carcin/11.12.2093.2265464
Camus AM, Geneste O, Honkakoski P, 1993. High variability of nitrosamine metabolism among individuals: role of cytochromes P450 2A6 and 2E1 in the dealkylation of N-nitrosodimethylamine and N-nitrosodiethylamine in mice and humans. Mol Carcinog 7(4):268–275. 10.1002/mc.2940070410.8352885
CARB. 1986. Inhalation uptake of selected chemical vapors at trace levels: Final report to California Air Resources Board. Sacramento, CA: California Air Resources Board. PB86209863. UCD-472-507. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB86209863.xhtml. April 17, 2020.
Cardwell CR, McDowell RD, Hughes CM, 2021. Exposure to ranitidine and risk of bladder cancer: A nested case-control study. Am J Gastroenterol 116(8):1612–1619. 10.14309/ajg.0000000000001310.34028367
Carlton WW, Price PS. 1973. Dietary copper and the induction of neoplasms in the rat by acetylaminofluorene and dimethylnitrosamine. Food Cosmet Toxicol 11(5):827–840. 10.1016/0015-6264(73)90141-7.4768879
Carpenter SP, Savage DD, Schultz ED, 1997. Ethanol-mediated transplacental induction of CYP2E1 in fetal rat liver. J Pharmacol Exp Ther 282(2):1028–1036.9262372
Carter RL, Percival WH, Roe FJ. 1969. Exceptional sensitivity of mink to the hepatotoxic effects of dimethylnitrosamine. J Pathol 97(1):79–88. 10.1002/path.1710970110.5783638
Carver JH, Salazar EP, Knize MG, 1981. Mutation induction at multiple gene loci in Chinese hamster ovary cells: The genetic activity of 15 coded carcinogens and noncarcinogens. Prog Mutat Res 1:594–601.
Castegnaro M, Eisenbrand G, Ellen G, 1982. Laboratory decontamination and destruction of carcinogens in laboratory wastes: some N-nitrosamines. IARC Sci Publ 43:1–73.
Cesarone CF, Bolognesi C, Santi L. 1979. DNA repair synthesis in mice spermatids after treatment with N-methyl-N-nitroso-urea and N-N-dimethyl-nitrosamine: preliminary results. Toxicology 12(2):183–186. 10.1016/0300-483x(79)90045-3.473234
Cesarone CF, Bolognesi C, Santi L. 1982. Evaluation of damage to DNA after in vivo exposure to different classes of chemicals. Archives of Toxicology Suppl 5:355–359. 10.1007/978-3-642-68511-8_66.
Chen B, You L, Wang Y, 1994. Allele-specific activation and expression of the K-ras gene in hybrid mouse lung tumors induced by chemical carcinogens. Carcinogenesis 15(9):2031–2035. 10.1093/carcin/15.9.2031.7923598
Chen B, Lee W, Westerhoff PK, 2010. Solar photolysis kinetics of disinfection byproducts. Water Res 44(11):3401–3409. 10.1016/j.watres.2010.03.014.20417540
Chen Y, Zhou Z, Mo Q, 2018. Gallic acid attenuates dimethylnitrosamine-induced liver fibrosis by alteration of Smad phosphoisoform signaling in rats. Biomed Res Int 2018:1682743. 10.1155/2018/1682743.30627538
Cheung KS, Leung WK. 2019. Long-term use of proton-pump inhibitors and risk of gastric cancer: a review of the current evidence. Therap Adv Gastroenterol 12:1756284819834511. 10.1177/1756284819834511.
Chhabra SK, Souliotis VL, Harbaugh JW, 1995. O6-methylguanine DNA adduct formation and modulation by ethanol in placenta and fetal tissues after exposure of pregnant patas monkeys to N-nitrosodimethylamine. Cancer Res 55(24):6017–6020.8521384
Chhabra SK, Anderson LM, Perella C, 2000. Coexposure to ethanol with N-nitrosodimethylamine or 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone during lactation of rats: marked increase in O(6)-methylguanine-DNA adducts in maternal mammary gland and in suckling lung and kidney. Toxicol Appl Pharmacol 169(2):191–200. 10.1006/taap.2000.9068.11097872
Chin W, Lee VM, Archer MC. 1993. Evidence that the hepatotoxicity of N-nitrosodimethylamine in the rat is unrelated to DNA methylation. Chem Res Toxicol 6(3):372–375. 10.1021/tx00033a019.8318659
Chowdhury S. 2014. N-Nitrosodimethylamine (NDMA) in food and beverages: A comparison in context to drinking water. Hum Ecol Risk Assess 20(5):1291–1312. 10.1080/10807039.2013.817144.
Clapp NK, Toya RE. 1970. Effect of cumulative dose and dose rate on dimethylnitrosamine oncogenesis in RF mice. J Natl Cancer Inst 45(3):495–498.5535566
Clawson GA, Blankenship LJ, Rhame JG, 1992. Nuclear enlargement induced by hepatocarcinogens alters ploidy. Cancer Res 52(5):1304–1308.1737393
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cliet I, Melcion C, Cordier A. 1993. Lack of predictivity of bone marrow micronucleus test versus testis micronucleus test: comparison with four carcinogens. Mutat Res 292(2):105–111. 10.1016/0165-1161(93)90137-o.7692246
Cliet I, Fournier E, Melcion C, 1989. In vivo micronucleus test using mouse hepatocytes. Mutat Res 216(6):321–326. 10.1016/0165-1161(89)90042-3.2601732
Clive D, Johnson KO, Spector JF, 1979. Validation and characterization of the L5178Y/TK+/− mouse lymphoma mutagen assay system. Mutat Res 59(1):61–108. 10.1016/0027-5107(79)90195-7.372791
Coccia P, Salmona M, Diomede L, 1988. Liver DNA alkylation after a single carcinogenic dose of dimethylnitrosamine to newborn and adult CFW Swiss mice. Chem Biol Interact 68(3–4):259–271.3214887
Cohen SZ, Zweig G. 1978. Analytical determination of N-nitroso compounds in pesticides by the United States Environmental Protection Agency--a preliminary study. IARC Sci Publ 19:333–342.
Cohen Sedgh R, Moon J, Jackevicius CA. 2021. Neoplasm reports in Food and Drug Administration adverse event reporting system following angiotensin receptor blocker recalls. Circ Cardiovasc Qual Outcomes 14(8):e007476. 10.1161/CIRCOUTCOMES.120.007476.34380327
Cooper SW, Kimbrough RD. 1980. Acute dimethylnitrosamine poisoning outbreak. J Forensic Sci 25(4):874–882.7430995
Crampton RF. 1980. Carcinogenic dose-related response to nitrosamines. Oncology 37(4):251–254. 10.1159/000225446.7443156
Crofton-Sleigh C, Doherty A, Ellard S, 1993. Micronucleus assays using cytochalasin-blocked MCL-5 cells, a proprietary human cell line expressing five human cytochromes P-450 and microsomal epoxide hydrolase. Mutagenesis 8(4):363–372.8377657
Cunningham ML, Hayward JJ, Shane BS, 1996. Distinction of mutagenic carcinogens from a mutagenic noncarcinogen in the Big Blue transgenic mouse. Environ Health Perspect 104(3):683–686.8781405
Dahlhaus M, Appel KE. 1993. N-Nitrosodimethylamine, N-nitrosodiethylamine, and N-nitrosomorpholine fail to generate 8-hydroxy-2'-deoxyguanosine in liver DNA of male F344 rats. Mutat Res 285(2):295–302. 10.1016/0027-5107(93)90118-y.7678903
Dai N, Mitch WA. 2013. Relative importance of N-nitrosodimethylamine compared to total N-nitrosamines in drinking waters. Environ Sci Technol 47(8):3648–3656. 10.1021/es305225b.23505971
Dai WD, Lee V, Chin W, 1991. DNA methylation in specific cells of rat liver by N-nitrosodimethylamine and N-nitrosomethylbenzylamine. Carcinogenesis 12(7):1325–1329. 10.1093/carcin/12.7.1325.2070499
Dangtakot R, Intuyod K, Chamgramol Y, 2021. CagA(+) Helicobacter pylori infection and N-nitrosodimethylamine administration induce cholangiocarcinoma development in hamsters. Helicobacter 26(4):e12817. 10.1111/hel.12817.34031944
Dass SB, Hammons GJ, Bucci TJ, 1998. Susceptibility of C57BL/6 mice to tumorigenicity induced by dimethylnitrosamine and 2-amino-1-methyl-6-phenylimidazo [4,5-b]pyridine in the neonatal bioassay. Cancer Lett 124(1):105–110. 10.1016/s0304-3835(97)00462-x.9500198
Daugherty JP, Clapp NK. 1976. Studies on nitrosamine metabolism. I. Subcellular distribution of radioactivity in tumor-susceptible tissues of RFM mice following administration of [14C]dimethylnitrosamine. Life Sci 19(2):265–271. 10.1016/0024-3205(76)90399-4.957870
Davies B, Morris T. 1993. Physiological parameters in laboratory animals and humans. Pharm Res 10(7):1093–1095. 10.1023/a:1018943613122.8378254
Davies R, Clothier B, Smith AG. 2000. Mutation frequency in the lacI gene of liver DNA from lambda/lacI transgenic mice following the interaction of PCBs with iron causing hepatic cancer and porphyria. Mutagenesis 15(5):379–383. 10.1093/mutage/15.5.379.10970442
Davies RL, Crespi CL, Rudo K, 1989. Development of a human cell line by selection and drug-metabolizing gene transfection with increased capacity to activate promutagens. Carcinogenesis 10(5):885–891. 10.1093/carcin/10.5.885.2706743
De Flora S, Zanacchi P, Camoirano A, 1984. Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test. Mutat Res 133(3):161–198. 10.1016/0165-1110(84)90016-2.6374443
De Stefani E, Deneo-Pellegrini H, Carzoglio JC, 1996. Dietary nitrosodimethylamine and the risk of lung cancer: a case-control study from Uruguay. Cancer Epidemiol Biomarkers Prev 5(9):679–682.8877057
De Stefani E, Boffetta P, Mendilaharsu M, 1998. Dietary nitrosamines, heterocyclic amines, and risk of gastric cancer: a case-control study in Uruguay. Nutr Cancer 30(2):158–162. 10.1080/01635589809514656.9589435
de Vocht F, Burstyn I, Straif K, 2007. Occupational exposure to NDMA and NMor in the European rubber industry. J Environ Monit 9(3):253–259. 10.1039/b615472g.17344951
Dean-Raymond D, Alexander M. 1976. Plant uptake and leaching of dimethylnitrosamine. Nature 262(5567):394–396. 10.1038/262394a0.
Delker DA, Geter DR, Kleinert KM, 2008. Frequency and spectrum of lacI mutations in the liver of Big Blue mice following the administration of genotoxic carcinogens singly and in series. Int J Toxicol 27(1):35–42. 10.1080/10915810701876620.18293211
Den Engelse L, Hollander CF, Misdorp W. 1974. A sex-dependent difference in the type of tumours induced by dimethylnitrosamine in the livers of C3Hf mice. Eur J Cancer 10(2):129–135. 10.1016/0014-2964(74)90064-4.
Desjardins R, Fournier M, Denizeau F, 1992. Immunosuppression by chronic exposure to N-nitrosodimethylamine (NDMA) in mice. J Toxicol Environ Health 37(3):351–361. 10.1080/15287399209531676.1433375
Devereux TR, Anderson MW, Belinsky SA. 1991. Role of ras protooncogene activation in the formation of spontaneous and nitrosamine-induced lung tumors in the resistant C3H mouse. Carcinogenesis 12(2):299–303. 10.1093/carcin/12.2.299.1995195
Diaz Gomez MI, Tamayo D, Castro JA. 1986. Administration of N-nitrosodimethylamine, N-nitrosopyrrolidine, or N'-nitrosonornicotine to nursing rats: their interactions with liver and kidney nucleic acids from sucklings. J Natl Cancer Inst 76(6):1133–1136.2423736
Dickins M, Wright K, Phillips M, 1985. Toxicity and mutagenicity of 6 anti-cancer drugs in Chinese hamster V79 cells co-cultured with rat hepatocytes. Mutat Res 157(2–3):189–197. 10.1016/0165-1218(85)90115-6.4040606
Dobo KL, Eastmond DA, Grosovsky AJ. 1997. The influence of cellular apoptotic capacity on N-nitrosodimethylamine-induced loss of heterozygosity mutations in human cells. Carcinogenesis 18(9):1701–1707. 10.1093/carcin/18.9.1701.9328164
Dobo KL, Eastmond DA, Grosovsky AJ. 1998. Sequence specific mutations induced by N-nitrosodimethylamine at two marker loci in metabolically competent human lymphoblastoid cells. Carcinogenesis 19(5):755–764. 10.1093/carcin/19.5.755.9635860
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Doolittle DJ, Muller G, Scribner HE. 1987. A comparative study of hepatic DNA repair, DNA replication and hepatotoxicity in the CD-1 mouse following multiple administrations of dimethylnitrosamine. Mutat Res 188(2):141–147. 10.1016/0165-1218(87)90103-0.3587262
Doolittle DJ, Bermudez E, Working PK, 1984. Measurement of genotoxic activity in multiple tissues following inhalation exposure to dimethylnitrosamine. Mutat Res 141(2):123–127. 10.1016/0165-7992(84)90023-x.6493268
Druckrey H, Preussmann R, Ivankovic S, 1967. [Organotropic carcinogenic effects of 65 various N-nitroso-compounds on BD rats]. Z Krebsforsch 69(2):103–201. (German)4230610
Du J, Shi X, Wang Y, 2022. Effects of chlorination on the nitrosamines formation from two algae species in drinking water source-M. aeruginosa and C. meneghiniana. Chemosphere 287(Pt 1):132093. 10.1016/j.chemosphere.2021.132093.34526274
Ducos P, Gaudin R, Maire C, 1988. Occupational exposure to volatile nitrosamines in foundries using the "Ashland" core-making process. Environ Res 47(1):72–78.3168966
Eckl PM, Strom SC, Michalopoulos G, 1987. Induction of sister chromatid exchanges in cultured adult rat hepatocytes by directly and indirectly acting mutagens/carcinogens. Carcinogenesis 8(8):1077–1083. 10.1093/carcin/8.8.1077.3111742
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
Elshazly SM, Mahmoud AA. 2014. Antifibrotic activity of hesperidin against dimethylnitrosamine-induced liver fibrosis in rats. Naunyn Schmiedebergs Arch Pharmacol 387(6):559–567. 10.1007/s00210-014-0968-2.24627177
Emery M, Fisher JM, Chien JY, 2003. CYP2E1 activity before and after weight loss in morbidly obese subjects with nonalcoholic fatty liver disease. Hepatology 38(2):428–435. 10.1053/jhep.2003.50342.12883487
EPA. 1978. Survey for airborne nitrosamines. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600179040. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000AS1M.txt. April 16, 2020.
EPA. 1979. Water-related environmental fate of 129 priority pollutants. Volume II. Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate esters, polycyclic aromatic hydrocarbons, nitrosamines, and miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000K6JL.txt. April 17, 2020.
EPA. 1985. Sampling of automobile interiors for organic emissions report. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600385008. PB85172567. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=940054Z7.txt. April 17, 2020.
EPA. 1996. Method 8070A: Nitrosamines by gas chromatography. U.S. Environmental Protection Agency. SW846. https://www.epa.gov/sites/production/files/2015-12/documents/8070a.pdf. April 15, 2020.
EPA. 2004. Method 521: Determination of nitrosamines in drinking water by solid phase extraction and capillary column gas chromatography with large volume injection and chemical ionization tandem mass spectrometry (MS/MS). Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R05054. https://cfpub.epa.gov/si/si_public_record_report.cfm?Lab=NERL&dirEntryId=103912. April 15, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2007. Provisional peer-reviewed toxicity values for N-nitrosodimethylamine (CASRN 62–75-9). Washington, DC: U.S. Environmental Protection Agency. EPA690R07024F. https://cfpub.epa.gov/ncea/pprtv/documents/NitrosodimethylamineN.pdf. April 10, 2020.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2014a. Technical fact sheet: N-nitroso-dimethylamine (NDMA). U.S. Environmental Protection Agency. EPA505F14005. https://www.epa.gov/sites/production/files/2014-03/documents/ffrrofactsheet_contaminant_ndma_january2014_final.pdf. April 13, 2020.
EPA. 2014b. 2014 National Emissions Inventory (NEI) Data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2014-national-emissions-inventory-nei-data. July 22, 2022.
EPA. 2016. Six-year review 3 technical support document for nitrosamines. U.S. Environmental Protection Agency. EPA810R16009A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100QN5C.txt. June 9, 2020.
EPA. 2017. 2017 National Emissions Inventory (NEI) Data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. July 22, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
Epstein SS, Arnold E, Andrea J, 1972. Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23(2):288–325. 10.1016/0041-008x(72)90192-5.5074577
Erkekoglu P, Baydar T. 2010. Evaluation of the protective effect of ascorbic acid on nitrite- and nitrosamine-induced cytotoxicity and genotoxicity in human hepatoma line. Toxicol Mech Methods 20(2):45–52. 10.3109/15376510903583711.20100056
Fadlallah S, Lachapelle M, Krzystyniak K, 1994. O6-methylguanine-DNA adducts in rat lymphocytes after in vivo exposure to N-nitrosodimethylamine (NDMA). Int J Immunopharmacol 16(7):583–591. 10.1016/0192-0561(94)90109-0.7928006
Fan CC, Lin TF. 2018. N-nitrosamines in drinking water and beer: Detection and risk assessment. Chemosphere 200:48–56. 10.1016/j.chemosphere.2018.02.025.29475028
Fan CY, Butler WH, O'Connor PJ. 1989. Cell and tissue specific localization of O6-methylguanine in the DNA of rats given N-nitrosodimethylamine: effects of protein deficient and normal diets. Carcinogenesis 10(10):1967–1970. 10.1093/carcin/10.10.1967.2507193
Farren NJ, Ramírez N, Lee JD, 2015. Estimated exposure risks from carcinogenic nitrosamines in urban airborne particulate matter. Environ Sci Technol 49(16):9648–9656. 10.1021/acs.est.5b01620.26207531
FDA. 2005a. CPG Sec 500.450: Volatile n-nitrosamines in rubber baby bottle nipples. U.S. Food and Drug Administration. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/cpg-sec-500450-volatile-n-nitrosamines-rubber-baby-bottle-nipples. May 9, 2020.
FDA. 2005b. CPG Sec 510.600: Dimethylnitrosamine in malt beverages. U.S. Food and Drug Administration. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/cpg-sec-510600-dimethylnitrosamine-malt-beverages. May 9, 2020.
FDA. 2019a. Laboratory analysis of valsartan products. U.S. Food and Drug Administration. https://www.fda.gov/drugs/drug-safety-and-availability/laboratory-analysis-valsartan-products. May 9, 2020.
FDA. 2019b. Laboratory analysis of ranitidine and nizatidine products. U.S. Food and Drug Administration. https://www.fda.gov/drugs/drug-safety-and-availability/laboratory-tests-ranitidine. May 9, 2020.
FDA. 2020a. Laboratory analysis of metformin products. U.S. Food and Drug Administration. https://www.fda.gov/drugs/drug-safety-and-availability/laboratory-tests-metformin. May 9, 2020.
FDA. 2020b. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
FDA. 2021. Control of nitrosamine impurities in human drugs, revision 1. U.S. Food and Drug Administration. https://www.fda.gov/media/141720/download. August 27, 2022.
Fine DH, Rounbehler DP, Pellizzari ED, 1976. N-Nitrosodimethylamine in air. Bull Environ Contam Toxicol 15(6):739–746. 10.1007/bf01685626.938767
Fine DH, Rounbehler DP, Rounbehler A, 1977a. Determination of dimethylnitrosamine in air, water, and soil by thermal energy analysis: measurements in Baltimore, MD. Environ Sci Technol 11:581–584.
Fine DH, Rounbehler DP, Fan T, 1977b. Human exposure to N-nitroso compounds in the environment. In: Hiatt HH, Watson JD, Winsten JA, eds. Origins of human cancer. Book A. Incidence of cancer in humans. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 293–307.
Fiume L, Campadelli-Fiume G, Magee PN, 1970. Cellular injury and carcinogenesis. Inhibition of metabolism of dimethylnitrosamine by aminoacetonitrile. Biochem J 120:601–605. 10.1042/bj1200601.5499972
Fletcher K, Tinwell H, Ashby J. 1998. Mutagenicity of the human bladder carcinogen 4-aminobiphenyl to the bladder of Muta ™Mouse transgenic mice. Mutat Res Fundam Mol Mech Mutagen 400(1`-2):245–250. 10.1016/s0027-5107(98)00070-0.
Florian J, Matta MK, DePalma R, 2021. Effect of oral ranitidine on urinary excretion of n-nitrosodimethylamine (NDMA): A randomized clinical trial. JAMA 326(3):240–249. 10.1001/jama.2021.9199.34180947
Frank CW, Berry CM. 1981. N-Nitrosamines. In: Clayton GD, Clayton FE, eds. Patty's industrial hygiene and toxicology. 3rd ed. New York, NY: John Wiley & Sons, 3117–3133.
Frank N, Tsuda M, Ohgaki H, 1990. Detoxifying potential of thioproline against N-nitroso compounds, N-nitrosodimethylamine and N-nitrosocimetidine. Cancer Lett 50(3):167–172. 10.1016/0304-3835(90)90260-5.2322930
Freund HA. 1937. Clinical manifestations and studies in parenchymatous hepatitis. Ann Intern Med 10(8):1144–1155. 10.7326/0003-4819-10-8-1144.
Frezza D, Smith B, Zeiger E. 1983. The intrasanguineous host mediated assay procedure using Saccharomyces cerevisiae: comparison with two other metabolic activation systems. Mutat Res 108(1–3):161–168. 10.1016/0027-5107(83)90117-3.6339885
Friedman MA, Staub J. 1976. Inhibition of mouse testicular DNA synthesis by mutagens and carcinogens as a potential sample mammalian assay for mutagenesis. Mutat Res 37(1):67–76. 10.1016/0027-5107(76)90055-5.967187
Fritzenschaf H, Kohlpoth M, Rusche B, 1993. Testing of known carcinogens and noncarcinogens in the Syrian hamster embryo (SHE) micronucleus test in vitro; correlations with in vivo micronucleus formation and cell transformation. Mutat Res 319(1):47–53. 10.1016/0165-1218(93)90029-d.7690458
Fritzsche M, Blom G, Keitel J, 2022. NDMA analytics in metformin products: Comparison of methods and pitfalls. Eur J Pharm Sci 168:106026. 10.1016/j.ejps.2021.106026.34597792
Fujioka T, Masaki S, Kodamatani H, 2017. Degradation of n-nitrosodimethylamine by UV-based advanced oxidation processes for potable reuse: A short review. Curr Pollut Rep 3(2):79–87. 10.1007/s40726-017-0052-x.
Fujita K, Kamataki T. 2001. Role of human cytochrome P450 (CYP) in the metabolic activation of N-alkylnitrosamines: application of genetically engineered Salmonella typhimurium YG7108 expressing each form of CYP together with human NADPH-cytochrome P450 reductase. Mutat Res 483(1–2):35–41. 10.1016/s0027-5107(01)00223-8.11600130
Fukushima S, Wanibuchi H, Morimura K, 2005. Lack of potential of low dose N-nitrosodimethylamine to induce preneoplastic lesions, glutathione S-transferase placental form-positive foci, in rat liver. Cancer Lett 222(1):11–15. 10.1016/j.canlet.2004.08.035.15837536
Fussgaenger RD, Ditschuneit H. 1980. Lethal exitus of a patient with N-nitrosodimethylamine poisoning, 2.5 years following the first ingestion and signs of intoxication. Oncology 37(4):273–277. 10.1159/000225451.7443160
Gallo V, Khan A, Gonzales C, 2008. Validation of biomarkers for the study of environmental carcinogens: a review. Biomarkers 13(5):505–534. 10.1080/13547500802054611.18979642
Gan J, Bondarenko S, Ernst F, 2006. Leaching of N-nitrosodimethylamine (NDMA) in turfgrass soils during wastewater irrigation. J Environ Qual 35(1):277–284. 10.2134/jeq2005.0264.16397103
Gao Z, Karfunkle M, Ye W, 2021. In vitro analysis of n-nitrosodimethylamine (NDMA) formation from ranitidine under simulated gastrointestinal conditions. JAMA Netw Open 4(6):e2118253. 10.1001/jamanetworkopen.2021.18253.34181009
Gao M, Jiang Z, Liao X, 2022. NDMA formation during ozonation of DMAPA: Influencing factors, mechanisms, and new pathway exploration. Sci Total Environ 825:153881. 10.1016/j.scitotenv.2022.153881.35182642
Garland WA, Norkus EP, Kuenzig WA, 1988. The effect of N-acetylcysteine on the toxicity induced by N-nitrosodimethylamine. Drug Metab Dispos 16(1):162–165.2894948
Genualdi S, Matos MP V, Mangrum JB, 2020. Investigation into the concentrations and sources of nitrates and nitrites in milk and plant-based powders. J Agric Food Chem 68(6):1725–1730. 10.1021/acs.jafc.9b07460.31967806
George J, Stern R. 2004. Serum hyaluronan and hyaluronidase: very early markers of toxic liver injury. Clin Chim Acta 348(1–2):189–197. 10.1016/j.cccn.2004.05.018.15369754
George J, Tsuchishima M, Tsutsumi M. 2019. Molecular mechanisms in the pathogenesis of N-nitrosodimethylamine induced hepatic fibrosis. Cell Death Dis 10(1):18. 10.1038/s41419-018-1272-8.30622238
George J, Suguna L, Ramachandran J, 2006. Efficacy of silymarin and curcumin on dimethyl nitrosamine induced liver fibrosis in rats. Biomedicine 26(3–4):18–26.
Georgiadis P, Samoli E, Kaila S, 2000. Ubiquitous presence of O6-methylguanine in human peripheral and cord blood DNA. Cancer Epidemiol Biomarkers Prev 9(3):299–305.10750669
Georgiadis P, Kaila S, Makedonopoulou P, 2010. Development and validation of a new, sensitive immunochemical assay for O^6^-methylguanine in DNA and its application in a population study. Cancer Epidemiol Biomarkers Prev 20(1):82–90. 10.1158/1055-9965.epi-10-0788.21081711
Gerson SL, Trey JE, Miller K, 1986. Comparison of O^6^-alkylguanine-DNA alkyltransferase activity based on cellular DNA content in human, rat and mouse tissues. Carcinogenesis 7(5):745–749. 10.1093/carcin/7.5.745.3698202
Giles GG, McNeil JJ, Donnan G, 1994. Dietary factors and the risk of glioma in adults: results of a case-control study in Melbourne, Australia. Int J Cancer 59(3):357–362. 10.1002/ijc.2910590311.7927941
Gkamprela E, Deutsch M, Pectasides D. 2017. Iron deficiency anemia in chronic liver disease: etiopathogenesis, diagnosis and treatment. Ann Gastroenterol 30:405–413. 10.20524/aog.2017.0152.28655976
Gollapudi BB, Jackson KM, Stott WT. 1998. Hepatic lacI and cII mutation in transgenic (lambdaLIZ) rats treated with dimethylnitrosamine. Mutat Res 419(1–3):131–135. 10.1016/s1383-5718(98)00132-6.9804924
Golob N, Grahek R, Ross M, 2022. Nitrocellulose blister material as a source of N-nitrosamine contamination of pharmaceutical drug products. Int J Pharm 618:121687. 10.1016/j.ijpharm.2022.121687.35314277
Gombar CT, Pylypiw HM, Harrington GW. 1987. Pharmacokinetics of N-nitrosodimethylamine in beagles. Cancer Res 47(2):343–347.3791224
Gombar CT, Harrington GW, Pylypiw HM, 1988. Pharmacokinetics of N-nitrosodimethylamine in swine. Carcinogenesis 9(8):1351–1354. 10.1093/carcin/9.8.1351.3402031
Gombar CT, Harrington GW, Pylypiw HM, 1990. Interspecies scaling of the pharmacokinetics of N-nitrosodimethylamine. Cancer Res 50(14):4366–4370.2364390
Gomez MID, Swann PF, Magee PN. 1977. The absorption and metabolism in rats of small oral doses of dimethylnitrosamine. Implication for the possible hazard of dimethylnitrosamine in human food. Biochem J 164(3):497–500. 10.1042/bj1640497.883948
Gomm W, Röthlein C, Schüssel K, 2021. N-nitrosodimethylamine-contaminated valsartan and the risk of cancer - a longitudinal cohort study based on German health insurance data. Dtsch Arztebl Int 118(21):357–362. 10.3238/arztebl.m2021.0129.34247699
Goto Y, Matsuda T, Ito K, 1999. Mutagenicities of N-nitrosodimethylamine and N-nitrosodiethylamine in Drosophila and their relationship to the levels of O-alkyl adducts in DNA. Mutat Res 425(1):125–134. 10.1016/s0027-5107(99)00032-9.10082923
Greene S, Alexander M, Leggett D. 1981. Formation of N-nitrosodimethylamine during treatment of municipal waste water by simulated land application. J Environ Qual 10(3):416–421. 10.2134/jeq1981.00472425001000030035x.
Griciute L, Castegnaro M, Bereziat JC. 1981. Influence of ethyl alcohol on carcinogenesis with N-nitrosodimethylamine. Cancer Lett 13(4):345–352. 10.1016/0304-3835(81)90063-x.7306961
Gushgari AJ, Halden RU. 2018. Critical review of major sources of human exposure to N-nitrosamines. Chemosphere 210:1124–1136. 10.1016/j.chemosphere.2018.07.098.30208538
Gushgari AJ, Halden RU, Venkatesan AK. 2017. Occurrence of N-nitrosamines in U.S. freshwater sediments near wastewater treatment plants. J Hazard Mater 323(Pt A):109-115. 10.1016/j.jhazmat.2016.03.091.
Haggerty HG, Holsapple MP. 1990. Role of metabolism in dimethylnitrosamine-induced immunosuppression: a review. Toxicology 63(1):1–23. 10.1016/0300-483x(90)90064-n.2200161
Hamada S, Ohyama W, Takashima R, 2015. Evaluation of the repeated-dose liver and gastrointestinal tract micronucleus assays with 22 chemicals using young adult rats: summary of the collaborative study by the Collaborative Study Group for the Micronucleus Test (CSGMT)/The Japanese Environmental Mutagen Society (JEMS) - Mammalian Mutagenicity Study Group (MMS). Mutat Res Genet Toxicol Environ Mutagen 780–781:2–17. 10.1016/j.mrgentox.2015.01.001.
Hamada S, Shigano M, Wako Y, 2022. Detection of hepatocarcinogens by combination of liver micronucleus assay and histopathological examination in 2-week or 4-week repeated dose studies. Genes Environ 44(1):2. 10.1186/s41021-021-00222-1.34983681
Hamilton A, Hardy HL. 1974. Dimethyl-nitrosamine. In: Industrial toxicology. 3rd ed. Acton, MA: Publishing Science Group, Inc., 311.
Hanigan D, Zhang J, Herckes P, 2012. Adsorption of N-nitrosodimethylamine precursors by powdered and granular activated carbon. Environ Sci Technol 46(22):12630–12639. 10.1021/es302922w.23106335
Hanigan D, Thurman EM, Ferrer I, 2015. Methadone contributes to N-nitrosodimethylamine formation in surface waters and wastewaters during chloramination. Environ Sci Tech Lett 2(6):151–157. 10.1021/acs.estlett.5b00096.
Hansch C, Leo A, Hoekman D. 1995. N-Nitrosodimethylamine. In: Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 10.
Hanst PL, Spence JW, Miller M. 1977. Atmospheric chemistry of N-nitroso dimethylamine. Environ Sci Technol 11(4):403–405. 10.1021/es60127a007.
Harrington GW, Magee PN, Pylypiw HM, 1987. The pig as an animal model for the study of nitrosamine metabolism. IARC Sci Publ 84:132–134.
Harrington GW, Magee PN, Pylypiw HM, 1990. The formation, disposition, and hepatic metabolism of dimethylnitrosamine in the pig. Drug Metab Dispos 18(5):626–631.1981711
Haruta S, Gan J, Chang AC, 2011. Evaluating Henry's law constant of N-nitrosodimethylamine (NDMA). Water Sci Technol 64(8):1636–1641. 10.2166/wst.2011.742.22335106
Hashimoto N, Ishikawa Y, Utsunomiya J. 1989. Effects of portacaval shunt, transposition, and dimethylnitrosamine-induced chronic liver injury on pancreatic hormones and amino acids in dog. J Surg Res 46(1):35–40. 10.1016/0022-4804(89)90179-0.2644488
Hawley GG. 1981. N-Nitrosodimethylamine. In: The condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold Company, Inc., 737.
Hayward JJ, Shane BS, Tindall KR, 1995. Differential in vivo mutagenicity of the carcinogen/noncarcinogen pair 2,4- and 2,6-diaminotoluene. Carcinogenesis 16(10):2429–2433. 10.1093/carcin/16.10.2429.7586147
He Y, Ding H, Xia X, 2021. GFP-fused yeast cells as whole-cell biosensors for genotoxicity evaluation of nitrosamines. Appl Microbiol Biotechnol 105(13):5607–5616. 10.1007/s00253-021-11426-4.34228183
Heading CE, Phillips JC, Lake BG, 1974. Some aspects of the metabolism of dimethylnitrosamine in the rat. Biochem Soc Trans 2(4):607–610. 10.1042/bst0020607.
Heath DF. 1962. The decomposition and toxicity of dialkynitrosamines in rats. Biochem J 85:72. 10.1042/bj0850072.16748970
Hemminki K. 1982. Dimethylnitrosamine adducts excreted in rat urine. Chem Biol Interact 39(2):139–148. 10.1016/0009-2797(82)90117-x.7060225
Herron DC, Shank RC. 1980. Methylated purines in human liver DNA after probable dimethylnitrosamine poisoning. Cancer Res 40(9):3116–3117.7427930
Hidajat M, McElvenny DM, Ritchie P, 2019a. Lifetime exposure to rubber dusts, fumes and N-nitrosamines and cancer mortality in a cohort of British rubber workers with 49 years follow-up. Occup Environ Med 76(4):250–258. 10.1136/oemed-2018-105181.30772818
Hidajat M, McElvenny DM, Mueller W, 2019b. Job-exposure matrix for historical exposures to rubber dust, rubber fumes and n-Nitrosamines in the British rubber industry. Occup Environ Med 76(4):259–267. 10.1136/oemed-2018-105182.30772817
Hidajat M, McElvenny DM, Ritchie P, 2020. Lifetime cumulative exposure to rubber dust, fumes and N-nitrosamines and non-cancer mortality: a 49-year follow-up of UK rubber factory workers. Occup Environ Med 77(5):316–323. 10.1136/oemed-2019-106269.31974293
Hindle RW, Armstrong JF, Peake AA. 1987. Determination of N-nitrosodimethylamine levels in some Canadian 2,4-D amine formulations. J Assoc Off Anal Chem 70(1):49–51.3558275
Hino K, Karaki Y, Hatanaka T, 2000. Salivary excretion of N-nitrosodimethylamine in dogs. Eur J Cancer Prev 9(4):275–281. 10.1097/00008469-200008000-00008.10958331
Hinuma K, Matsuda J, Tanida N, 1990. N-Nitrosamines in the stomach with special reference to in vitro formation, and kinetics after intragastric or intravenous administration in rats. Gastroenterol Jpn 25(4):417–424. 10.1007/bf02779329.2210216
Hobbie KR, DeAngelo AB, George MH, 2012. Neoplastic and nonneoplastic liver lesions induced by dimethylnitrosamine in Japanese medaka fish. Vet Pathol 49(2):372–385. 10.1177/0300985811409443.21724976
Hong SW, Jung KH, Zheng HM, 2010. The protective effect of resveratrol on dimethylnitrosamine-induced liver fibrosis in rats. Arch Pharm Res 33(4):601–609. 10.1007/s12272-010-0415-y.20422370
Hooi JK Y, Lai WY, Ng WK, 2017. Global prevalence of Helicobacter pylori infection: Systematic review and meta-analysis. Gastroenterology 153(2):420–429. 10.1053/j.gastro.2017.04.022.28456631
Horesovsky G, Recio L, Everitt J, 1995. p53 status in spontaneous and dimethylnitrosamine-induced renal cell tumors from rats. Mol Carcinog 12(4):236–240. 10.1002/mc.2940120408.7727045
Hrudey SE, Bull RJ, Cotruvo JA, 2013. Drinking water as a proportion of total human exposure to volatile N-nitrosamines. Risk analysis: an official publication of the Society for Risk Analysis 33(12):2179–2208. 10.1111/risa.12070.23786353
Hsie AW, Machanoff R, Couch DB, 1978. Mutagenicity of dimethylnitrosamine and ethyl methanesulfonate as determined by the host-mediated CHO/HGPRT assay. Mutat Res 51(1):77–84. 10.1016/0027-5107(78)90010-6.209324
Hsieh M, Lai WW, Lin AY. 2020. Sunlight photolysis mitigates the formation of N-nitrosodimethylamine (NDMA) during the chloramination of methadone. Chem Eng J 384:123307. 10.1016/j.cej.2019.123307.
Huang PH, Catalano A. 1994. Changes in secondary structure of DNA of rat embryos following treatment with 1,2-diethylhydrazine and dimethylnitrosamine in vivo. Teratog Carcinog Mutagen 14(2):53–64. 10.1002/tcm.1770140202.8066547
Hutchings JW, Ervens B, Straub D, 2010. N-nitrosodimethylamine occurrence, formation and cycling in clouds and fogs. Environ Sci Technol 44(21):8128–8133. 10.1021/es101698q.20932002
IARC. 1978. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: some N-nitroso compounds. Lyon, France: International Agency for Research on Cancer. Vol. 17, https://publications.iarc.fr/35. June 10, 2020.
IARC. 1982. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: the rubber industry. Lyon, France: International Agency for Research on Cancer. Vol. 28, https://publications.iarc.fr/46. August 24, 2022.
IARC. 1987. Overall evaluations of carcinogenicity: an updating of IARC Monographs volumes 1 to 42. IARC Monogr Eval Carcinog Risks Hum Suppl 7:40–74.
IARC. 2004. Tobacco smoke and involuntary smoking. IARC monographs on the evaluation of carcinogenic risks to humans: Volume 83. Lyon, France: International Agency for Research on Cancer. https://www.ncbi.nlm.nih.gov/books/NBK316407/pdf/Bookshelf_NBK316407.pdf. May 21, 2021.
Ikeuchi T, Sasaki M. 1981. Differential inducibility of chromosome aberrations and sister-chromatid exchanges by indirect mutagens in various mammalian cell lines. Mutat Res 90(2):149–161. 10.1016/0165-1218(81)90078-1.7329436
Inoue K, Shibata T, Abe T. 1983. Induction of sister-chromatid exchanges in human lymphocytes by indirect carcinogens with and without metabolic activation. Mutat Res 117(3–4):301–309. 10.1016/0165-1218(83)90129-5.6304505
Inui N, Nishi Y, Taketomi M, 1979. Transplacental action of sodium nitrite on embryonic cells of Syrian golden hamster. Mutat Res 66(2):149–158. 10.1016/0165-1218(79)90060-0.556172
Ireton HJ, McGiven AR, Davies DJ. 1972. Renal mesenchymal tumours induced in rats by dimethylnitrosamine: light- and electron-microscope studies. J Pathol 108(3):181–185. 10.1002/path.1711080302.4119086
IRIS. 1987. N-Nitrosodimethylamine; CASRN 62–75-9. Chemical assessment summary. Integrated Risk Information. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0045_summary.pdf. April 15, 2020.
Ishidate M, Yoshikawa K. 1980. Chromosome aberration tests with Chinese hamster cells in vitro with and without metabolic activation--a comparative study on mutagens and carcinogens. Arch Toxicol Suppl 4:41–44. 10.1007/978-3-642-67729-8_8.
Ishiwata H, Mizushiro H, Tanimura A, 1978. Metabolic fate of the precursors of N-nitroso compounds. II. Salivary secretion and urinary excretion of nitrosatable compounds in man. Shokuhin Eiseigaku Zasshi 19(1):91–97. 10.3358/shokueishi.19.91.
Ito N, Fukushima S, Tsuda H, 1982. Induction of preneoplastic and neoplastic lesions in rats treated N-nitroso compounds. IARC Sci Publ 41:597–601.
Iversen OH. 1980. Tumorigenicity of N-nitroso-diethyl, -dimethyl and -diphenyl-amines in skin painting experiments. A study utilizing the tetrazolium test and skin applications on hairless mice. Eur J Cancer 16(5):695–698. 10.1016/0014-2964(80)90211-x.
Iwagami M, Kumazawa R, Miyamoto Y, 2021. Risk of cancer in association with ranitidine and nizatidine vs other H2 blockers: analysis of the Japan Medical Data Center claims database 2005–2018. Drug Saf 44(3):361–371. 10.1007/s40264-020-01024-0.33247391
Iwakuma T, Sakumi K, Nakatsuru Y, 1997. High incidence of nitrosamine-induced tumorigenesis in mice lacking DNA repair methyltransferase. Carcinogenesis 18(8):1631–1635. 10.1093/carcin/18.8.1631.9276640
Jacobson KH, Wheelwright HJ, Clem JH, 1955. Studies on the toxicology of N-nitrosodimethylamine vapor. AMA Arch Ind Health 12(6):617–622.13268079
Jagannath DR, Vultaggio DM, Brusick DJ. 1981. Genetic activity of 42 coded compounds in the mitotic gene conversion assay using Saccharomyces cerevisiae strain D4. Prog Mutat Res 1:456–467.
Jakszyn P, Bingham S, Pera G, 2006. Endogenous versus exogenous exposure to N-nitroso compounds and gastric cancer risk in the European Prospective Investigation into Cancer and Nutrition (EPIC-EURGAST) study. Carcinogenesis 27(7):1497–1501. 10.1093/carcin/bgl019.16571648
Jakszyn P, Gonzalez CA, Lujan-Barroso L, 2011. Red meat, dietary nitrosamines, and heme iron and risk of bladder cancer in the European Prospective Investigation into Cancer and Nutrition (EPIC). Cancer Epidemiol Biomarkers Prev 20(3):555–559. 10.1158/1055-9965.EPI-10-0971.21239687
Jang JJ, Cho KJ, Myong NH, 1990. Enhancement of dimethylnitrosamine-induced glutathione S-transferase P-positive hepatic foci by Clonorchis sinensis infestation in F344 rats. Cancer Lett 52(2):133–138. 10.1016/0304-3835(90)90255-v.2199025
Jannetti RA, Anderson LM. 1981. Dimethylnitrosamine demethylase activity in fetal, suckling, and maternal mouse liver and its transplacental and transmammary induction by polychlorinated biphenyls. J Natl Cancer Inst 67(2):461–466.6790803
Jenkins SA, Grandison A, Baxter JN, 1985. A dimethylnitrosamine-induced model of cirrhosis and portal hypertension in the rat. J Hepatol 1(5):489–499. 10.1016/s0168-8278(85)80747-9.4056351
Jiao J, Glickman BW, Anderson MW, 1993. Mutational specificity of N-nitrosodimethylamine: Comparison between in vivo and in vitro assay. Mutat Res 301(1):27–31.7677940
Jiao J, Douglas GR, Gingerich JD, 1997. Analysis of tissue-specific lacZ mutations induced by N-nitrosodibenzylamine in transgenic mice. Carcinogenesis 18(11):2239–2245. 10.1093/carcin/18.11.2239.9395227
Johansson EB, Tjalve H. 1978. The distribution of [14C]dimethylnitrosamine in mice. Autoradiographic studies in mice with inhibited and noninhibited dimethylnitrosamine metabolism and a comparison with the distribution of [14C]formaldehyde. Toxicol Appl Pharmacol 45(2):565–575. 10.1016/0041-008x(78)90118-7.568326
Johnson KW, Munson AE, Holsapple MP. 1987. Primary cellular target responsible for dimethylnitrosamine-induced immunosuppression in the mouse. Immunopharmacology 13(1):47–60. 10.1016/0162-3109(87)90026-9.2952621
Johnson TE, Umbenhauer DR, Galloway SM. 1996. Human liver S-9 metabolic activation: proficiency in cytogenetic assays and comparison with phenobarbital/beta-naphthoflavone or aroclor 1254 induced rat S-9. Environ Mol Mutagen 28(1):51–59. 10.1002(SICI)1098-2280(1996)28:1<51::AID-EM8>3/.0.CO;2-H.8698047
Jönsson LS, Lindh CH, Bergendorf U, 2009. N-nitrosamines in the southern Swedish rubber industries - exposure, health effects, and immunologic markers. Scand J Work Environ Health 35(3):203–211. 10.5271/sjweh.1323.19404559
Kanan S. 2010. Occurrence and formation of disinfection by-products in indoor U.S. swimming pools. TigerPrints. Clemson University. All Dissertations 532. https://tigerprints.clemson.edu/all_dissertations/532. May 26, 2020.
Kaplan DL, Kaplan AM. 1985. Biodegradation of N-nitrosodimethylamine in aqueous and soil systems. Appl Environ Microbiol 50(4):1077–1086.16346905
Katic J, Cemeli E, Baumgartner A, 2010. Evaluation of the genotoxicity of 10 selected dietary/environmental compounds with the in vitro micronucleus cytokinesis-block assay in an interlaboratory comparison. Food Chem Toxicol 48(10):2612–2623. 10.1016/j.fct.2010.06.030.20600534
Katoh Y, Tanaka M, Takayama S. 1982. Higher efficiency of hamster hepatocytes than rat hepatocytes for detecting dimethylnitrosamine and diethylnitrosamine in hepatocyte-mediated Chinese hamster V79 cell mutagenesis assay. Mutat Res 105(4):265–269. 10.1016/0165-7992(82)90040-9.7133033
Kay JE, Corrigan JJ, Armijo AL, 2021. Excision of mutagenic replication-blocking lesions suppresses cancer but promotes cytotoxicity and lethality in nitrosamine-exposed mice. Cell Rep 34(11):108864. 10.1016/j.celrep.2021.108864.33730582
Keefer LK, Lijinsky W, Garcia H. 1973. Deuterium isotope effect on the carcinogenicity of dimethylnitrosamine in rat liver. J Natl Cancer Inst 51(1):299–302. 10.1093/jnci/51.1.299.4720880
Keefer LK, Anjo T, Wade D, 1987. Concurrent generation of methylamine and nitrite during denitrosation of N-nitrosodimethylamine by rat liver microsomes. Cancer Res 47(2):447–452.3791233
Keire DA, Bream R, Wollein U, 2022. International regulatory collaboration on the analysis of nitrosamines in metformin-containing medicines. AAPS J 24(3):56. 10.1208/s12248-022-00702-4.35449372
Keszei AP, Goldbohm RA, Schouten LJ, 2013. Dietary N-nitroso compounds, endogenous nitrosation, and the risk of esophageal and gastric cancer subtypes in the Netherlands Cohort Study. Am J Clin Nutr 97(1):135–146. 10.3945/ajcn.112.043885.23193003
Khanna SD, Puri D. 1966. The hepatotoxic effects of dimethylnitrosamine in the rat. J Pathol Bacteriol 91(2):605–608. 10.1002/path.1700910238.5918630
Khorol’skii MD, Anan’ina OV, Chaplenko AA, 2019. Comparison of approaches to determining N-nitrosodimethylamine impurity in valsartan drug substance by GC-MS methods. Pharm Chem J 53(8):766–770. 10.1007/s11094-019-02076-y.
Kim BS, Yang KH, Haggerty HG, 1989. Production of DNA single-strand breaks in unstimulated splenocytes by dimethylnitrosamine. Mutat Res 213(2):185–193. 10.1016/0027-5107(89)90150-4.2761556
Kim H, Tcha J, Shim MY, 2019. Dry-heat cooking of meats as a source of airborne N-nitrosodimethylamine (NDMA). Atmosphere 10(2):91. 10.3390/atmos10020091.
Kim S, Lee S, Hong J, 2021a. Effect of ranitidine intake on the risk of gastric cancer development. Healthcare (Basel) 9(8):1071. 10.3390/healthcare9081071.34442208
Kim YD, Wang J, Shibli F, 2021b. No association between chronic use of ranitidine, compared with omeprazole or famotidine, and gastrointestinal malignancies. Aliment Pharmacol Ther 54(5):606–615. 10.1111/apt.16464.34251045
Kimbrough RD. 1982. Pathological changes in human beings acutely poisoned by dimethylnitrosamine. In: Magee KD, ed. Nitrosamines and human cancer. Banbury Report. Vol. 12. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 25–36.
Klaude M, Persson G, von der Decken A. 1989. Combined effect of dimethylnitrosamine and a lysine-restricted diet on O6-methylguanine-DNA methyltransferase levels in mouse tissues. Mutat Res 218(2):135–142. 10.1016/0921-8777(89)90019-0.2505067
Klein RG. 1982. Calculations and measurements on the volatility of N-nitrosamines and their aqueous solutions. Toxicology 23(2–3):135–147. 10.1016/0300-483x(82)90093-2.7112590
Klein RG, Schmezer P. 1984. Quantitative measurement of the exhalation rate of volatile N-nitrosamines in inhalation experiments with anaesthetized Sprague-Dawley rats. IARC Sci Publ 57:513–517.
Klein RG, Janowsky I, Schmezer P, 1989. Effect of long-term inhalation of N-nitroso-dimethylamine (NDMA) and SO2/NOx in rats. Exp Pathol 37(1–4):273–280. 10.1016/s0232-1513(89)80067-2.2637168
Klein RG, Janowsky I, Pool-Zobel BL, 1991. Effects of long-term inhalation of N-nitrosodimethylamine in rats. IARC Sci Publ 105:322–328.
Kma L, Sharan RN. 2014. Dimethylnitrosamine-induced reduction in the level of poly-ADP-ribosylation of histone proteins of blood lymphocytes--a sensitive and reliable biomarker for early detection of cancer. Asian Pac J Cancer Prev 15(15):6429–6436. 10.7314/apjcp.2014.15.15.6429.25124638
Knekt P, Jarvinen R, Dich J, 1999. Risk of colorectal and other gastro-intestinal cancers after exposure to nitrate, nitrite and N-nitroso compounds: a follow-up study. Int J Cancer 80(6):852–856. 10.1002(sici)1097-0215(19990315)80:6<852::aid-ijc9>3/.0.co;2-s.10074917
Kobayashi M, Tchan Y. 1978. Formation of dimethylnitrosamine in polluted environment and the role of photosynthetic bacteria. Water Res 12(3):199–201. 10.1016/0043-1354(78)90009-X.
Koike R, Uchiyama T, Arimoto-Kobayashi S, 2018. Increase of somatic cell mutations in oxidative damage-sensitive drosophila. Genes Environ 40:3. 10.1186/s41021-017-0090-z.29339978
Koppang N, Rimeslatten H. 1976. Toxic and carcinogenic effects of nitrosodimethylamine in mink. IARC Sci Publ 14:443–452.
Kornbrust D, Dietz D. 1985. Aroclor 1254 pretreatment effects on DNA repair in rat hepatocytes elicited by in vivo or in vitro exposure to various chemicals. Environ Mutagen 7(6):857–870. 10.1002/em.2860070607.3933969
Korsrud GO, Grice HG, Goodman TK, 1973. Sensitivity of several serum enzymes for the detection of thioacetamide-, dimethylnitrosamine- and diethanolamine-induced liver damage in rats. Toxicol Appl Pharmacol 26(2):299–313. 10.1016/0041-008x(73)90265-2.4751108
Krasner SW, Mitch WA, McCurry DL, 2013. Formation, precursors, control, and occurrence of nitrosamines in drinking water: a review. Water Res 47(13):4433–4450. 10.1016/j.watres.2013.04.050.23764594
Krasner SW, Westerhoff P, Mitch WA, 2018. Behavior of NDMA precursors at 21 full-scale water treatment facilities. Environ Sci 4(12):1966–1978. 10.1039/c8ew00442k.
Krishna G, Theiss JC. 1995. Concurrent analysis of cytogenetic damage in vivo: a multiple endpoint-multiple tissue approach. Environ Mol Mutagen 25(4):314–320. 10.1002/em.2850250408.7607186
Krishna G, Kropko ML, Theiss JC. 1990. Dimethylnitrosamine-induced micronucleus formation in mouse bone marrow and spleen. Mutat Res 242(4):345–351. 10.1016/0165-1218(90)90053-5.2255328
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kroeger-Koepke MB, Michejda CJ. 1979. Evidence for several demethylase enzymes in the oxidation of dimethylnitrosamine and phenylmethylnitrosamine by rat liver fractions. Cancer Res 39(5):1587–1591.34478
Kroeger-Koepke MB, Koepke SR, Hernandez L, 1992. Activation of a beta-hydroxyalkylnitrosamine to alkylating agents: evidence for the involvement of a sulfotransferase. Cancer Res 52(12):3300–3305.1596888
Krul CA, Zeilmaker MJ, Schothorst RC, 2004. Intragastric formation and modulation of N-nitrosodimethylamine in a dynamic in vitro gastrointestinal model under human physiological conditions. Food Chem Toxicol 42(1):51–63.14630130
Kulka U, Paul D, Bauchinger M. 1993. Development of short-term mutagenicity test systems in vitro: Metabolic activation of indirectly acting mutagens by three immortal rat hepatocyte lines. Mutagenesis 8(3):193–197. 10.1093/mutage/8.3.193.8332081
Kuroki T, Drevon C, Montesano R. 1977. Microsome-mediated mutagenesis in V79 Chinese hamster cells by various nitrosamines. Cancer Res 37(4):1044–1050.321116
Kyrtopoulos SA. 1998. DNA adducts in humans after exposure to methylating agents. Mutat Res 405(2):135–143.9748543
La Vecchia C, D'Avanzo B, Airoldi L, 1995. Nitrosamine intake and gastric cancer risk. Eur J Cancer Prev 4(6):469–474. 10.1097/00008469-199512000-00005.8580782
Lachapelle M, Fadlallah S, Krzystyniak K, 1992. Colloidal gold ultraimmunocytochemical localization of DNA and RNA adducts in rat hepatocytes. Carcinogenesis 13(12):2335–2339. 10.1093/carcin/13.12.2335.1282095
Lachapelle M, Marion M, Krzystyniak K, 1994. Immunocytochemical evidence for a nuclear and a cytoplasmic O6-methylguanine repair mechanism in cultured rat hepatocytes. J Toxicol Environ Health 43(4):441–451. 10.1080/15287399409531933.7990169
Lakritz L, Pensabene JW. 1984. Survey of human milk for volatile N-nitrosamines and the influence of diet on their formation. Food Chem Toxicol 22(9):721–724. 10.1016/0278-6915(84)90199-6.6541625
Lakritz L, Simenhoff ML, Dunn SR, 1980. N-Nitrosodimethylamine in human blood. Food Cosmet Toxicol 18(1):77–79. 10.1016/0015-6264(80)90014-0.7372214
Lambert IB, Singer TM, Boucher SE, 2005. Detailed review of transgenic rodent mutation assays. Mutat Res 590(1–3):1–280. 10.1016/j.mrrev.2005.04.002.16081315
Langenbach R. 1986. Mutagenic activity and structure-activity relationships of short-chain dialkyl N-nitrosamines in a hamster hepatocyte V79 cell-mediated system. Mutat Res 163(3):303–311. 10.1016/0027-5107(86)90029-1.3785266
Langenbach R, Leavitt S, Hix C, 1986. Rat and hamster hepatocyte-mediated induction of SCEs and mutation in V79 cells and mutation of salmonella by aminofluorene and dimethylnitrosamine. Mutat Res 161(1):29–37. 10.1016/0027-5107(86)90097-7.3010094
Larsson SC, Bergkvist L, Wolk A. 2006. Processed meat consumption, dietary nitrosamines and stomach cancer risk in a cohort of Swedish women. Int J Cancer 119(4):915–919. 10.1002/ijc.21925.16550597
Lawson T, Kolar C. 1992. Mutation of V79 cells by N-dialkylnitrosamines after activation by hamster pancreas duct cells. Mutat Res 272(2):139–144. 10.1016/0165-1161(92)90042-k.1383746
Le Hegarat L, Dumont J, Josse R, 2010. Assessment of the genotoxic potential of indirect chemical mutagens in HepaRG cells by the comet and the cytokinesis-block micronucleus assays. Mutagenesis 25(6):555–560. 10.1093/mutage/geq039.20675360
Leavey-Roback SL, Sugar CA, Krasner SW, 2016. NDMA formation during drinking water treatment: A multivariate analysis of factors influencing formation. Water Res 95:300–309. 10.1016/j.watres.2016.02.060.27015632
Lee HS. 2019. Literature compilation of volatile N-nitrosamines in processed meat and poultry products - an update. Food Addit Contam Part A Chem Anal Control Expo Risk Assess 36(10):1491–1500. 10.1080/19440049.2019.1649472.31393816
Lee U, Oh E. 2015. Pharmacokinetic changes of drugs in a rat model of liver cirrhosis induced by dimethylnitrosamine, alone and in combination with diabetes mellitus induced by streptozotocin. Biopharm Drug Dispos 36(1):1–14. 10.1002/bdd.1901.24861008
Lee VM, Keefer LK, Archer MC. 1996. An evaluation of the roles of metabolic denitrosation and α-hydroxylation in the hepatotoxicity of N-nitrosodimethylamine. Chem Res Toxicol 9(8):1319–1324. 10.1021/tx960077u.8951235
Lee WR, Abrahamson S, Valencia R, 1983. The sex-linked recessive lethal test for mutagenesis in Drosophila melanogaster. A report of the U.S. Environmental Protection Agency Gene-Tox Program. Mutat Res 123(2):183–279. 10.1016/0165-1110(83)90025-8.6413857
Lee C, Choi W, Kim YG, 2005. UV photolytic mechanism of N-nitrosodimethylamine in water: dual pathways to methylamine versus dimethylamine. Environ Sci Technol 39(7):2101–2106.15871243
Lefevre PA, Tinwell H, Galloway SM, 1994. Evaluation of the genetic toxicity of the peroxisome proliferator and carcinogen methyl clofenapate, including assays using Muta mouse and Big Blue transgenic mice. Hum Exp Toxicol 13(11):764–775.7857696
Levallois P, Ayotte P, Van MJMS, 2000. Excretion of volatile nitrosamines in a rural population in relation to food and drinking water consumption. Food Chem Toxicol 38(11):1013–1019. 10.1016/s0278-6915(00)00089-2.11038239
Liangpunsakul S, Kolwankar D, Pinto A, 2005. Activity of CYP2E1 and CYP3A enzymes in adults with moderate alcohol consumption: A comparison with nonalcoholics. Hepatology 41(5):1144–1150. 10.1002/hep.20673.15841467
Liew D, Culbert J, Linge K, 2015. National occurrence of N-nitrosodimethylamine (NDMA): An investigation of 38 Australian drinking water supplies. ACS Symp Ser 1190:135–149. 10.1021/bk-2015-1190.ch008.
Lijinsky W, Reuber MD. 1984. Carcinogenesis in rats by nitrosodimethylamine and other nitrosomethylalkylamines at low doses. Cancer Lett 22(1):83–88. 10.1016/0304-3835(84)90047-8.6538112
Lijinsky W, Kovatch RM. 1989. Carcinogenesis by nitrosamines and azoxyalkanes by different routes of administration to rats. Biomed Environ Sci 2(2):154–159.2590501
Lijinsky W, Kovatch RM, Riggs CW. 1987. Carcinogenesis by nitrosodialkylamines and azoxyalkanes given by gavage to rats and hamsters. Cancer Res 47(15):3968–3972.3607743
Liviac D, Creus A, Marcos R. 2011. Genotoxic evaluation of the non-halogenated disinfection byproducts nitrosodimethylamine and nitrosodiethylamine. J Hazard Mater 185(2–3):613–618. 10.1016/j.jhazmat.2010.09.062.20952128
Loh YH, Jakszyn P, Luben RN, 2011. N-Nitroso compounds and cancer incidence: the European Prospective Investigation into Cancer and Nutrition (EPIC)-Norfolk study. Am J Clin Nutr 93(5):1053–1061. 10.3945/ajcn.111.012377.21430112
Lorr NA, Miller KW, Chung HR, 1984. Potentiation of the hepatotoxicity of N-nitrosodimethylamine by fasting, diabetes, acetone, and isopropanol. Toxicol Appl Pharmacol 73(3):423–431. 10.1016/0041-008x(84)90095-4.6719461
Lotlikar PD, Hong YS, Baldy WJ. 1978. Effect of dimethylnitrosamine concentration on its demethylation by liver microsomes from control and 3-methylcholanthrene pretreated rats, hamsters and guinea pigs. Cancer Lett 4(6):355–361. 10.1016/s0304-3835(78)95777-4.667816
Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book, Co., 4–9.
Lyman WJ. 1985. Estimation of physical properties. In: Neely WB, Blau GE, eds. Environmental exposure from chemicals. Vol. 1. Boca Raton, FL: CRC Press, Inc., 30–31.
Ma XL, Baraona E, Lasker JM, 1991. Effects of ethanol consumption on bioactivation and hepatotoxicity of N-nitrosodimethylamine in rats. Biochem Pharmacol 42(3):585–591. 10.1016/0006-2952(91)90321-u.1859464
Ma F, Zhang Z, Jiang J, 2015. Chromium (VI) potentiates the DNA adducts (O(6)-methylguanine) formation of N-nitrosodimethylamine in rat: implication on carcinogenic risk. Chemosphere 139:256–259. 10.1016/j.chemosphere.2015.06.077.26143543
Madden JW, Gertman PM, Peacock EE. 1970. Dimethylnitrosamine-induced hepatic cirrhosis: a new canine model of an ancient human disease. Surgery 68(1):260–267; discussion 267-268.10483478
Madle E, Kasper P, Madle S, 1987. Hepatocyte-mediated SCE induction by indirect mutagens: importance of hepatocyte density and cell-to-cell contact. Mutat Res 188(2):153–160. 10.1016/0165-1218(87)90105-4.3108661
Maduagwu EN, Bassir O. 1980. A comparative assessment of toxic effects of dimethylnitrosamine in six different species. Toxicol Appl Pharmacol 53(2):211–219. 10.1016/0041-008x(80)90421-4.6771883
Magee PN. 1956. Toxic liver injury; the metabolism of dimethylnitrosamine. Biochem J 64(4):676–682. 10.1042/bj0640676.13382818
Magee PN, Barnes JM. 1956. The production of malignant primary hepatic tumours in the rat by feeding dimethylnitrosamine. Br J Cancer 10(1):114–122. 10.1038/bjc.1956.15.13342328
Magee PN, Hultin T. 1962. Toxic liver injury and carcinogenesis. Methylation of proteins of rat-liver slices by dimethylnitrosamine in vitro. Biochem J 83:106–114. 10.1042/bj0830106.14468248
Maling HM, Stripp B, Sipes IG, 1975. Enhanced hepatotoxicity of carbon tetrachloride, thioacetamide, and dimethylnitrosamine by pretreatment of rats with ethanol and some comparisons with potentiation by isopropanol. Toxicol Appl Pharmacol 33(2):291–308. 10.1016/0041-008x(75)90096-4.1179434
Mallik MA, Tesfai K. 1981. Transformation of nitrosamines in soil and in vitro by soil microorganisms. Bull Environ Contam Toxicol 27(1):115–121. 10.1007/bf01610996.7296028
Martelli A, Robbiano L, Giuliano L, 1985. DNA fragmentation by N-nitrosodimethylamine and methyl methanesulfonate in human hepatocyte primary cultures. Mutat Res 144(3):209–211. 10.1016/0165-7992(85)90142-3.4058441
Martelli A, Robbiano L, Gazzaniga GM, 1988. Comparative study of DNA damage and repair induced by ten N-nitroso compounds in primary cultures of human and rat hepatocytes. Cancer Res 48(15):4144–4152.3390807
Martino PE, Diaz Gomez MI, Tamayo D, 1988. Studies on the mechanism of the acute and carcinogenic effects of N-nitrosodimethylamine on mink liver. J Toxicol Environ Health 23(2):183–192. 10.1080/15287398809531105.3343695
Matsuoka A, Hayashi M, Ishidate M. 1979. Chromosomal aberration tests on 29 chemicals combined with S9 mix in vitro. Mutat Res 66(3):277–290. 10.1016/0165-1218(79)90089-2.375085
Matsuoka A, Sofuni T, Ishidate M. 1986. Effect of surfactants on the induction of chromosomal aberrations in Chinese hamster cells in culture [abstract]. Mutat Res 164:273–274.
Matsushima T, Hayashi M, Matsuoka A, 1999. Validation study of the in vitro micronucleus test in a Chinese hamster lung cell line (CHL/IU). Mutagenesis 14(6):569–580. 10.1093/mutage/14.6.569.10567032
McCormick A, Nicholson MJ, Baylis MA, 1973. Nitrosamines in cigarette smoke condensate. Nature 244(5413):237–238. 10.1038/244237a0.4583100
McGiven AR, Ireton HJ. 1972. Renal epithelial dysplasia and neoplasia in rats given dimethylnitrosamine. J Pathol 108(3):187–190. 10.1002/path.1711080303.4119087
McGwin G. 2020. The association between ranitidine use and gastrointestinal cancers. Cancers (Basel) 13(1):24. 10.3390/cancers13010024.33374592
McLaren J, Boulikas T, Vamvakas S. 1994. Induction of poly(ADP-ribosyl)ation in the kidney after in vivo application of renal carcinogens. Toxicology 88(1–3):101–112. 10.1016/0300-483x(94)90113-9.8160192
McNamee JP, Bellier PV. 2015. Use of a standardized JaCVAM in vivo rat comet assay protocol to assess the genotoxicity of three coded test compounds; ampicillin trihydrate, 1,2-dimethylhydrazine dihydrochloride, and N-nitrosodimethylamine. Mutat Res Genet Toxicol Environ Mutagen 786–788:158–164. 10.1016/j.mrgentox.2015.02.005.
McQueen CA, Kreiser DM, Williams GM. 1983. The hepatocyte primary culture/DNA repair assay using mouse or hamster hepatocytes. Environ Mutagen 5(1):1–8. 10.1002/em.2860050102.
Mehta R, Silinskas KC, Zucker PF, 1987. Micronucleus formation induced in rat liver and esophagus by nitrosamines. Cancer Lett 35(3):313–320. 10.1016/0304-3835(87)90133-9.3594426
Michaud DS, Holick CN, Batchelor TT, 2009. Prospective study of meat intake and dietary nitrates, nitrites, and nitrosamines and risk of adult glioma. Am J Clin Nutr 90(3):570–577. 10.3945/ajcn.2008.27199.19587083
Mico BA, Swagzdis JE, Hu HS, 1985. Low-dose in vivo pharmacokinetic and deuterium isotope effect studies of N-nitrosodimethylamine in rats. Cancer Res 45(12 Pt 1):6280–6285.4063978
Mills AL, Alexander M. 1976. Factors affecting dimethylnitrosamine formation in samples of soil and water. J Environ Qual 5(4):437–440. 10.2134/jeq1976.00472425000500040024x.
Mirsalis JC, Butterworth BE. 1980. Detection of unscheduled DNA synthesis in hepatocytes isolated from rats treated with genotoxic agents: an in vivo- in vitro assay for potential carcinogens and mutagens. Carcinogenesis 1(7):621–625. 10.1093/carcin/1.7.621.11219838
Mirsalis JC, Tyson CK, Steinmetz KL, 1989. Measurement of unscheduled DNA synthesis and S-phase synthesis in rodent hepatocytes following in vivo treatment: Testing of 24 compounds. Environ Mol Mutagen 14(3):155–164. 10.1002/em.2850140305.2792091
Mirsalis JC, Provost GS, Matthews CD, 1993. Induction of hepatic mutations in lacI transgenic mice. Mutagenesis 8(3):265–271. 10.1093/mutage/8.3.265.8332090
Mirvish SS. 1975. Formation of N-nitroso compounds: Chemistry, kinetics, and in vivo occurrence. Toxicol Appl Pharmacol 31(3):325–351. 10.1016/0041-008x(75)90255-0.238307
Mirvish SS, Issenberg P, Sornson HC. 1976. Air-water and ether-water distribution of N-nitroso compounds: implications for laboratory safety, analytic methodology, and carcinogenicity for the rat esophagus, nose, and liver. J Natl Cancer Inst 56(6):1125–1129. 10.1093/jnci/56.6.1125.994213
Mitch WA, Sharp JO, Trussell RR, 2003. N-Nitrosodimethylamine (NDMA) as a drinking water contaminant: A review. Environ Eng Sci 20(5):389–404. 10.1089/109287503768335896.
Moiseev GE, Benemanskii VV. 1975. [The carcinogenic activity of small concentrations of nitrosodimethylamine when inhaled]. Vopr Onkol 21(6):107–109. (Russian)1210151
Moniuszko-Jakoniuk J, Roszczenko A, Dzieciol J. 1999. Influence of low concentrations of N-nitrosodimethylamine on the iron level and histopathological picture of rats liver, spleen and bone marrow. Acta Pol Toxicol 7(2):179–186.
Moon SH, Lee CM, Park SH, 2019. Effects of hepatocyte growth factor gene-transfected mesenchymal stem cells on dimethylnitrosamine-induced liver fibrosis in rats. Growth Factors 37(3–4):105-119. 10.1080/08977194.2019.1652399.
Morrison V, Ashby J. 1994. Reconciliation of five negative and four positive reports of the activity of dimethylnitrosamine in the mouse bone marrow micronucleus assay. Mutagenesis 9(4):361–365. 10.1093/mutage/9.4.361.7968579
Mumma RO, Raupach DC, Waldman JP, 1984. National survey of elements and other constituents in municipal sewage sludges. Arch Environ Contam Toxicol 13(1):75–83. 10.1007/bf01055648.
Nakatsuru Y, Matsukuma S, Nemoto N, 1993. O^6^-Methylguanine-DNA methyltransferase protects against nitrosamine-induced hepatocarcinogenesis. Proc Natl Acad Sci U S A 90(14):6468–6472. 10.1073/pnas.90.14.6468.8341657
Napalkov NP, Alexandrov VA. 1968. On the effects of blastomogenic substances on the organism during embryogenesis. Z Krebsforsch 71(1):32–50. 10.1007/bf00524500.4299347
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Nasr NE H, Metwaly MG, Ahmed EO, 2021. Investigating the root cause of N-nitrosodimethylamine formation in metformin pharmaceutical products. Expert Opin Drug Saf 20(7):855–862. 10.1080/14740338.2021.1917547.33849366
Neal SB, Probst GS. 1983. Chemically-induced sister-chromatid exchange in vivo in bone marrow of Chinese hamsters. An evaluation of 24 compounds. Mutat Res 113(1):33–43. 10.1016/0165-1161(83)90239-x.6828042
Negishi T, Shiotani T, Fujikawa K, 1991. The genotoxicities of N-nitrosamines in Drosophila melanogaster in vivo: the correlation of mutagenicity in the wing spot test with the DNA damages detected by the DNA-repair test. Mutat Res 252(2):119–128. 10.1016/0165-1161(91)90012-w.1901957
Negishi T, Yamada K, Miyamoto K, 2020. Mismatch repair systems might facilitate the chromosomal recombination induced by N-nitrosodimethylamine, but not by N-nitrosodiethylamine, in Drosophila. Mutagenesis 35(2):197–206. 10.1093/mutage/geaa008.32109288
Ng WL, Fong LY, Newberne PM. 1984. Forestomach squamous papillomas in the rat: effect of dietary zinc deficiency on induction. Cancer Lett 22(3):329–332. 10.1016/0304-3835(84)90170-8.6713373
NIOSH. 2019. N-Nitrosodimethylamine. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0461.html. April 11, 2020.
Nishie K. 1983. Comparison of the effects of N-nitrosodimethylamine on pregnant and nonpregnant Holtzman rats. Food Chem Toxicol 21(4):453–462. 10.1016/0278-6915(83)90102-3.6684627
Nishie K, Norred WP, Wasserman A, 1972. Phototoxicity and differential hepatotoxicity as biological indicators of nitrosamine activity. Toxicol Appl Pharmacol 23(4):680–691. 10.1016/0041-008x(72)90108-1.4630166
Nivard MJ, Pastink A, Vogel EW. 1996. Mutational spectra induced under distinct excision repair conditions by the 3 methylating agents N-methyl-N-nitrosourea, N-methyl-N'-nitro-N-nitrosoguanidine and N-nitrosodimethylamine in postmeiotic male germ cells of Drosophila. Mutat Res 352(1–2):97–115. 10.1016/0027-5107(96)00011-5.8676923
Nørgaard M, Andersen IT, Heide-Jørgensen U, 2022. Ranitidine and risk of bladder and kidney cancer: A population-based cohort study. Cancer Epidemiol Biomarkers Prev 31(1):45–50. 10.1158/1055-9965.Epi-21-0737.34649959
NTP. 2016. N-Nitrosamines: 15 listings. In: Report on carcinogens. 14th ed. National Toxicology Program, https://ntp.niehs.nih.gov/ntp/roc/content/profiles/nitrosamines.pdf. April 11, 2020.
NTP. 2021. N-Nitrosamines: 15 listings. In: Report on carcinogens. 15^th^ ed. National Toxicology Program, https://ntp.niehs.nih.gov/ntp/roc/content/profiles/nitrosamines.pdf. August 27, 2022.
O'Connor PJ, Chu YH, Cooper DP, 1982. Species differences in the inducibility of hepatic O^6^-alkylguanine repair in rodents. Biochimie 64(8–9):769–773. 10.1016/s0300-9084(82)80127-2.6814526
Odagiri Y, Adachi S, Katayama H, 1986. Detection of the cytogenetic effect of inhaled aerosols by the micronucleus test. Mutat Res 170(1–2):79–83. 10.1016/0165-1218(86)90084-4.3083247
Ohsawa K, Furihata C, Mori M, 1993. Ability of N-methyl-N'-nitro-N-nitrosoguanidine, 4-nitroquinoline 1-oxide, dimethylnitrosamine, and NaCl to induce unscheduled DNA synthesis, stimulate replicative DNA synthesis, and produce DNA single-strand breaks in pyloric mucosa of rat stomach. Mutat Res 287(2):307–319. 10.1016/0027-5107(93)90023-9.7685490
Okabe A, Kiriyama Y, Suzuki S, 2019. Short-term detection of gastric genotoxicity using the DNA double-strand break marker gamma-H2AX. J Toxicol Pathol 32(2):91–99. 10.1293/tox.2019-0007.31092975
Okinaka RT, Barnhart BJ, Chen DJ. 1981. Comparison between sister-chromatid exchange and mutagenicity following exogenous metabolic activation of promutagens. Mutat Res 91(1):57–61. 10.1016/0165-7992(81)90071-3.7193802
Oliver JE. 1979. Volatilization of some herbicide-related nitrosamines from soils. J Environ Qual 8(4):596–601. 10.2134/jeq1979.00472425000800040031x.
Oliver JE, Kearney PC, Kontson A. 1979. Degradation of herbicide-related nitrosamines in aerobic soils. J Agric Food Chem 27(4):887–891. 10.1021/jf60224a018.
Omori Y, Takahashi A, Ohno Y, 1979. Drug-nitrite interactions: species and sex differences in the formation of dimethylnitrosamine and its effects on the hepatic enzyme activities. Arch Toxicol Suppl 2(2):349–354. 10.1007/978-3-642-67265-1_35.
O'Neil MJ. 2013. N-Nitrosodimethylamine. In: The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 15^th^ ed. Cambridge, UK: Royal Society of Chemistry, 1147.
O'Neill JP, Machanoff R, San Sebastian JR, 1982. Cytotoxicity and mutagenicity of dimethylnitrosamine in mammalian cells (CHO/HGPRT system); enhancement by calcium phosphate. Environ Mutagen 4(1):7–18. 10.1002/em.2860040103.7067668
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
OSHA. 2021d. Occupational safety and health standards. 13 Carcinogens. Code of Federal Regulations 29 CFR 1910.1003. Occupational Safety and Health Administration. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1003.pdf. August 28, 2022.
Otsuka H, Kuwahara A. 1971. Hemangiomatous lesions of mice treated with nitrosodimethylamine. Gann 62(3):147–156.5567074
Oury B, Limasset JC, Protois JC. 1997. Assessment of exposure to carcinogenic N-nitrosamines in the rubber industry. Int Arch Occup Environ Health 70(4):261–271.9342627
Özbay S, Sireli UT. 2021. Volatile N-nitrosamines in processed meat products and salami from Turkey. Food Addit Contam Part B Surveill 14(2):110–114. 10.1080/19393210.2021.1885502.33583352
Palli D, Saieva C, Coppi C, 2001. O^6^-Alkylguanines, dietary N-nitroso compounds, and their precursors in gastric cancer. Nutr Cancer 39(1):42–49. 10.1207/S15327914nc391_6.11588901
Pancholy SK. 1978. Formation of carcinogenic nitrosamines in soils. Soil Biol Biochem 10(1):27–32. 10.1016/0038-0717(78)90006-8.
Park SJ, Jeong MJ, Park SR, 2018. Release of N-nitrosamines and N-nitrosatable substances from baby bottle teats and rubber kitchen tools in Korea. Food Sci Biotechnol 27(5):1519–1524. 10.1007/s10068-018-0373-6.30319863
Parr MK, Joseph JF. 2019. NDMA impurity in valsartan and other pharmaceutical products: Analytical methods for the determination of N-nitrosamines. J Pharm Biomed Anal 164:536–549. 10.1016/j.jpba.2018.11.010.30458387
Pedal I, Besserer K, Goerttler K, 1982. Fatal nitrosamine poisoning. Arch Toxicol 50(2):101–112. 10.1007/bf00373392.7125905
Pegg AE, Hui G. 1978. Removal of methylated purines from rat liver DNA after administration of dimethylnitrosamine. Cancer Res 38(7):2011–2017.657138
Pegg AE, Perry W. 1981. Alkylation of nucleic acids and metabolism of small doses of dimethylnitrosamine in the rat. Cancer Res 41(8):3128–3132.7248969
Pegg AE, Perry W, Bennett RA. 1981. Effect of partial hepatectomy on removal of O^6^-methylguanine from alkylated DNA by rat liver extracts. Biochem J 197(1):195–201. 10.1042/bj1970195.7317030
Pelkonen P, Kirby GM, Wild CP, 1994. Metabolism of nitrosamines and aflatoxin B1 by hamster liver CYP2A enzymes. Chem Biol Interact 93(1):41–50. 10.1016/0009-2797(94)90084-1.8069948
Peto R, Gray R, Brantom P, 1984. Nitrosamine carcinogenesis in 5120 rodents: chronic administration of sixteen different concentrations of NDEA, NDMA, NPYR and NPIP in the water of 4440 inbred rats, with parallel studies on NDEA alone of the effect of age of starting (3, 6 or 20 weeks) and of species (rats, mice or hamsters). IARC Sci Publ 57:627–665.
Peto R, Gray R, Brantom P, 1991a. Effects on 4080 rats of chronic ingestion of N-nitrosodiethylamine or N-nitrosodimethylamine: a detailed dose-response study. Cancer Res 51(23 Pt 2):6415–6451.1933906
Peto R, Gray R, Brantom P, 1991b. Dose and time relationships for tumor induction in the liver and esophagus of 4080 inbred rats by chronic ingestion of N-nitrosodiethylamine or N-nitrosodimethylamine. Cancer Res 51(23 Pt 2):6452–6469.1933907
Petzold GL, Swenberg JA. 1978. Detection of DNA damage induced in vivo following exposure of rats to carcinogens. Cancer Res 38(6):1589–1594.647672
Phillips JC, Lake BG, Heading CE, 1975. Studies on the metabolism of dimethylnitrosamine in the rat. I. Effect of dose, route of administration and sex. Food Cosmet Toxicol 13(2):203–209. 10.1016/s0015-6264(75)80005-8.1132850
Plumlee MH, Reinhard M. 2007. Photochemical attenuation of N-nitrosodimethylamine (NDMA) and other nitrosamines in surface water. Environ Sci Technol 41(17):6170–6176.17937298
Pobel D, Riboli E, Cornee J, 1995. Nitrosamine, nitrate and nitrite in relation to gastric cancer: a case-control study in Marseille, France. Eur J Epidemiol 11(1):67–73. 10.1007/bf01719947.7489775
Polo J, Chow YL. 1976. Efficient photolytic degradation of nitrosamines. J Natl Cancer Inst 56(5):997–1001. 10.1093/jnci/56.5.997.994211
Pool BL, Brendler S, Klein RG, 1988. Effects of SO2 or NOx on toxic and genotoxic properties of chemical carcinogens. II. Short term in vivo studies. Carcinogenesis 9(7):1247–1252. 10.1093/carcin/9.7.1247.2898305
Pool BL, Brendler SY, Liegibel UM, 1990. Employment of adult mammalian primary cells in toxicology: in vivo and in vitro genotoxic effects of environmentally significant N-nitrosodialkylamines in cells of the liver, lung, and kidney. Environ Mol Mutagen 15(1):24–35.2298198
Pool-Zobel BL, Klein RG, Liegibel UM, 1992. Systemic genotoxic effects of tobacco-related nitrosamines following oral and inhalational administration to Sprague-Dawley rats. Clin Investig 70(3–4):299–306. 10.1007/bf00184666.
Pottegard A, Kristensen KB, Ernst MT, 2018. Use of N-nitrosodimethylamine (NDMA) contaminated valsartan products and risk of cancer: Danish nationwide cohort study. BMJ 362:k3851. 10.1136/bmj.k3851.30209057
Prival MJ, Mitchell VD. 1981. Influence of microsomal and cytosolic fractions from rat, mouse, and hamster liver on the mutagenicity of dimethylnitrosamine in the Salmonella plate incorporation assay. Cancer Res 41(11 Pt 1):4361–4367.7030474
Qiu Y, Bei E, Xie S, 2019. Contributions of volatilization, photolysis, and biodegradation to N‑nitrosodimethylamine removal in conventional drinking water treatment plants. Sci Total Environ 697:133993. 10.1016/j.scitotenv.2019.133993.32380594
Ramakrishna G, Bialkowska A, Perella C, 2000. Ki-ras and the characteristics of mouse lung tumors. Mol Carcinog 28(3):156–167. 10.1002/1098-2744(200007)28:3<156::aid-mc4>3.0.co;2-m.10942532
Rana SV, Kumar A. 2000. Metallothionein induced by cadmium or zinc inhibits lipid peroxidation in rats exposed to dimethylnitrosamine. Arh Hig Rada Toksikol 51(3):279–286.11148932
Rana SV, Kumar A. 2001. Effect of cadmium and zinc-metallothionein on methemoglobin and nitric oxide in dimethylnitrosamine treated rats. Indian J Exp Biol 39(5):487–489.11510137
Rao GS, Osborn JC, Adatia MR. 1982. Drug-nitrite interactions in human saliva: effects of food constituents on carcinogenic N-nitrosamine formation. J Dent Res 61(6):768–771. 10.1177/00220345820610062301.6953112
Reh BD, Fajen JM. 1996. Worker exposures to nitrosamines in a rubber vehicle sealing plant. Am Ind Hyg Assoc J 57(10):918–923. 10.1080/15428119691014431.8865601
Reny R, Plumlee MH, Kodamatani H, 2021. NDMA and NDMA precursor attenuation in environmental buffers prior to groundwater recharge for potable reuse. Sci Total Environ 762:144287. 10.1016/j.scitotenv.2020.144287.33360455
RePORTER. 2022. N-Nitrosodimethylamine. Research Portfolio Online Reporting Tools, National Institutes of Health. http://projectreporter.nih.gov/reporter.cfm. April 9, 2020.
Robbiano L, Mereto E, Migliazzi Morando A, 1997. An in vivo micronucleus assay for detecting the clastogenic effect in rat kidney cells. Mutat Res 390(1–2):51–57. 10.1016/s0165-1218(96)00165-6.9150752
Robbiano L, Baroni D, Novello L, 2006. Correlation between induction of DNA fragmentation in lung cells from rats and humans and carcinogenic activity. Mutat Res 605(1–2):94–102. 10.1016/j.mrgentox.2006.03.001.16690349
Rodriguez-Arnaiz R, Soto PO, Oyarzun JC, 1996. Analysis of mitotic recombination induced by several mono- and bifunctional alkylating agents in the Drosophila wing-spot test. Mutat Res 351(2):133–145. 10.1016/0027-5107(95)00217-0.8622707
Rogers MA, Vaughan TL, Davis S, 1995. Consumption of nitrate, nitrite, and nitrosodimethylamine and the risk of upper aerodigestive tract cancer. Cancer Epidemiol Biomarkers Prev 4(1):29–36.7894321
Roscher E, Wiebel FJ. 1989. H4IIEC3 rat hepatoma cells activate N-nitrosodimethylamine but are resistant to the genotoxic products. Mutagenesis 4(4):292–296. 10.1093/mutage/4.4.292.2550724
Ross RD, Morrison J, Rounbehler DP, 1977. N-Nitroso-compound impurities in herbicide formulations. J Agric Food Chem 25(6):1416–1418. 10.1021/jf60214a013.915140
Rossberger S, Andrae U, Wiebel FJ. 1987. Comparison of the continuous rat hepatoma cell line 2sFou with primary rat hepatocyte cultures for the induction of DNA repair synthesis by nitrosamines, benzo[a]pyrene and hydroxyurea. Mutat Res 182(1):41–51. 10.1016/0165-1161(87)90006-9.3807938
Rostkowska K, Zwierz K, Arciuch LP, 1998. Activity of lysosomal exoglycosidases of rat alimentary tract in chronic exposure to N-nitrosodimethylamine. Pol J Environ Stud 7(5):313–316.
Roszczenko A, Jablonski J, Moniuszko-Jakoniuk J. 1996a. [Effect of n-nitrosodimethylamine (NDMA) on activity of selected enzymes in blood serum of the rat]. Med Pr 47(1):49–53. (Polish)8834597
Roszczenko A, Jablonski J, Moniuszko-Jakoniuk J, 1996b. The influence of low doses of n-nitrosodimethylamine on the chosen parameters of iron balance in rat. Pol J Environ Stud 5(5):37–40.
Rothfuss A, O’Donovan M, De BM, 2010. Collaborative study on fifteen compounds in the rat-liver Comet assay integrated into 2- and 4-week repeat-dose studies. Mutat Res 702(1):40–69. 10.1016/j.mrgentox.2010.07.006.20656055
Rounbehler DP, Reisch J, Fine DH. 1980. Nitrosamines in new motor-cars. Food Cosmet Toxicol 18(2):147–151. 10.1016/0015-6264(80)90068-1.7390337
Rounbehler DP, Krull IS, Goff EU, 1979. Exposure to n-nitrosodimethylamine in a leather tannery. Food Cosmet Toxicol 17(5):487–491. 10.1016/0015-6264(79)90008-7.520982
Sack S, Avisar D, Kaplan A, 2021. Detection of N-nitrosodimethylamine (NDMA) and its formation potential in hospital wastewater. Environ Sci Pollut Res Int 28(11):14199–14206. 10.1007/s11356-021-12785-1.33547606
Saha JK, Xia J, Sandusky GE, 2007. Study of plasma protein C and inflammatory pathways: biomarkers for dimethylnitrosamine-induced liver fibrosis in rats. Eur J Pharmacol 575(1–3):158–167. 10.1016/j.ejphar.2007.07.052.17719030
Sakai H, Takamatsu T, Kosaka K, 2012. Effects of wavelength and water quality on photodegradation of N-Nitrosodimethylamine (NDMA). Chemosphere 89(6):702–707. 10.1016/j.chemosphere.2012.06.025.22795068
Sasaki YF. 1991. Micronucleus test with mouse peripheral blood erythrocytes: summary report of the fifth collaborative study by CSGMT/JEMS.MMS. Mutat Res 253(3):283. 10.1016/0165-1161(91)90231-v.
Sato S, Taketomi M, Morita T. 1992. Simplified mouse peripheral reticulocyte micronucleus test with dimethylnitrosamine. Mutat Res 278(2–3):103–107.1372689
Sawada S, Furihata C, Matsushima T. 1989. In vivo short-term assays of repair and replication of rat liver DNA. J Cancer Res Clin Oncol 115(4):345–350. 10.1007/bf00400961.2760099
Sawada S, Yamanaka T, Yamatsu K, 1991. Chromosome aberrations, micronuclei and sister-chromatid exchanges (SCEs) in rat liver induced in vivo by hepatocarcinogens including heterocyclic amines. Mutat Res 251(1):59–69. 10.1016/0027-5107(91)90215-a.1944376
Sawada S, Asakura S, Daimon H, 1995. Comparison of autoradiography, liquid scintillation counting and immunoenzymatic staining of 5-bromo-2'-deoxyuridine for measurement of unscheduled DNA synthesis and replicative DNA synthesis in rat liver. Mutat Res 344(3–4):109–116. 10.1016/0165-1218(95)00039-9.7491128
Sawicki E, Belsky T, Friedel RA, 1977. N-Nitrosodimethylamine an ambient air. Analytical method. Health Lab Sci 14(1):59–63.833005
Scanlan RA. 1983. Formation and occurrence of nitrosamines in food. Cancer Res 43(5 Suppl):2435s–2440s.6831466
SCCP. 2007. Opinion on the presence and release of nitrosamines and nitrosatable compounds from rubber balloons. Scientific Committee on Consumer Products. https://ec.europa.eu/health/ph_risk/committees/04_sccp/docs/sccp_o_121.pdf. September 15, 2020.
Scherer E, Van Den Berg T, Vermeulen E, 1989. Immunocytochemical analysis of O6-alkylguanine shows tissue specific formation in and removal from esophageal and liver DNA in rats treated with methylbenzylnitrosamine, dimethylnitrosamine, diethylnitrosamine and ethylnitrosourea. Cancer Lett 46(1):21–29. 10.1016/0304-3835(89)90210-3.2660979
Scherer G, Urban M, Hagedorn HW, 2010. Determination of methyl-, 2-hydroxyethyl- and 2-cyanoethylmercapturic acids as biomarkers of exposure to alkylating agents in cigarette smoke. J Chromatogr 878:2520–2528. 10.1016/j.jchromb.2010.02.023.
Schlingemann J, Boucley C, Hickert S, 2022. Avoiding N-nitrosodimethylamine formation in metformin pharmaceuticals by limiting dimethylamine and nitrite. Int J Pharm 620:121740. 10.1016/j.ijpharm.2022.121740.35421534
Schreiber IM, Mitch WA. 2006. Occurrence and fate of nitrosamines and nitrosamine precursors in wastewater-impacted surface waters using boron as a conservative tracer. Environ Sci Technol 40(10):3203–3210. 10.1021/es052078r.16749682
SEPA. 2015. Review of amine emissions from carbon capture systems. Scottish Environment Protection Agency. https://www.sepa.org.uk/media/155585/review-of-amine-emissions-from-carbon-capture-systems.pdf. June 22, 2022.
Sgroi M, Roccaro P, Oelker GL, 2014. N-Nitrosodimethylamine formation upon ozonation and identification of precursors source in a municipal wastewater treatment plant. Environ Sci Technol 48(17):10308–10315. 10.1021/es5011658.25029629
Sgroi M, Roccaro P, Oelker G, 2016. N-Nitrosodimethylamine (NDMA) formation during ozonation of wastewater and water treatment polymers. Chemosphere 144:1618–1623. 10.1016/j.chemosphere.2015.10.023.26517390
Sgroi M, Vagliasindi FG A, Snyder SA, 2018. N-Nitrosodimethylamine (NDMA) and its precursors in water and wastewater: A review on formation and removal. Chemosphere 191:685–703. 10.1016/j.chemosphere.2017.10.089.29078192
Shaddock JG, Feuers RJ, Chou MW, 1993. Effects of aging and caloric restriction on the genotoxicity of four carcinogens in the in vitro rat hepatocyte/DNA repair assay. Mutat Res 295(1):19–30. 10.1016/0921-8734(93)90008-q.7677926
Shane BS, de Boer JG, Glickman BW, 1999. Oxazepam is mutagenic in vivo in Big Blue^®^ transgenic mice. Carcinogenesis 20(7):1315–1321. 10.1093/carcin/20.7.1315.10383906
Shane BS, Smith-Dunn DL, deBoer JG, 2000a. Subchronic administration of phenobarbital alters the mutation spectrum of lacI in the livers of Big Blue^®^ transgenic mice. Mutat Res Fundam Mol Mech Mutagen 448(1):69–80. 10.1016/s0027-5107(00)00002-6.
Shane BS, Smith-Dunn DL, de Boer JG, 2000b. Mutant frequencies and mutation spectra of dimethylnitrosamine (DMN) at the lacI and cII loci in the livers of Big Blue transgenic mice. Mutat Res 452(2):197–210. 10.1016/s0027-5107(00)00081-6.11024479
Shapley D. 1976. Nitrosamines: scientists on the trail of prime suspect in urban cancer. Science 191(4224):268–270. 10.1126/science.191.4224.268.17832134
Sharma RK, Lemmon M, Bakke J, 1983. Studies of in utero sister chromatid exchange induction and cell replication kinetics [abstract]. Environ Mutagen 5:406.
Sharma S, Salehi F, Scheithauer BW, 2009. Role of MGMT in tumor development, progression, diagnosis, treatment and prognosis. Anticancer Res 29(10):3759–3768.19846906
Sharpless CM, Linden KG. 2003. Experimental and model comparisons of low- and medium-pressure Hg lamps for the direct and H2O2 assisted UV photodegradation of N-nitrosodimethylamine in simulated drinking water. Environ Sci Technol 37(9):1933–1940.12775068
Shen L, Liao X, Qi H, 2019. NDMA formation from 4,4'-hexamethylenebis (HDMS) during ozonation: influencing factors and mechanisms. Environ Sci Pollut Res Int 26(2):1584–1594. 10.1007/s11356-018-3684-5.30443725
Shephard SE, Gunz D, Schlatter C. 1995. Genotoxicity of agaritine in the lacI transgenic mouse mutation assay: Evaluation of the health risk of mushroom consumption. Food Chem Toxicol 33(4):257–264. 10.1016/0278-6915(94)00142-b.7737599
Sheweita SA, El-Bendery HA, Mostafa MH. 2014. Novel study on N-nitrosamines as risk factors of cardiovascular diseases. Biomed Res Int 2014:817019. 10.1155/2014/817019.25243185
Sheweita SA, El Banna YY, Balbaa M, 2017. N-Nitrosamines induced infertility and hepatotoxicity in male rabbits. Environ Toxicol 32(9):2212–2220. 10.1002/tox.22436.28573719
Shimizu RW, Sun JD, Li AP, 1984. The use of sister-chromatid exchange in Chinese hamster primary lung cell cultures to measure genotoxicity. Mutat Res 130(5):333–342. 10.1016/0165-1161(84)90019-0.6493254
Singh J, Roscher E. 1991. Induction of DNA damage by N-nitrosodiethylamine in rat hepatoma cells: correlation with cytochrome P450-mediated aldrin epoxidase activity. Mutagenesis 6(2):117–121. 10.1093/mutage/6.2.117.2056911
Sirianni SR, Huang CC. 1987. Comparison of S9 fractions from rats, mice, and Chinese hamsters to metabolize dimethylnitrosamine and diethylnitrosamine to intermediates that induce sister-chromatid exchanges in V79 cells. Mutat Res 188(1):7–11. 10.1016/0165-1218(87)90108-x.3574338
Skaare JU, Nafstad I. 1978. Interaction of vitamin E and selenium with the hepatotoxic agent dimethylnitrosamine. Acta Pharmacol Toxicol (Copenh) 43(2):119–128. 10.1111/j.1600-0773.1978.tb02245.x.696341
Smith CJ, Perfetti TA, Rumple MA, 2000. "IARC group 2A Carcinogens" reported in cigarette mainstream smoke. Food Chem Toxicol 38(4):371–383. 10.1016/s0278-6915(99)00156-8.10722891
Soltermann F, Lee M, Canonica S, 2013. Enhanced N-nitrosamine formation in pool water by UV irradiation of chlorinated secondary amines in the presence of monochloramine. Water Res 47(1):79–90. 10.1016/j.watres.2012.09.034.23098367
Song P, Wu L, Guan W. 2015. Dietary nitrates, nitrites, and nitrosamines intake and the risk of gastric cancer: A meta-analysis. Nutrients 7(12):9872–9895. 10.3390/nu7125505.26633477
Sørensen L, Zahlsen K, Hyldbakk A, 2015. Photodegradation in natural waters of nitrosamines and nitramines derived from CO2 capture plant operation. Int J Greenhouse Gas Control 32:106–114. 10.1016/j.ijggc.2014.11.004.
Souliotis VL, Chhabra S, Anderson LM, 1995. Dosimetry of O6-methylguanine in rat DNA after low-dose, chronic exposure to N-nitrosodimethylamine (NDMA). Implications for the mechanism of NDMA hepatocarcinogenesis. Carcinogenesis 16(10):2381–2387. 10.1093/carcin/16.10.2381.7586139
Souliotis VL, van Delft JH, Steenwinkel MJ, 1998. DNA adducts, mutant frequencies and mutation spectra in lambda lacZ transgenic mice treated with N-nitrosodimethylamine. Carcinogenesis 19(5):731–739. 10.1093/carcin/19.5.731.9635857
Souliotis VL, Henneman JR, Reed CD, 2002. DNA adducts and liver DNA replication in rats during chronic exposure to N-nitrosodimethylamine (NDMA) and their relationships to the dose-dependence of NDMA hepatocarcinogenesis. Mutat Res 500(1–2):75–87. 10.1016/s0027-5107(01)00301-3.11890936
Spiegelhalder B, Preussman R. 1983. II.1.a Analysis of airborne N-nitrosamines: general aspects and sampling strategies. IARC Sci Publ 45:41–53.
Spiegelhalder B, Eisenbrand G, Preussmann R. 1982. Urinary excretion of N-nitrosamines in rats and humans. IARC Sci Publ 41:443–449.
Steinmetz KL, Mirsalis JC. 1984. Induction of unscheduled DNA synthesis in primary cultures of rat pancreatic cells following in vivo and in vitro treatment with genotoxic agents. Environ Mutagen 6(3):321–330. 10.1002/em.2860060308.6376085
Stott W, Watanabe PG. 1980. Kinetic interaction of chemical mutagens with mouse sperm in vivo as it relates to animal mutagenic effects. Toxicol Appl Pharmacol 55(3):411–416. 10.1016/0041-008x(80)90042-3.7434354
Straif K, Weiland S, Werner B, 1999. Elevated mortality from nonalcohol-related chronic liver disease among female rubber workers: Is it associated with exposure to nitrosamines? Am J Ind Med 35(3):264–271. 10.1002(sici)1097–0274(199903)35:3<264::aid-ajim6>3/.0.co;2-x.9987559
Straif K, Weiland SK, Bungers M, 2000. Exposure to high concentrations of nitrosamines and cancer mortality among a cohort of rubber workers. Occup Environ Med 57(3):180–187. 10.1136/oem.57.3.180.10810100
Streeter AJ, Nims RW, Sheffels PR, 1990a. Metabolic denitrosation of N-nitrosodimethylamine in vivo in the rat. Cancer Res 50(4):1144–1150.2297762
Streeter AJ, Nims RW, Wu PP, 1990b. Toxicokinetics of N-nitrosodimethylamine in the Syrian golden hamster. Arch Toxicol 64(7):562–566. 10.1007/bf01971835.2073129
Stripp B, Sipes G, Maling HM, 1974. Dibenamine impairment of rat hepatic microsomal enzymes and its relation to hepatotoxicity induced by CCl4 and dimethlynitrosamine. Drug Metab Dispos 2(5):464–467.4156310
Strombeck DR, Harrold D, Rogers Q, 1983. Plasma amino acid, glucagon, and insulin concentrations in dogs with nitrosamine-induced hepatic disease. Am J Vet Res 44(11):2028–2036.6359978
Stuff JE, Goh ET, Barrera SL, 2009. N-Nitroso compounds: Assessing agreement between food frequency questionnaires and 7-day food records. J Am Diet Assoc 109:1179–1183. 10.1016/j.jada.2009.04.006.19559134
Stumpf R, Margison GP, Montesano R, 1979. Formation and loss of alkylated purines from DNA of hamster liver after administration of dimethylnitrosamine. Cancer Res 39(1):50–54.761197
Sulc M, Hodek P, Stiborova M. 2010. The binding affinity of carcinogenic N-nitrosodimethylamine and N-nitrosomethylaniline to cytochromes P450 2B4, 2E1 and 3A6 does not dictate the rate of their enzymatic N-demethylation. Gen Physiol Biophys 29(2):175–185. 10.4149/gpb_2010_02_175.20577029
Sulc M, Kubickova B, Maslova V, 2004. Rabbit liver microsomal system: study of interaction with two model N-nitrosamines and their metabolism. Gen Physiol Biophys 23(4):423–433.15815077
Sumi Y, Miyakawa M. 1983. Susceptibility of germ-free rats to the hepatotoxic effects of dimethylnitrosamine or dimethylamine plus sodium nitrite administered orally. Cancer Res 43(6):2942–2946.6850604
Surh YJ, Lee RC, Park KK, 1995. Chemoprotective effects of capsaicin and diallyl sulfide against mutagenesis or tumorigenesis by vinyl carbamate and N-nitrosodimethylamine. Carcinogenesis 16(10):2467–2471. 10.1093/carcin/16.10.2467.7586153
Suzuki T, Itoh T, Hayashi M, 1996. Organ variation in the mutagenicity of dimethylnitrosamine in Big Blue mice. Environ Mol Mutagen 28(4):348–353. 10.1002(SICI)1098-2280(1996)28:4<348::AID-EM8>3/.0.CO;2-7.8991063
Suzuki T, Miyata Y, Saeki K, 1998. In vivo mutagenesis by the hepatocarcinogen quinoline in the lacZ transgenic mouse: evidence for its in vivo genotoxicity. Mutat Res 412(2):161–166. 10.1016/s1383-5718(97)00185-x.9539970
Suzuki H, Ikeda N, Kobayashi K, 2005. Evaluation of liver and peripheral blood micronucleus assays with 9 chemicals using young rats. A study by the Collaborative Study Group for the Micronucleus Test (CSGMT)/Japanese Environmental Mutagen Society (JEMS)-Mammalian Mutagenicity Study Group (MMS). Mutat Res 583(2):133–145. 10.1016/j.mrgentox.2005.03.012.15899588
Suzuki H, Takasawa H, Kobayashi K, 2009. Evaluation of a liver micronucleus assay with 12 chemicals using young rats (II): a study by the Collaborative Study Group for the Micronucleus Test/Japanese Environmental Mutagen Society-Mammalian Mutagenicity Study Group. Mutagenesis 24(1):9–16. 10.1093/mutage/gen047.18765420
Swann PF, Coe AM, Mace R. 1984. Ethanol and dimethylnitrosamine and diethylnitrosamine metabolism and disposition in the rat. Possible relevance to the influence of ethanol on human cancer incidence. Carcinogenesis 5(10):1337–1343. 10.1093/carcin/5.10.1337.6435899
Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28. 10.1007/978-1-4612-5462-1_3.
Swedmark S, Romert L, Beije B, 1994. Comparison of co-cultivation of V79 cells with rat hepatocytes and rat H4IIE hepatoma cells for studying nitrosamine-induced hprt gene mutations. Mutagenesis 9(4):281–287. 10.1093/mutage/9.4.281.7968567
Szczuka A, Huang N, MacDonald JA, 2020. N-Nitrosodimethylamine formation during UV/hydrogen peroxide and UV/chlorine advanced oxidation process treatment following reverse osmosis for potable reuse. Environ Sci Technol 54(23):15465–15475. 10.1021/acs.est.0c05704.33185421
Takahashi S, Hall J, Montesano R. 1996. Temporal cell-type-specific mRNA expression of O6-methylguanine-DNA methyltransferases in liver of rats treated with dimethylnitrosamine. Am J Pathol 148(2):497–507.8579112
Takahashi S, Ikeda Y, Orita S, 2000. Enhancing effects of 2-amino-4,5-diphenylthiazole-induced polycystic kidneys on renal carcinogenesis in rats treated with dimethylnitrosamine. Toxicol Appl Pharmacol 167(1):12–17. 10.1006/taap.2000.8983.10936074
Takashima R, Takasawa H, Kawasako K, 2015. Evaluation of a repeated dose liver micronucleus assay in rats treated with two genotoxic hepatocarcinogens, dimethylnitrosamine and 2-acetylaminofluorene: the possibility of integrating micronucleus tests with multiple tissues into a repeated dose general toxicity study. Mutat Res Genet Toxicol Environ Mutagen 780–781:18–24. 10.1016/j.mrgentox.2014.10.007.
Takayama S, Oota K. 1965. Induction of malignant tumors in various strains of mice by oral administration of N-nitrosodimethylamine and N-nitrosodiethylamine. Gann 56:189–199.14321933
Tan S, Jiang S, Lai Y, 2019. Formation potential of nine nitrosamines from polyacrylamide during chloramination. Sci Total Environ 670:1103–1110. 10.1016/j.scitotenv.2019.03.281.31018426
Tate RL, Alexander M. 1975. Stability of nitrosamines in samples of lake water, soil, and sewage. J Natl Cancer Inst 54(2):327–330.234536
Tates AD, Neuteboom I, Hofker M. 1980. A micronucleus technique for detecting clastogenic effects of mutagens/carcinogens (DEN, DMN) in hepatocytes of rat liver in vivo. Mutat Res 74(1):11–20. 10.1016/0165-1161(80)90187-9.7360154
Terao K, Aikawa T, Kera K. 1978. A synergistic effect of nitrosodimethylamine on sterigmatocystin carcinogenesis in rats. Food Cosmet Toxicol 16(6):591–596. 10.1016/s0015-6264(78)80228-4.215497
Terracini B, Palestro G, Gigliardi MR, 1966. Carcinogenicity of dimethylnitrosamine in Swiss mice. Br J Cancer 20(4):871–876. 10.1038/bjc.1966.100.4290203
Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book, Co., 15–27.
Tinwell H, Lefevre PA, Ashby J. 1994a. Mutation studies with dimethyl nitrosamine in young and old lac I transgenic mice. Mutat Res 307(2):501–508. 10.1016/0027-5107(94)90261-5.7514724
Tinwell H, Lefevre PA, Ashby J. 1994b. Response of the Muta mouse lacZ/galE- transgenic mutation assay to DMN: comparisons with the corresponding Big Blue (lacI) responses. Mutat Res 307(1):169–173. 10.1016/0027-5107(94)90289-5.7513794
Tinwell H, Lefevre PA, Ashby J. 1998. Relative activities of methyl methanesulphonate (MMS) as a genotoxin, clastogen and gene mutagen to the liver and bone marrow of MutaMouse mice. Environ Mol Mutagen 32(2):163–172.9776179
Tinwell H, Liegibel U, Krebs O, 1995. Comparison of lacI and lacZ transgenic mouse mutation assays: an EU-sponsored interlaboratory study. Mutat Res 335(2):185–190. 10.1016/0165-1161(95)90054-3.7477049
Tomkins DJ, Kwok SE, Douglas GR, 1982. Sister chromatid exchange response of human diploid fibroblasts and Chinese hamster ovary cells to dimethylnitrosamine and benzo(a)pyrene. Environ Mutagen 4(3):203–214. 10.1002/em.2860040302.6284499
Tricker AR, Spiegelhalder B, Preussman R. 1989. Environmental exposure to preformed nitroso compounds. Cancer Surv 8(2):251–272.2696580
Tricker AR, Ditrich C, Preussmann R. 1991. N nitroso compounds in cigarette tobacco and their occurrence in mainstream tobacco smoke. Carcinogenesis 12(2):257–261.1995191
Trzos RJ, Petzold GL, Brunden MN, 1978. The evaluation of sixteen carcinogens in the rat using the micronucleus test. Mutat Res 58(1):79–86. 10.1016/0165-1218(78)90097-6.362195
Tsuda S, Murakami M, Matsusaka N, 2001. DNA damage induced by red food dyes orally administered to pregnant and male mice. Toxicol Sci 61(1):92–99. 10.1093/toxsci/61.1.92.11294979
Tsutsumi T, Akiyama H, Demizu Y, 2019. Analysis of an impurity, N-nitrosodimethylamine, in valsartan drug substances and associated products using GC-MS. Biol Pharm Bull 42(4):547–551. 10.1248/bpb.b19-00006.30726781
Tuazon EC, Carter WP, Atkinson R, 1984. Atmospheric reactions of N-nitrosodimethylamine and dimethylnitramine. Environ Sci Technol 18(1):49–54. 10.1021/es00119a011.22299842
Uhl M, Helma C, Knasmuller S. 1999. Single-cell gel electrophoresis assays with human-derived hepatoma (Hep G2) cells. Mutat Res 441(2):215–224. 10.1016/s1383-5718(99)00050-9.10333535
Uibu J, Tauts O, Levin A, 1996. N-nitrosodimethylamine, nitrate and nitrate-reducing microorganisms in human milk. Acta Paediatr 85(10):1140–1142.8922070
Ungar H. 1984. Primary portal venopathy in the golden hamster treated with low doses of dimethylnitrosamine. Liver 4(4):244–254. 10.1111/j.1600-0676.1984.tb00934.x.6482685
Ungar H. 1986. Venoocclusive disease of the liver and phlebectatic peliosis in the golden hamster exposed to dimethylnitrosamine. Pathol Res Pract 181(2):180–187. 10.1016/S0344-0338(86)80008-5.3737474
Vaidya R, Wilson CA, Salazar-Benites G, 2021. Factors affecting removal of NDMA in an ozone-biofiltration process for water reuse. Chemosphere 264(Pt 1):128333. 10.1016/j.chemosphere.2020.128333.33011478
Valentin-Severin I, Le Hegarat L, Lhuguenot JC, 2003. Use of HepG2 cell line for direct or indirect mutagens screening: comparative investigation between comet and micronucleus assays. Mutat Res 536(1–2):79–90. 10.1016/s1383-5718(03)00031-7.12694748
van Breda SG, Mathijs K, Sági-Kiss V, 2019. Impact of high drinking water nitrate levels on the endogenous formation of apparent N-nitroso compounds in combination with meat intake in healthy volunteers. Environ Health 18(1):87. 10.1186/s12940-019-0525-z.31623611
Van Huy N, Murakami M, Sakai H, 2011. Occurrence and formation potential of N-nitrosodimethylamine in ground water and river water in Tokyo. Water Res 45(11):3369–3377. 10.1016/j.watres.2011.03.053.21514620
Veid J, Karttunen V, Myohanen K, 2011. Acute effects of ethanol on the transfer of nicotine and two dietary carcinogens in human placental perfusion. Toxicol Lett 205(3):257–264. 10.1016/j.toxlet.2011.06.014.21704686
Venkatesan AK, Pycke BF, Halden RU. 2014. Detection and occurrence of N-nitrosamines in archived biosolids from the targeted national sewage sludge survey of the U.S. Environmental Protection Agency. Environ Sci Technol 48(9):5085–5092. 10.1021/es5001352.24697330
Vermeer IT, Pachen DM, Dallinga JW, 1998. Volatile N-nitrosamine formation after intake of nitrate at the ADI level in combination with an amine-rich diet. Environ Health Perspect 106(8):459–463. 10.1289/ehp.106-1533225.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver. Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483. 10.1111/j.1432-1033.1996.0476z.x.8681961
Vogel EW, Barbin A, Nivard MJ, 1990. Nucleophilic selectivity of alkylating agents and their hypermutability in Drosophila as predictors of carcinogenic potency in rodents. Carcinogenesis 11(12):2211–2217. 10.1093/carcin/11.12.2211.2265471
Wade GG, Mandel R, Ryser HJ. 1987. Marked synergism of dimethylnitrosamine carcinogenesis in rats exposed to cadmium. Cancer Res 47(24 Pt 1):6606–6613.3677096
Wagner ED, Osiol J, Mitch WA, 2014. Comparative in vitro toxicity of nitrosamines and nitramines associated with amine-based carbon capture and storage. Environ Sci Technol 48(14):8203–8211. 10.1021/es5018009.24940705
Wang HY, Qin M, Dong L, 2017. Genotoxicity of a low-dose nitrosamine mixture as drinking water disinfection byproducts in NIN3T3 cells. Int J Med Sci 14(10):961–969. 10.7150/ijms.20121.28924367
Waynforth HB, Magee PN. 1974. The effect of N-nitroso-N-methylurea and N-dimethylnitrosamine on cell mediated and humoral immune responses in rats and mice. Br J Cancer 30(6):512–523. 10.1038/bjc.1974.230.4614857
Weast RC. 1983. Dimethyl amine N-nitroso or Dimethylnitrsoamine. In: CRC handbook of chemistry and physics. 64th ed. Boca Raton, FL: CRC Press, C-270.
Webster RP, Gawde MD, Bhattacharya RK. 1996. Protective effect of rutin, a flavonol glycoside, on the carcinogen-induced DNA damage and repair enzymes in rats. Cancer Lett 109(1–2):185–191.9020919
White CM. 2020. Understanding and preventing (N-nitrosodimethylamine) NDMA contamination of medications. Ann Pharmacother 54(6):611–614. 10.1177/1060028019892222.31771343
WHO. 2002. Concise international chemical assessment document: N-Nitrosodimethylamine. World Health Organization. CICAD 38. https://www.who.int/ipcs/publications/cicad/en/cicad38.pdf?ua=1. April 17, 2020.
WHO. 2008. N-Nitrosodimethylamine (NDMA). Guidelines for drinking-water quality. World Health Organization. https://www.who.int/water_sanitation_health/dwq/chemicals/ndmasummary_2ndadd.pdf. April 15, 2020.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wild D. 1978. Cytogenetic effects in the mouse of 17 chemical mutagens and carcinogens evaluated by the micronucleus test. Mutat Res 56(3):319–327. 10.1016/0027-5107(78)90200-2.342949
Windholz M. 1983. N-Nitrosodimethylamine. In: The Merck index. 10th ed. Rahway, NJ: Merck and Co, Inc., 952, 864, 1387-1388.
Winton DJ, Gooderham NJ, Boobis AR, 1990. Mutagenesis of mouse intestine in vivo using the Dlb-1 specific locus test: studies with 1,2-dimethylhydrazine, dimethylnitrosamine, and the dietary mutagen 2-amino-3,8-dimethylimidazo[4,5-f]quinoxaline. Cancer Res 50(24):7992–7996.2253241
Wishnok JS, Rogers AE, Sanchez O, 1978. Dietary effects on the pharmacokinetics of three carcinogenic nitrosamines. Toxicol Appl Pharmacol 43(2):391–398. 10.1016/0041-008x(78)90018-2.76347
Wishnok JS, Tannenbaum SR, Fox JG, 1987. The ferret as a model for endogenous synthesis and metabolism of N-nitrosamines. IARC Sci Publ 84:135–137.
Wolf T, Niehaus-Rolf C, Luepke NP. 2003. Investigating genotoxic and hematotoxic effects of N-nitrosodimethylamine, N-nitrosodiethylamine and N-nitrosodiethanolamine in the hen's egg-micronucleus test (HET-MN). Food Chem Toxicol 41(4):561–573. 10.1016/s0278-6915(02)00281-8.12615129
Woodruff RC, Seeger MA. 1991. Test of a semiselective screen for induced aneuploidy in germ cells of Drosophila melanogaster females with structurally normal chromosomes. Mutat Res 252(1):61–82. 10.1016/0165-1161(91)90252-4.1899913
WQP. 2022. Water quality portal: N-Nitroso-dimethylamine. National Water Quality Monitoring Council. https://www.waterqualitydata.us/. July 22, 2022.
Yamane Y, Sakai K, Umeda T, 1984. Suppressive effect of cupric acetate on DNA alkylation, DNA synthesis and tumorigenesis in the liver of dimethylnitrosamine-treated rats. Gann 75(12):1062–1069.6526221
Yang CS, Tu YY, Koop DR, 1985. Metabolism of nitrosamines by purified rabbit liver cytochrome P-450 isozymes. Cancer Res 45(3):1140–1145.3971365
Yang CS, Yoo JS, Ishizaki H, 1990. Cytochrome P450IIe1: roles in nitrosamine metabolism and mechanisms of regulation. Drug Metab Rev 22(2–3):147–159. 10.3109/03602539009041082.2272285
Yang J, Marzan TA, Ye W, 2020. A cautionary tale: Quantitative KC-HRMS analytical procedures for the analysis of N-nitrosodimethylamine in metformin. AAPS J 22(4):89. 10.1208/s12248-020-00473-w.32613429
Yoo JS, Guengerich FP, Yang CS. 1988. Metabolism of N-nitrosodialkylamines by human liver microsomes. Cancer Res 48(6):1499–1504.3345523
Yoo JS, Ishizaki H, Yang CS. 1990. Roles of cytochrome P450IIE1 in the dealkylation and denitrosation of N-nitrosodimethylamine and N-nitrosodiethylamine in rat liver microsomes. Carcinogenesis 11(12):2239–2243. 10.1093/carcin/11.12.2239.2265475
Yoo JS, Ning SM, Patten CJ, 1987. Metabolism and activation of N-nitrosodimethylamine by hamster and rat microsomes: comparative study with weanling and adult animals. Cancer Res 47(4):992–998.3802105
Yoon HJ, Kim JH, Seo GH, 2021. Risk of cancer following the use of n-nitrosodimethylamine (NDMA) contaminated ranitidine products: A nationwide cohort study in South Korea. J Clin Med 10(1):153. 10.3390/jcm10010153.33466237
Zeng T, Li RJ, Mitch WA. 2016. Structural modifications to quaternary ammonium polymer coagulants to inhibit N-nitrosamine formation. Environ Sci Technol 50(9):4778–4787. 10.1021/acs.est.6b00602.27096602
Zheng J, Stuff J, Tang H, 2019. Dietary N-nitroso compounds and risk of pancreatic cancer: results from a large case-control study. Carcinogenesis 40(2):254–262. 10.1093/carcin/bgy169.30475991
Zheng J, Daniel CR, Hatia RI, 2021. Dietary N-nitroso compounds and risk of hepatocellular carcinoma: A USA-based study. Hepatology 74(6):3161–3173. 10.1002/hep.32046.34233041
Zhu Y, Wang PP, Zhao J, 2014. Dietary N-nitroso compounds and risk of colorectal cancer: a case-control study in Newfoundland and Labrador and Ontario, Canada. Br J Nutr 111(6):1109–1117. 10.1017/S0007114513003462.24160559
Zmysłowski A, Książek I, Szterk A. 2020. N-nitrosodimethylamine contamination in the metformin finished products. Molecules 25(22):5304. 10.3390/molecules25225304.33202951