# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Custodio Muianga, M.P.H., Ph.D., C.H.M.M. (Lead)
  Nickolette Roney, M.P.H.
  Jennifer Przybyla, Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Heather Carlson-Lynch, M.S., D.A.B.T.
  Mario Citra, Ph.D.
  Claire Heit, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  - Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  - ATSDR, Office of Community Health and Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA/Center for Public Health and Environmental Assessment (CPHEA); EPA/Office of Water (OW).

## PEER REVIEWERS

1. Paul Westerhoff; Regents Professor; School of Sustainable Engineering and the Built Environment; Arizona State University; Tempe, Arizona
2. Steve Hrudey; Ph.D. Professor Emeritus; Department of Laboratory Medicine and Pathology; University of Alberta; Edmonton, Alberta, Canada
3. David Eastmond; Professor and Toxicologist; Department of Molecular Cell and Systems Biology; University of California Riverside; Riverside, California

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile's final content. The responsibility for the content of this profile lies with ATSDR.