# VERSION HISTORY

Date | Description
April 2023 | Final toxicological profile released
January 2022 | Draft for public comment toxicological profile released
December 1989 | Final toxicological profile released