# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of NDMA are listed in Table 4-1.

Table 4-1 Chemical Identity of N-Nitrosodimethylamine

Characteristic | Information | Reference
Chemical name | Methanamine, N-methyl-N-nitroso | O'Neil 2013
Synonym(s) and registered trade name(s) | N-Nitrosodimethylamine; dimethylnitrosamine; DMNA; DMN; NDMA | O'Neil 2013
Chemical formula | C_2_H_6_N_2_O | O’Neil 2013
Chemical structure | (CH_3_)_2_N–N=O | O’Neil 2013
CAS Registry Number | 62-75-9 | O’Neil 2013

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of NDMA are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of N-Nitrosodimethylamine

Property | Information | Reference
Molecular weight | 74.08 | Weast 1983
Color | Yellow | IARC 1978
Physical state | Liquid | IARC 1978
Melting point | −25°C | Lyman 1985
Boiling point | 154°C | Weast 1983
Density at 20°C | 1.0059 (specific gravity, 20/4°C) | EPA 2014a
Odor | No distinct odor | Frank and Berry 1981
Odor threshold:
Water | Not available
Air | Not available
Solubility:
Water at 20°C | Miscible | Mirvish et al. 1976
Organic solvents | Soluble in alcohol, ether, other organic solvents | IARC 1978; Weast 1983
Partition coefficients:
Log K_ow_ | −0.57 | Hansch et al. 1995
Log K_oc_ | 1.07 (estimated using Equation 4–8) | Lyman 1982
Vapor pressure at 20°C | 2.7 mmHg | Klein 1982
Henry’s law constant | 1.99×^10–6^ atm-m^3^/mol at 37°C; 2.63×^10−7^ atm-m^3^/mol at 20°C (estimated using vapor pressure and water solubility data); 2.24×^10−6^ atm-m^3^/mol at 25°C | Haruta et al. 2011; Mirvish et al. 1976
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | ppm (v/v)×3.08=mg/m^3^ mg/m^3^×0.325=ppm (v/v)