# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals. Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102–1, Atlanta, Georgia 30329–4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodimethylamine
CAS Numbers: | 62-75-9
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: The acute-duration inhalation data were not considered adequate for derivation of an acute-duration inhalation MRL for NDMA.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. Available animal data consist of acute lethality studies in rats, mice, and dogs exposed once for 4 hours (all reported by Jacobson et al. 1955). These authors reported LC50 values of 57 ppm in mice and 78 ppm in rats; in dogs, the lowest concentration tested (16 ppm) was lethal to two of three exposed animals. These data are not adequate for derivation of an acute-duration inhalation MRL.

Agency Contacts (Chemical Managers): Custodio Muianga, PhD, MPH, CHMM

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodimethylamine
CAS Numbers: | 62-75-9
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: The intermediate-duration inhalation data were not considered adequate for derivation of an intermediate-duration inhalation MRL for NDMA.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Custodio Muianga, PhD, MPH, CHMM

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodimethylamine
CAS Numbers: | 62-75-9
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: The chronic-duration inhalation data were not considered adequate for derivation of a chronic-duration inhalation MRL for NDMA.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. Three chronic inhalation cancer bioassays in rats (Druckrey et al. 1967; Klein et al. 1989, 1991; Moiseev and Benemanski 1975) and one in mice (Moiseev and Benemanski 1975) are available, but the only nonneoplastic endpoints evaluated (by Klein et al. [1989, 1991] only) were survival and body weight, so these data were not adequate for MRL derivation.

Agency Contacts (Chemical Managers): Custodio Muianga, PhD, MPH, CHMM

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodimethylamine
CAS Numbers: | 62-75-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.00001 (1×10^−5^) mg/kg/day (0.01 μg/kg/day)
Critical Effect: | Liver effect causing decreased total blood iron binding capacity
References: | Moniuszko-Jakoniuk et al. 1999; Roszczenko et al. 1996a, 1996b
Point of Departure: | BMDL_1SD_ of 0.0014 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 18
Species: | Rat

MRL Summary: An oral MRL of 0.00001 (1×10^−5^) mg/kg/day (0.01 µg/kg/day) was derived based on the 95% lower confidence limit of a benchmark dose (BMDL_1SD_) of 0.0014 mg/kg/day for a liver effect resulting in decreased total blood iron binding capacity in rats exposed to NDMA in drinking water for 10 days. An uncertainty factor (UF) of 100 (10 for animal to human and 10 for human variability) was applied to the BMDL to derive the acute-duration oral MRL.

Selection of the Critical Effect: No dose-response data are available for humans. Abundant data indicate that the liver is the most sensitive endpoint for toxic effects following oral exposure to NDMA after all durations. In every species tested (including rats, mice, hamsters, monkeys, dogs, cats, guinea pigs, and mink), oral exposure to NDMA induced severe damage to the liver (see, for example, Anderson et al. 1992a; Carter et al. 1969; Khanna and Puri 1966; Maduagwu and Bassir 1980; Nishie 1983; Ungar 1984). The liver effects, mediated by reactive metabolites of NDMA, are typically characterized by hemorrhagic necrosis, followed (if the animal survives) by fibrosis, cirrhosis, and portal hypertension. These effects have been seen after acute-, intermediate-, and chronic-duration exposures. Many of the studies of animals exposed orally to NDMA identified serious LOAELs for hepatic effects without NOAELs.

Table A-1 shows the studies reporting effects at the lowest oral doses in acute-duration studies. Effects observed at the lowest dose (0.0016–0.002 mg/kg/day) included altered iron parameters (Roszczenko et al. 1996b) and increased serum AST, ALT, ALP, and GGT (Roszczenko et al. 1996a). Thus, these studies indicate effects on the circulation of iron in the blood and concurrently on the liver. The liver plays an important role in maintaining iron levels (production of proteins that regulate iron; storage of excess iron; and mobilization of iron to systemic circulation as needed), and perturbations of iron circulation, with concomitant hematological abnormalities, frequently accompany liver disease (reviewed by Anderson and Shah 2013 and Gkamprela et al. 2017). NDMA treatment in dogs and rats has been used as a model for human liver fibrosis (and its sequelae of cirrhosis, portal hypertension, and hepatocellular carcinoma) for nearly 40 years. Hepatic effects have been observed in animals and humans after NDMA exposure. Therefore, it is possible that the decrements in iron binding parameters at the low doses used by Roszczenko et al. (1996b) are related to the early liver effects (increases in serum hepatic enzyme levels) observed at comparable doses in the study by Roszczenko et al. (1996a). Although data demonstrating a clear mechanistic linkage between the iron binding and hepatic changes are not available, it is clear that the decreases in iron circulation parameters are adverse: inadequate circulating iron in humans leads to symptoms of anemia including fatigue, weakness, and difficulty concentrating, as well as effects on growth and development in infants and children. Furthermore, the identification of a LOAEL at this dose (0.0016 mg/kg/day; Roszczenko et al. 1996b) is supported by the LOAEL for adverse hepatic effects at a comparable dose (0.002 mg/kg/day) (Roszczenko et al. 1996a).

Table A-1 Summary of Acute-Duration Oral Studies of N-Nitrosodimethylamine in Animals (Doses ≤5 mg/kg/day)

Species (Strain) | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
Rat (Wistar, male) | 10 days, 7 days/week (W) | 0.0007 | 0.0016 | Decreased serum total and latent iron binding capacity | Roszczenko et al. 1996b
Rat (Wistar, male) | 10 days, 7 days/week (W) | ND | 0.002 | Increased serum AST, ALT, ALP, and GGT (no other endpoints evaluated) | Roszczenko et al. 1996a
Rat (Wistar, male) | 10 days, 7 days/week (W) | 0.003 | ND | No changes in liver histopathology | Moniuszko-Jakoniuk et al. 1999
Rat (Crl:CD[SD], male) | 14 days, 7 days/week (GW) | ND | 1 | Inflammatory cell infiltration | Hamada et al. 2015; Takashima et al. 2015
Rat (strain NS) | Once (G) | 0.7 | 1.9 | Vacuolation | Korsrud et al. 1973
Mouse (Swiss-Webster) | 4 days (G) | ND | 3.75 | Hepatocellular hypertrophy | Nishie et al. 1972
Rat (strain NS) | 7–14 days (F) | ND | 3.75 (serious LOAEL) | Necrosis | Khanna and Puri 1966
Mouse (CD-1) | 14 days, 7 days/week (G) | ND | 4 | Increased serum ALT and AST | Doolittle et al. 1987
Hamster (Golden) | 1–14 days, 7 days/week (W) | ND | 4 | Increased serum ALT Ungar 1984 and AST
Rat (F344) | 14 days, 7 days/week (G) | ND | 4 (serious LOAEL) | Necrosis | Asakura et al. 1998
Other (death, cancer)
Mouse (A/JNCR) | Once (G) | ND | 5 (CEL) | Lung tumors at sacrifice 16 weeks after dosing | Anderson et al. 1992a
Cat (strain NS) | 5–11 days (G) | NA | 5 (serious LOAEL) | LD_50_ | Maduagwu and Bassir 1980
Monkey (strain NS) | 5–11 days (G) | NA | 5 (serious LOAEL) | LD_50_ | Maduagwu and Bassir 1980
Rat (strain NS) | 5–11 days (G) | NA | 5 (serious LOAEL) | LD_50_ | Maduagwu and Bassir 1980
Guinea pig (strain NS) | 5–11 days (G) | NA | 5 (serious LOAEL) | Death | Maduagwu and Bassir 1980

ALP = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartate aminotransferase; CEL = cancer effect level; (F) = feed; (G) = gavage; GGT= gamma-glutamyl transferase; (GW) = gavage in water; LD_50_ = medial lethal dose; LOAEL = lowest-observed-adverse-effect level; NA = not applicable; ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified; (W) = water

As Table A-1 shows, effect levels for the studies by Roszczenko et al. 1996 a, 1996b) and Moniuszko-Jakoniuk et al. (1999) were substantially lower than the remaining effect levels (≥1.9 mg/kg/day) (Korsrud et al. 1973); thus, these studies were considered for use in deriving the MRL.

Selection of the Principal Study: The lowest LOAEL was 0.0016 mg/kg/day for altered iron indices in the 10-day study by Roszczenko et al. (1996b); a NOAEL of 0.0007 mg/kg/day was identified for this study. A comparable LOAEL of 0.002 mg/kg/day was identified for increased serum AST, ALT, ALP, and GGT in a parallel single dose study by Roszczenko et al. (1996a). Moniuszko-Jakoniuk et al. (1999) was a multi-dose study for which a NOAEL of 0.003 mg/kg/day was identified for liver histology.

Both of the studies by Roszczenko et al. (1996a, 1996b) examined limited endpoints (serum enzyme and iron indices), and neither included organ weight or histopathology evaluation of the liver. The lack of histopathology data in these studies raises the question of whether the dose of 0.0016 mg/kg/day could be considered a serious LOAEL. However, this same group of investigators conducted a third study (Moniuszko-Jakoniuk et al. 1999) of comparable design in which histopathology was examined in the liver, spleen, and bone marrow. All three studies were conducted in male Wistar rats of approximately the same initial body weight (190–220 g), and in all studies, the rats were administered NDMA in drinking water at concentrations of 0.01–0.05 mg/L for 10 days. In the study by Moniuszko-Jakoniuk et al. (1999), a NOAEL of 0.003 mg/kg/day was identified, based on a lack of histopathology changes in the liver, bone marrow, and spleen after 10 days of exposure. The results of this study provide support for the conclusion that the LOAEL identified for Roszczenko et al. (1996b) is not a serious LOAEL.

Considering the data for the three studies together, Roszczenko et al. (1996b) was chosen as the principal study for the derivation of the acute-duration oral MRL. The study identified the lowest LOAEL, with a corresponding NOAEL. Support for the LOAEL and NOAEL determination for Roszczenko et al. (1996b) is provided by the other studies conducted by the same group of investigators (Moniuszko-Jakoniuk et al. 1999; Roszczenko et al. 1996a).

Summary of the Principal and Supporting Studies:

Roszczenko A, Jabloński J, Moniuszko-Jakoniuk J, 1996b. The influence of low doses of N-nitrosodimethylamine on the chosen parameters of iron balance in rat. Polish J Environ Studies 5(5):37–40.

Roszczenko et al. (1996b) administered NDMA in drinking water to groups of seven male Wistar rats for 10 days at concentrations of 10, 20, and 50 μg/L (0.01, 0.02, or 0.05 mg/L) in a study evaluating iron indices. Exposure concentrations were estimated by the study authors to result in doses of 0.0007, 0.0016, or 0.0035 mg/kg/day, respectively. The animals were sacrificed at the end of the 10-day exposure. Blood was collected for analysis of hematocrit and hemoglobin concentration. In addition, iron, latent iron binding capacity (portion of the plasma transferrin molecule that is not bound to iron), total iron binding capacity (maximum concentration of iron that can be bound to transferrin), and the percentage transferrin saturation were measured in serum. Iron concentrations in the liver and spleen were analyzed. At the lowest dose, no statistically significant effect on any measured parameter was observed. Significant increases in hemoglobin concentration were seen at doses ≥0.0016 mg/kg/day (8 and 15% at 0.0016 and 0.0035 mg/kg/day, respectively). Hematocrit was not significantly increased at any dose. Serum iron concentration was significantly decreased by 36% at the high dose. Significant decreases in total iron binding capacity^1^ were observed at doses ≥0.0016 mg/kg/day (18 and 30% at 0.0016 and 0.0035 mg/kg/day, respectively). Latent (unsaturated) iron binding capacity was significantly decreased by 42% at 0.0016 mg/kg/day, but there was no significant difference at 0.0035 mg/kg/day. There was no significant change in the percent transferrin saturation, despite values that decreased with dose (7% decrease at 0.0016 mg/kg/day and 14% decrease at 0.0035 mg/kg/day). After 10 days of exposure, there were no significant differences in the iron content of the liver or spleen. A NOAEL of 0.0007 mg/kg/day and a LOAEL of 0.0016 mg/kg/day were identified for this study based on the decreases in total and latent (unsaturated) iron binding capacity.

Roszczenko A, Jablonski J, Moniuszko-Jakoniuk J. 1996a. [Effect of n-nitrosodimethylamine (NDMA) on activity of selected enzymes in blood serum of the rat (translation and original document)]. Med Pr 47(1):49–53 (Polish).8834597

Roszczenko et al. (1996a) administered NDMA in drinking water at a concentration of 20 μg/L (0.02 mg/L) to groups of seven male Wistar rats for 10 days, yielding a dose estimated by the authors to be 0.002 mg/kg/day. The only endpoints measured were serum enzymes (AST, ALT, ALP, and GGT) assessed at the end of exposure. Statistically significant increases of ≥2-fold (compared with controls) in all four enzymes were observed: serum AST, ALT, and ALP were doubled, and a 6-fold increase in GGT was measured.

Moniuszko-Jakoniuk J, Roszczenko A, Dzieciol J. 1999. Influence of low concentrations of N-nitrosodimethylamine on the iron level and histopathological picture of rats liver, spleen, and bone marrow. Acta Poloniae Toxicologica 7(2):179–186 .

In the study by Moniuszko-Jakoniuk et al. (1999) groups of eight male Wistar rats were exposed to NDMA concentrations of 30 or 45 μg/L (0.03 or 0.045 mg/L) in drinking water for 10 days. The study authors did not estimate doses; based on the ratio of dose to concentration (0.0035 mg/kg/day for 0.05 mg/L) reported by Roszczenko et al. (1996b), the concentrations in the Moniuszko-Jakoniuk et al. (1999) study (0.03 and 0.045 mg/L) were estimated to result in doses of approximately 0.002 and 0.003 mg/kg/day, respectively. The control group (n=24) received drinking water without added NDMA. When sacrificed at the end of the exposure period, iron content of the liver and spleen was measured, and histopathology was evaluated in the liver, bone marrow, and spleen. There was no effect on the iron content of the liver or spleen, and there were no histopathological changes observed in the liver, bone marrow, or spleen in either dose group after 10 days of exposure.

Selection of the Point of Departure for the MRL: BMD modeling was performed for each of the iron indices evaluated by Roszczenko et al. (1996b), as shown in Table A-2.

Table A-2 Changes in Iron Indices in Male Wistar Rats Following Exposure to N-Nitrosodimethylamine in Drinking Water for 10 Days

| Exposure dose (mg/kg/day)
| 0 | 0.0007 | 0.0016 | 0.0035
Number of animals | 7 | 7 | 7 | 7
Total iron binding capacity (μmol/L) | 138.94±22.74 | 120.13±10.04 (−14%) | 114.12±13.97^b^ (−18%) | 96.94±4.93^c^ (−30%)
Hematocrit (%) | 26.27±1.65^a^ | 26.1±1.21 (−1%) | 27.31±1.58 (4%) | 27.3±2.34 (4%)
Hemoglobin (g/L) | 11.91±0.73 | 13.01±1.02 (9%) | 12.88±0.74^b^ (8%) | 13.69±1.27^b^ (15%)
Latent iron binding capacity (μmol/L) | 100.62±17.56 | 101.26±10.02 (1%) | 57.93±7.28^b^ (−42%) | 87.14±6.86 (−13%)
Percent transferrin saturation (%) | 47.34±6.05 | 51.16±7.62 (8%) | 43.83±6.94 (−7%) | 40.52±5.90 (−14%)
Serum iron (μmol/L) | 65.88±10.05 | 66.78±8.09 (1%) | 59.21±6.59 (−10%) | 41.95±2.41^b^ (−36%)

a Mean±standard deviation.

b Statistically significantly (p<0.05) different from controls.

c Statistically significantly (p<0.001) different from controls.

Source: Roszczenko et al. 1996b

The data for iron indices shown in Table A-2 were fit to continuous models in EPA’s Benchmark Dose Software (BMDS; version 3.1.2) using a benchmark response (BMR) of 1 standard deviation. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the point of departure (POD) when the difference between the BMDLs estimated from these models was ≥3 fold; otherwise, the BMDL from the model with the lowest Akaike Information Criterion (AIC) was chosen. All continuous models were applied to the data and considered for the derivation of a POD except for the Hill model; the continuous Hill model has five parameters and requires a dataset with a minimum of six datapoints (including control).

For latent iron binding capacity (µmol/L), none of the models provided an adequate fit to the variance data with or without the variance model applied.

For total iron binding capacity, constant variance models did not provide adequate fit to the variance data. With the non-constant variance applied, all applicable models provided adequate fit to both the variance and the means for total iron binding capacity. Visual inspection of the dose-response curves suggested adequate fit, BMDLs were not 10 times lower than the lowest non-zero dose, and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear). The Polynomial models and Power model converged on the form of the linear model. The Linear model estimated a BMD_1SD_ and BMDL_1SD_ of 0.0021 and 0.0014 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-3.

Table A-3 Model Predictions (Non-Constant Variance) for Total Iron Binding Capacity (μmol/L) in Male Wistar Rats Following Exposure to N-Nitrosodimethylamine in Drinking Water for 10 Days (Roszczenko et al. 1996b)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 0.0014 | 0.0010 | 0.14 | 223.62 | −0.23 | 0.69
Exponential (model 3)^d^ | 0.0014 | 0.0010 | 0.14 | 223.62 | −0.23 | 0.69
Exponential (model 4)^d^ | 0.0010 | 0.0006 | 0.10 | 224.73 | −0.90 | 0.18
Exponential (model 5)^d^ | 0.0010 | 0.0006 | 0.10 | 224.74 | −0.88 | 0.24
Polynomial (3-degree)^e^ | 0.0021 | 0.0014 | 0.21 | 223.28 | −0.31 | 1.03
Polynomial (2-degree)^e^ | 0.0021 | 0.0014 | 0.21 | 223.28 | −0.31 | 1.03
Power^d^ | 0.0021 | 0.0014 | 0.21 | 223.28 | −0.31 | 1.03
Linear ^e,f^ | 0.0021 | 0.0014 | 0.21 | 223.28 | −0.31 | 1.03

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMD.

d Power restricted to ≥1.

e Coefficients restricted to be negative.

f Selected model. Constant variance models did not provide adequate fit to the variance data. With non-constant variance model applied, all models provided adequate fit to the means. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC is selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure concentration associated with a one standard deviation change in outcome from control mean)

For hematocrit, constant variance models provided adequate fit to the variance data; however, the upper bound on the benchmark dose (BMDU) was infinite (unbounded) for all models. With the non-constant variance applied, all applicable models provided adequate fit to both the variance and the means. The BMDUs for the Exponential 2, Exponential 3, Exponential 4, and Power models could not be determined (infinity); therefore, these models were not considered. The BMD computation failed for the Exponential 5 model; therefore, the BMD and BMDL could not be estimated. Visual inspection of the remaining dose-response curves suggested adequate fit, BMDLs were not 10 times lower than the lowest non-zero dose, and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for the remaining models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear). The BMD of the selected model was slightly higher (0.0036 mg/kg/day) than the maximum dose tested (0.0035 mg/kg/day). The Linear model estimated a BMD_1SD_ and BMDL_1SD_ of 0.0036 and 0.0015 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-4.

Table A-4 Model Predictions (Non-Constant Variance) for Hematocrit (%) in Male Wistar Rats Following Exposure to N-Nitrosodimethylamine in Drinking Water for 10 Days (Roszczenko et al. 1996b)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | | | 0.50 | 112.44 | −0.46 | 0.20
Exponential (model 3)^d^ | | | 0.50 | 112.44 | −0.46 | 0.20
Exponential (model 4)^d^ | | | 0.32 | 114.38 | −0.38 | 0.31
Exponential (model 5)^d^ | | | 0.26 | 115.35 | −9999 | 0.23
Polynomial (3-degree)^e^ | 0.0035 | 0.0015 | 0.22 | 115.62 | −0.33 | 0.09
Polynomial (2-degree)^e^ | 0.0036 | 0.0015 | 0.22 | 115.62 | −0.29 | 0.05
Power^d^ | | | 0.23 | 115.56 | −0.33 | 0.01
Linear ^e,f^ | 0.0036 | 0.0015 | 0.46 | 113.63 | −0.28 | 0.12

a BMD and BMDL values for models that do not provide adequate fit, for models that failed to calculate BMDLs, and for models with infinite BMDUs are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMD.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. Constant variance models provided adequate fit to the variance data; however, the BMDU was infinity for all models. With the non-constant variance applied, all applicable models provided adequate fit to both the variance and the means. The BMD computation failed for the Exponential 5 model; therefore, the BMD and BMDL could not be estimated. The BMDUs for the Exponential 2, Exponential 3, Exponential 4, and Power models could not be determined (infinity); therefore, these models were not selected. BMDLs for the remaining models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure concentration associated with a one standard deviation change in outcome from control mean); BMDU = upper bound on the BMD

For hemoglobin, all applicable constant variance models provided adequate fit to the variance data. The BMDU for the Exponential 4 and 5 models could not be determined (infinity) so these models were not selected. Visual inspection of the remaining dose-response curves suggested adequate fit, BMDLs were not 10 times lower than the lowest non-zero dose, and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for the remaining models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear). The Polynomial 2-degree, polynomial 3-degree and power models converged on the form of the linear model. The Linear model estimated a BMD_1SD_ and a BMDL_1SD_ of 0.0022 and 0.0014 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-5.

Table A-5 Model Predictions (Constant Variance) for Hemoglobin Concentration (g/L) in Male Wistar Rats Following Exposure to N-Nitrosodimethylamine in Drinking Water for 10 Days (Roszczenko et al. 1996b)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 0.0023 | 0.0015 | 0.24 | 82.08 | −0.12 | −0.99
Exponential (model 3)^d^ | 0.0023 | 0.0015 | 0.24 | 82.08 | −0.12 | −0.99
Exponential (model 4)^d^ | | | 0.18 | 83.04 | 0.87 | −0.26
Exponential (model 5)^d^ | | | 0.18 | 83.04 | 0.87 | −0.26
Polynomial (3-degree)^e^ | 0.0022 | 0.0014 | 0.25 | 81.99 | −0.16 | −0.95
Polynomial (2-degree)^e^ | 0.0022 | 0.0014 | 0.25 | 81.99 | −0.16 | −0.95
Power^d^ | 0.0022 | 0.0014 | 0.25 | 81.99 | −0.16 | −0.95
Linear ^e,f^ | 0.0022 | 0.0014 | 0.25 | 81.99 | −0.16 | −0.95

a BMD and BMDL values for models that do not provide adequate fit and for models with infinite BMDUs are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMD.

d Power restricted to ≥1.

e Coefficients restricted to be positive.

f Selected model. Constant variance models provided adequate fit to the variance data. The 95% upper bounds for the Exponential 4 and 5 models were infinity. BMDLs for the remaining models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear). The Polynomial 2-degree, polynomial 3-degree and power models converged on the form of the linear model. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold), so the model with the lowest AIC is selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure concentration associated with a one standard deviation change in outcome from control mean); BMDU = upper bound on the BMD

For percent transferrin saturation, all applicable constant variance models provided adequate fit to the variance data. Only the Exponential 2 and Linear models provided adequate fit to the means. Visual inspection of the dose-response curves for these models suggested adequate fit, BMDLs were not 10 times lower than the lowest non-zero dose, and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for the adequately fit models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear). The Linear model estimated a BMD_1SD_ and a BMDL_1SD_ of 0.0026 and 0.0016 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-6.

Table A-6 Model Predictions (Constant Variance) for Percent Transferrin Saturation in Male Wistar Rats Following Exposure to N-Nitrosodimethylamine in Drinking Water for 10 Days (Roszczenko et al. 1996b)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 0.0025 | 0.0014 | 0.19 | 190.72 | −0.56 | −0.85
Exponential (model 3)^d^ | | | 0.09 | 192.32 | 0.16 | −0.62
Exponential (model 4)^d^ | | | 0.07 | 192.72 | −0.56 | −0.85
Exponential (model 5)^d^ | | | NA | 192.67 | 0.00 | −0.80
Polynomial (3-degree)^e^ | | | 0.08 | 192.52 | 0.13 | −0.61
Polynomial (2-degree)^e^ | | | 0.08 | 192.52 | 0.13 | −0.61
Power^d^ | | | 0.08 | 192.37 | 0.15 | −0.61
Linear ^e,f^ | 0.0026 | 0.0016 | 0.19 | 190.66 | −0.01 | −0.82

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMD.

d Power restricted to ≥1.

e Coefficients restricted to be negative.

f Selected model. Constant variance models provided adequate fit to the variance data. Only the Exponential 2 and Linear models provided an adequate fit to the means. BMDLs for the adequately fit models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure concentration associated with a one standard deviation change in outcome from control mean)

For serum iron concentration (µmol/L), constant variance models did not provide adequate fit to the variance data. With the non-constant variance applied, all applicable models provided adequate fit to both the variance and the means, except for the Exponential 4 and 3-degree polynomial models. Visual inspection of the dose-response curves suggested adequate fit, BMDLs were not 10 times lower than the lowest non-zero dose, and scaled residuals did not exceed ±2 units at the data point closest to the predefined BMR. BMDLs for the adequately fit models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential 3). The Exponential 3 model estimated a BMD_1SD_ and a BMDL_1SD_ of 0.0017 and 0.0011 mg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-7.

Table A-7 Predictions (Non-Constant Variance) for Serum Iron Concentration (μmol/L) in Male Wistar Rats Following Exposure to N-Nitrosodimethylamine in Drinking Water for 10 Days (Roszczenko et al. 1996b)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-Value^b^ | AIC | Dose near BMD | Dose near control
Exponential (model 2)^d^ | 0.0011 | 0.0008 | 0.18 | 186.63 | 0.54 | −1.58
Exponential (model 3) ^d,e^ | 0.0017 | 0.0011 | 0.85 | 184.13 | −0.16 | −0.44
Exponential (model 4)^d^ | | | 0.09 | 188.63 | 0.53 | −1.60
Exponential (model 5)^d^ | 0.0017 | 0.0011 | 0.72 | 185.92 | −0.01 | −0.24
Polynomial (3-degree)^f^ | | | NA | 188.36 | −0.25 | −0.50
Polynomial (2-degree)^f^ | 0.0018 | 0.0011 | 0.54 | 186.17 | −0.24 | −0.40
Power^d^ | 0.0018 | 0.0011 | 0.61 | 186.04 | −0.18 | −0.39
Linear^f^ | 0.0013 | 0.0009 | 0.31 | 186.15 | 0.69 | −1.25

a BMD and BMDL values for models that do not provide adequate fit are not included in the table.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at concentrations immediately below and above the BMD.

d Power restricted to ≥1.

e Selected model. Constant variance models did not provide adequate fit to the variance data. With the non-constant variance applied, all applicable models provided adequate fit to both the variance and the means, except for the Exponential 4 and 3-degree polynomial models. BMDLs for the adequately fit models were sufficiently close (differed by <3-fold), so the model with the lowest AIC was selected (Exponential 3).

f Coefficients restricted to be negative.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure concentration associated with a one standard deviation change in outcome from control mean)

Table A-8 summarizes the potential candidate PODs for the acute-duration oral MRL for NDMA. The BMDL values were similar among the candidate endpoints (0.0011–0.0016 mg/kg/day). The BMDL_1SD_ value of 0.0014 mg/kg/day for decreased total iron binding capacity was selected as the critical effect following acute-duration oral exposure to NDMA, as it is the most sensitive effect showing a monotonic change (Table A-2). Modeling results for the other candidate endpoints provide strong support for the selected POD. The Linear model fit to the total iron binding capacity data is presented in Figure A-1.

Table A-8 Candidate Points of Departure for the Acute-Duration Oral MRL

Endpoint | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ mg/kg/day)
Total iron binding capacity | | | 0.0021 | 0.0014
Percent hematocrit | | | 0.0036 | 0.0015
Hemoglobin | | | 0.0022 | 0.0014
Latent iron binding capacity | 0.0007 | 0.0016 | No model fit
Percent transferrin saturation | | | 0.0026 | 0.0016
Serum iron | | | 0.0017 | 0.0011

BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; SD = standard deviation

Figure A-1 Fit of Linear Model (Non-constant Variance) to Total Iron Binding Capacity (µmol/L) in Male Wistar Rats Following Exposure to N-Nitrosodimethylamine in Drinking Water for 10 Days (Roszczenko et al. 1996b)

Uncertainty Factor: The BMDL_1SD_ was divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_1 SD_ ÷ (UF) 0.0014 mg / kg / day ÷ (10 × 10) ≈ 0.00001 mg / kg / day (1 × 10^− 10^ mg / kg / day)

Other Additional Studies or Pertinent Information that Lend Support to this: As discussed above, the studies by Roszczenko et al. (1996a) and Moniuszko-Jakoniuk et al. (1999) provide support for the effect level determinations by Roszczenko et al. (1996b). Examples of other studies that demonstrate liver toxicity, often severe, after oral exposure to higher doses of NDMA in rats, mice, hamsters, monkeys, dogs, cats, guinea pigs, and mink include: Anderson et al. (1992a); Carter et al. (1969); Hamada et al. 2015; Khanna and Puri (1966); Maduagwu and Bassir (1980); Nishie (1983); Takashima et al. 2015; and Ungar (1984).

Agency Contacts (Chemical Managers): Custodio Muianga, PhD, MPH, CHMM

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodimethylamine
CAS Numbers: | 62-75-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: The intermediate-duration oral data were not considered adequate for derivation of an intermediate-duration oral MRL for NDMA.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Table A-9 summarizes results from candidate intermediate-duration oral studies in laboratory animals.

Table A-9 Summary of Intermediate-Duration Oral Studies of N-Nitrosodimethylamine in Animals (Doses ≤1.5 mg/kg/day)

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
Rat (Wistar, male) | 30 or 90 days, 7 days/week (W) | ND | 0.0016 (severity unknown) | Altered iron indices after 30 days | Roszczenko et al. 1996b
Rat (Wistar, male) | 30 or 90 days, 7 days/week (W) | ND | 0.002 (severity unknown) | Increased serum AST, ALT, ALP, and GGT after 30 days | Roszczenko et al. 1996a
Rat (Wistar, male) | 30 or 90 days, 7 days/week (W) | ND | 0.002 (serious LOAEL) | Degeneration, argyrophilic and collagenic fibers, and inflammatory infiltrations near portal biliary tract after 30 days; steatosis and parenchymatosis after 90 days | Moniuszko-Jakoniuk et al. 1999
Mink | 122 days, 7 days/week (F) | 0.08 | 0.13 | Venopathy | Koppang and Rimeslatten 1976
Rabbit (New Zealand) | 12 weeks, 7 days/week (GW) | ND | 0.5 (serious LOAEL) | Necrosis; vascular degeneration; central vein congestion | Sheweita et al. 2017
Dog (Beagles) | 24 weeks, 2 days/week at 2 mg/kg (C) | ND | 0.6 (serious LOAEL) | Severe hepatic effects including histopathology; elevated serum enzyme levels; and ascites | Boothe et al. 1992
Dog (Mongrel) | 4 weeks, 2 days/week at 2.51 mg/kg (C) | ND | 0.72 (serious LOAEL) | Necrosis; fibrosis; increased serum AST and ALT | Hashimoto et al. 1989
Dog (Mongrel) | 4 weeks, 2 days/week at 2.51 mg/kg (C) | ND | 0.72 (serious LOAEL) | Necrosis; fibrosis; increased serum AST, ALT, ALP, and bilirubin; ascites | Madden et al. 1970
Rat (strain NS) | 30 days, 1 time/day (G) | ND | 1 | Vacuolation and congestion | Maduagwu and Bassir 1980
Monkeys and guinea pigs (species NS) | 30 days, 1 time/day (G) | ND | 1 (serious LOAEL) | Necrosis | Maduagwu and Bassir 1980
Rat (Crl:CD[SD], male) | 28 days, 7 days/week (G) | 1 | 2 | Inflammatory cell infiltration | Hamada et al. 2015; Takashima et al. 2015
Rat (Sprague-Dawley) | 15 days, 1 time/day (GW) | 0.5 | 2 (serious LOAEL) | Hepatocyte degeneration and fibrosis | Rothfuss et al. 2010
Hematology effects
Rat (Wistar, male) | 30 or 90 days, 7 days/week (W) | ND | 0.002 (serious LOAEL) | Bone marrow histopathology changes after 90 days: focal necrosis; edema, degeneration; decrease in megakaryocytes and migration to vascular sinus; myelosclerosis | Moniuszko-Jakoniuk et al. 1999
Developmental effects
Mouse (CD-1) | 75 days prior to mating and through pregnancy until weaning (W) | ND | 0.026 (serious LOAEL) | Perinatal death (stillborn and within 2 days of birth) | Anderson et al. 1978
Reproductive effects
Rabbit (New Zealand) | 12 weeks, 7 days/week (GW) | ND | 0.5 (serious LOAEL) | Histopathology changes in testes | Sheweita et al. 2017
Immune system effects
Mouse (C57BL/6) | 13 weeks, 7 days/week (W) | 0.26 | 1.3 | Immunosuppression | Desjardins et al. 1992
Other (death, cancer)
Mouse (A/JNCr) | 16–48 weeks, 7 days/week (W) | ND | 0.25 (CEL) | Lung tumors | Anderson et al. 1992a
Mink | 23–34 days, 7 days/week (F) | ND | 0.32 (serious LOAEL) | Death | Carter et al. 1969
Rat (MRC) | 30 weeks, 5 days/week (W) | ND | 0.4 (CEL) | Liver tumors | Keefer et al. 1973
Mouse (RF) | 32 weeks, 7 days/week (W) | ND | 0.4 (CEL) | Lung tumors | Clapp and Toya 1970
Rat (F344) | 30 weeks, (5 days/week) (W) | ND | 0.75 (serious LOAEL, CEL) | Decreased survival and liver tumors | Lijinsky and Reuber 1984
Cats (strain NS) | 30 days, 1 time/day (G) | ND | 1 (serious LOAEL) | Death | Maduagwu and Bassir 1980
Mouse (Swiss) | 38 weeks, 7 days/week (W) | ND | 1 (serious LOAEL, CEL) | Decreased survival and liver, lung, and kidney tumors | Terracini et al. 1966
Hamster (Syrian Golden) | Up to 7 months, 7 days/week (W) | ND | 1.1 (serious LOAEL) | Decreased survival and liver tumors | Bosan et al. 1987
Mouse (C3Hf) | 13 weeks, 7 days/week (W) | ND | 1.2 (serious LOAEL, CEL) | Decreased survival; liver and lung tumors | Den Engelse et al. 1974
Rat (Wistar) | 30 weeks, 7 days/week (W) | ND | 1.5 (serious LOAEL, CEL) | Decreased survival and liver tumors | Takahashi et al. 2000

ALP = alkaline phosphatase; ALT = alanine aminotransferase; AST = aspartate aminotransferase; (C) = capsule; CEL = cancer effect level; (F) = feed; (G) = gavage; GGT= gamma-glutamyl transferase; (GW) = gavage in water; LOAEL = lowest-observed-adverse-effect level; NA = not applicable; ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified; (W) = water

Roszczenko et al. (1996b) identified effects at the lowest dose (0.0016 mg/kg/day) tested in any intermediate-duration study. In this study, groups of seven male Wistar rats were exposed to NDMA in drinking water for 30 or 90 days in a study evaluating iron indices. Exposure concentrations of 10 or 20 μg/L (0.01 and 0.02 mg/L) were estimated by the study authors to yield doses of 0.0007 and 0.0016 mg/kg/day, respectively. At sacrifice at the end of exposure, blood was collected for analysis of hematocrit and hemoglobin concentration. Iron, total and latent iron binding capacity, and percentage transferrin saturation in serum were measured. Iron concentration in the liver and spleen were analyzed. At 0.0007 mg/kg/day, no statistically significant effect on any measured parameter was observed. At 0.0016 mg/kg/day, there was a significant 28% increase in hemoglobin concentration, but no effect on hematocrit. Serum iron concentration was not significantly affected by treatment. Latent iron binding capacity was significantly decreased by 51%, and there was a significant, 22% increase in percent transferrin saturation. Total iron binding capacity was lower than controls at 0.0016 mg/kg/day, but the difference (16%) was not statistically significant. Iron content of the liver did not differ significantly from controls in treated animals, but there was a significant and marked 87% increase in iron content of the spleen.

In the related study by Roszczenko et al. (1996a), NDMA was administered in drinking water at a concentration of 20 μg/L (0.02 mg/L) to groups of seven male Wistar rats for 30 or 90 days, yielding a dose of approximately 0.002 mg/kg/day. The only endpoints measured in this study were serum enzymes (AST, ALT, ALP, and GGT). Statistically significant increases in enzymes were observed at all time points. After 30 days, serum AST was increased by 10% compared to controls; ALT and ALP concentrations were doubled; and a 4-fold increase in GGT was measured. Results at 90 days were similar to those after 30 days.

Neither of the studies by Roszczenko et al. (1996a, 1996b) evaluated organ weights or liver or other organ histopathology; thus, the severity of the effect levels in the intermediate-duration experiments conducted by these authors is uncertain. In a third study by these investigators (Moniuszko-Jakoniuk et al. 1999), groups of eight male Wistar rats were exposed to NDMA in drinking water (0.03 and 0.045 mg/L) at estimated doses of 0.002 and 0.003 mg/kg/day for 30 or 90 days; iron content of the liver and spleen and histopathology of the liver, bone marrow, and spleen were assessed. After 30 days, liver histopathology changes including degeneration, argyrophilic and collagenic fibers, and inflammatory infiltrations near the portal biliary tract were observed at both doses, and at 0.003 mg/kg/day, there were bone marrow changes including focal necrosis, edema, and degeneration. After 90 days, the liver effects at both doses were more severe, including steatosis and parenchymatosis, and there were histopathology changes at both doses in the spleen and bone marrow. The authors did not report incidences or severity scores for any of the histopathology changes.

The study by Moniuszko-Jakoniuk et al. (1999) demonstrated exposure duration- and dose-related increases in the severity of liver histopathology changes in rats exposed to doses as low as 0.002 mg/kg/day (0.03 mg/L in water) NDMA. Because there are no histopathology data for lower doses/concentrations (0.01 and 0.02 mg/L or 0.0007 and 0.0016–0.002 mg/kg/day) in the 30- and 90-day experiments by Roszczenko et al. (1996a, 1996b), a clear NOAEL cannot be determined, and the LOAELs are of uncertain severity. Therefore, the data for the intermediate duration are insufficient for derivation of a MRL.

Agency Contacts (Chemical Managers): Custodio Muianga, PhD, MPH, CHMM

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodimethylamine
CAS Numbers: | 62-75-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: The chronic-duration oral data were not considered adequate for derivation of a chronic-duration oral MRL for NDMA.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Table A-10 summarizes results from candidate chronic-duration oral studies in laboratory animals.

Table A-10 Summary of Chronic-Duration Oral Studies of N-Nitrosodimethylamine in Animals

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Other (death, cancer)
Rat (Wistar) | 3.5 years, 7 days/week (W) | ND | 0.022 (serious LOAEL, CEL) | Decreased survival due to liver tumors | Peto et al. 1984, 1991a, 1991b
Mink (NS) | 1–2 years, 7 days/week (F) | ND | 0.1 (serious LOAEL, CEL) | Decreased survival, liver tumors | Koppang and Rimeslatten 1976
Rat (Wistar) | 96 weeks, 7 days/week (F) | ND | 0.13 (CEL) | Liver tumors | Arai et al. 1979; Ito et al. 1982
Mouse (A/JNCr) | 72 weeks, 7 days/week (W) | ND | 0.24 (CEL) | Lung tumors | Anderson et al. 1992a
Rat (Wistar) | 54 weeks, 7 days/week (F) | ND | 0.5 (CEL) | Testicular tumors | Terao et al. 1978
Mouse (RF) | Lifetime (mean 406 days), 7 days/week (W) | ND | 0.43 (serious LOAEL, CEL) | Decreased survival and liver and lung tumors | Clapp and Toya 1970
Hepatic effects
Dog (Beagle) | 56 weeks, 2 days/week at 2 mg/kg (C) | ND | 0.6^a^ (serious LOAEL) | Fibrosis, cirrhosis, necrosis | Butler-Howe et al. 1993

a Adjusted for discontinuous exposure (2 mg/kg × 2/7 days/week).

(C) = capsule; CEL = cancer effect level; (F) = feed; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified; (W) = water

Peto et al. (1984, 1991a, 1991b) conducted a large cancer dose-response study of NDMA in rats. Groups of 60 rats/sex were exposed to 1 of 15 concentrations of NDMA in drinking water (between 0.033 and 16.896 ppm) for 3.5 years. The authors noted that the longer duration was intended to enable effects to be detected at very low doses. These water concentrations yielded estimated doses of 0.001–0.697 mg/kg/day (Peto et al. 1984, 1991b). Controls received untreated water. Groups of six rats/sex/dose were sacrificed after 12 and 18 months, and the remaining animals were observed until natural death, moribund appearance, or appearance of palpable liver abnormalities. Macroscopic necropsies were performed on all animals. Histopathology examinations were performed on grossly observed lesions; apart from these, only the liver and esophagus were routinely examined microscopically. Results for the interim sacrifices were not reported separately. In both male and female rats, NDMA doses ≥0.022 mg/kg/day were associated with decreased survival due to liver tumors. Significant dose-related trends were observed for several liver lesions, including hyperplastic nodules, cytomegaly, cysts, hepatocyte shrinkage (males only), and abnormality of glycogen-containing cells (females only). The incidences of these lesions were not significantly different from controls at doses <0.022 mg/kg/day in pairwise statistical tests (Fisher’s exact test). However, these lesions may reflect preneoplastic changes, and the incidences may have been influenced by progression to tumors (liver neoplasms were observed at all doses); thus, neither NOAEL nor LOAEL values can be identified from these data.

As Table A-5 shows, the remaining chronic studies used single exposure levels much higher than the serious LOAEL of 0.022 mg/kg/day from Peto et al. (1984, 1991a, 1991b) and identified serious LOAELs for decreased survival and/or CELs. Therefore, the available data do not provide an adequate basis for derivation of a chronic-duration oral MRL.

Agency Contacts (Chemical Managers): Custodio Muianga, PhD, MPH, CHMM

1 Total iron binding capacity refers to the sum of serum iron and serum unsaturated (latent) iron-binding capacity. Percentage transferrin saturation is calculated by dividing the serum iron concentration by the total iron binding capacity and multiplying by 100.