# CHAPTER 8 REFERENCES

* Cited in text

+ Cited in supplemental document

*ACGIH. 2016. CAS Number Index. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. February 28, 2017.
*Adamson RH, Sieber SM. 1979. The use of nonhuman primates for chemical carcinogenesis studies. Ecotoxicol Environ Qua1 2:275–302.
*Adamson RH, Sieber SM. 1983. Chemical carcinogenesis studies in nonhuman primates. U.S. EPA, Res Dev, EPA600983008, PB83220137, 129–156.
*AIHA. 2015. Current ERPG Values (2015). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2015%20ERPG%20Levels.pdf. March 22, 2016.
*Airoldi L, Marcr A, Bonfanti M, . 1984. Kinetics and bioavailability of N-nitrosodiethanolamine after intravenous and cutaneous administration to rats. Fundam Chem Toxicol 22:133–138.
*Alliston TG, Cox GB, Kirk RS. 1972. Determination of steam-volatile N-nitrosamines in foods by formation of electron-capturing derivatives from electrochemically derived amines. Analyst 97:915–920.4637883
*Althoff J, Krueger FW, Mohr U. 1973a. Carcinogenic effect of dipropylnitrosamine and compounds related by beta oxidation. J Nat Cancer Inst 51:287–288.4720879
*Althoff J, Krueger FW, Hilfrich J, . 1973b. Carcinogenicity of betahydroxylated dipropylnitrosamine. Naturwissenschaften 60:55.
*Althoff J, Pour P, Grandjean C, , 1977a. Transplacental effects of nitrosamines in Syrian hamsters: III. Dimethyl and dipropylnitrosamine. Z Krebsforsch Klin Onkol 90:79–86.
*Althoff J, Grandjean C, Pour P, . 1977b. Comparison of the effect of beta-oxidized dipropylnitrosamine metabolites administered at equimolar doses to Syrian hamsters. Z Krebsforsch Klin Onkol 90:141–148.
*Althoff J, Grandjean C. 1979. In vivo studies in Syrian golden hamsters: A transplacental bioassay of ten nitrosamines. Natl Cancer Inst Monogr 51:251–255.
*Amacher DE, Paillet SC, Turner GN. 1979. Utility of the mouse lymphoma L5178Y/TK assay for the detection of chemical mutagens. Banbury Report 2:277–293.
Amacher DE, Paillet SC. 1981. The use of cultured embryonic mammalian cells for the activation of promutagens in the L5178Y/TK+/- mutation assay. Environ Mutagen 3:351–352.
*Amacher DE, Paillet SC. 1982. Hamster hepatocyte-mediated activation of procarcinogens to mutagens in the L5178Y/TK mutation assay. Mutat Res 106:305–316.7155171
*Amacher DE, Paillet SC. 1983. The activation of procarcinogens to mutagens by cultured rat hepatocytes in the L5178Y/TK mutation assay. Mutat Res 113:77–88.6828044
*Amlacher E, Rudolph C. 1981. The thymidine incorporation inhibiting screening system to test carcinogenic substances: A nuclear DNA synthesis suppressive short-term test. Arch Geschwulstforsch 51:605–610.7337543
*Araki A, Muramatsu M, Matsushima T. 1984. Comparison of mutagenicities of N-nitrosamines on Salmonella typhimurium TA100 and Escherichia coli WP2 UVRA/PKMOl using rat and hamster liver S9 mix. Gann 75:8–16.6373472
Archer MC. 1981. Mechanisms of alkylation of DNA by N-nitrosodialkylamines. Abst Pap-Am Chem Soc 181:AGFD 35.
Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Intern J Chem Kinetics 19:799–828.
*ATSDR. 2017. N-Nitrosodi-n-propylamine. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
*Barnes JM, Magee PN. 1954. Some toxic properties of dimethylnitrosamine. Br J Ind Med 11:167–174.13182155
*Barnes D, Bellin J, DeRosa C, . 1987. Reference dose (RfD): description and use in health risk assessments. Volume I, Appendix A: Integrated risk information system supportive documentation. Washington, DC: US Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600886032a.
*Bartsch H, Camus A, Malaveille C. 1976. Comparative mutagenicity of N-nitrosamines in a semi-solid and in a liquid incubation system in the presence of rat or human tissue fractions. Mutat Res 37:149–162.794701
*Bartsch H, Malaveille C, Camus AM, . 1980. Validation and comparative studies on 180 chemicals with S. Typhimurium strains and V79 Chinese hamster cells in the presence of various metabolizing systems. Mutat Res 76:1–50.6993936
*Bauman PA, Hotchkiss JH, Parker RS. 1985. Metabolism of N-nitrosodi-n-propylamine and N-nitrosodiallylamine by isolated rat hepatocytes. Cancer Lett 28:229–236.4052993
Begutter H, Klus H, Ultsch I. 1985. Capillary gas chromatographic determination of volatile and tobacco-specific N-nitrosamines by thermal energy analyzer. J Chromatogr 321:475–479.
*Berard DF, Rainey DP. 1979. Dissipation of 14C N-nitroso-di-n-propylanol from field soil and residue determinations in field grown soybeans. Bull Environ Contam Toxicol 23:141–144.574034
*Billedeau SM, Thompson HC Jr, Miller BJ, . 1986. Volatile N-nitrosamines in infant pacifiers sold in the United States as determined by gas chromatography - thermal energy analysis. J Assoc Off Anal Chem 69(1):31–34.3949695
+*Blattmann L, Preussmann R. 1973. Structure of rat urinary metabolites of carcinogenic dialkylnitrosamines. Z Krebsforsch Klin Onkol 79:3–5.
*Bradley MO, Dysart G. 1981a. Measurements on DNA single and double strand breaks and their repair by filter elution in rat hepatocytes nitrosamines and gamma irradiation. Proc Am Assoc Cancer Res Am Soc Clin Oncol 22:90.
*Bradley MO, Dysart G. 1981b. Measurements on DNA single and double strand breaks and their repair by filter elution in rat hepatocytes nitrosamines and gamma irradiation. 12th Annual Meeting of the Environmental Mutagen Society. Environ Mutagen 3:395.
*Bradley MO, Dysart G, Fitzsimmons K, . 1982. Measurements by filter elution of DNA single- and double-strand breaks in rat hepatocytes: Effects of nitrosamines and gamma-irradiation. Cancer Res 42:2592–2597.7083152
*Brambilla G, Cavanna M, Pino A, . 1981. Quantitative correlation among DNA damaging potency of six N-nitroso compounds and their potency in inducing tumor growth and bacterial mutations. Carcinogenesis 2:425–429. (London)7023730
*Brambilla G, Carlo P, Finollo R, . 1987a. Dose-response curves for liver DNA fragmentation-induced in rats by sixteen N-nitroso compounds as measured by viscometric and alkaline elution analyses. Cancer Res 47:3485–3491.3581083
*Brambilla G, Martelli A, Robbianao L, . 1987b. Induction of DNA fragmentation and repair in human hepatocytees by N-nitroso compounds. Proc AACR 28:114.
*Brittebo EB, Tjalve H. 1982. Tissue-specificity of N-nitrosodi-butylamine metabolism in Sprague-Dawley rats. Chem-Biol Interact 38:231–242.6276033
*Bronaugh RL, Congdon ER, Scheuplein RJ. 1979. The percutaneous absorption of N-nitrosodiethanolamine through excised human skin. J Invest Dermatol 72:204.
*Bronaugh RL, Congdon ER, Scheuplein RJ. 1981. The effect of cosmetic vehicles on the penetration of N-nitrosodiethanolamine through excised human skin. Invest Dermatol 76:94–96.
*Bysshe SB. 1982. Bioconcentration factor in aquatic organisms. Handbook of chemical property estimation methods. Lyman WJ, Reehl WF, Rosenblatt DH, Eds. McGraw Hill Book Co., New York, Chapter 5.
*Callahan MA, Slimak MW, Gabel NW, . 1979. Water-related environmental fate of 129 priority pollutants, Vol. II. EPA440479029B. U.S. EPA, Washington, DC.
+CAS (Chemical Abstract Service). 1988. CA Registry File, Online: 8/3/88.
*Castegnaro M, Michelon J, Walker EA. 1982. Some detoxification methods for N-nitrosamine-contaminated wastes. IARC Sci Pub1 41:151–157.
*Cerutti G, Zappavigna R, Santini PL. 1975. N-Alkylnitrosamines in domestic and imported cheese [Abstract]. Latte 3:224–227.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Cohen SZ, Zweig G, Law M, . 1978. Analytical determination of N-nitroso compounds in pesticides by the United States environmental protection agency -- A preliminary study. IARC Sci Pub1 19:333–342.
*Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
*Cooper CV. 1987. Gas chromatographic/mass spectrometric analysis of extracts of workplace air samples for nitrosamines. Am Ind Hyg Assoc J 48:265.3578037
*Cooper SW, Kimbrough RD. 1980. Acute dimethynitrosamine poisoning outbreak. J Forensic Sci 25:874–882.7430995
*Cooper SF, Lemoyne C, Gauvreau D. 1987. Identification and quantitation of N-nitrosamines in human postmortem organs. J Anal Toxicol 11:12–18.3821072
*Crosby DG. 1979. The significance of light induced pesticide transformations. In: Advances in pest. Sci., Part III. Geissbuhler H, Ed. Permagon Press, Oxford, 568–576.
Crosby DG, Humphrey JR, Muilanen KW. 1980. The photodecomposition of dipropylnitrosamine vapor. Chemos 9:51–54.
+Dahl AR. 1985. Mutagenicity of some dialkylnitrosamines, cyclic nitrosamines and N,N-diethanolnitrosamine in Salmonella typhimurium with rat and rabbit nasal, lung and liver S9 homogenates. Mutat Res 158:141–147.3908927
Dahl AR. 1986. Activation of nitrosamines to mutagens by rat and rabbit nasal, lung and liver S9 homogenates. Adv Exp Med Biol 197:367–372.2945408
Danz M, Urban H, Schmidt A, . 1978. A possible short-term prediction of potential carcinogenicity of chemical compounds in vivo by means of a promoting activity test (PAT). Exp Pathol 16:109–120.
*Daugherty JP, Klapp NK. 1976. Studies on nitrosamine metabolism: I. Subcellular distribution of radioactivity in tumor-susceptible tissues of RFM mice following administration of (14C) dimethylnitrosamine. Life Sci 19:265–271.957870
*Day EW, Jr, Saunders DG, Mosier JW. 1982. Estimation of inhalation exposure to N-nitrosodipropylamine during the application and incorporation of the herbicide trifluralin. Environ Sci Technol 16:131–136.
*Degan P, Montesano R, Wild CP. 1988. Antibodies against 7-methyldeoxyguanosine: Its detection in rat peripheral blood lymphocyte DNA and potential applications to molecular epidemiology. Cancer Res 48:5065–5070.3409234
*Diaz Gomez MI, Swann PF, Magee PN. 1977. The absorption and metabolism in rats of small oral doses of dimethylnitrosamine. Implication for the possible hazard of diemthylnitrosamine in human food. Biochem J 164:497–500.883948
*Dickhaus S, Reznik G, Green U, . 1977. The carcinogenic effect of beta-oxidized dipropylnitrosamine in mice: I. Dipropylnitrosamine and methyl-propylnitrosamine. Z Krebsforsch Klin Onkol 90:253–258.
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. February 28, 2017.
*Drescher GS, Frank CW. 1978. Estimation of extractable N-nitroso compounds at the parts-per-billion level. Anal Chem 50:2118–2121.
+*Druckrey H, Preussman R, Ivankovic S, . 1967. Organotropic carcinogenic effects of 65 different N-nitroso compounds on BD rats. Z Krebsforsch 69:103–201.4230610
*Du Plessis LS, Nunn JR. 1972. Nitrosamine analysis, part 1, the estimation of low molecular weight alkyl nitrosamines. Bogvoski P, Preussmann R, Walker EA, Eds. International Agency for Research on Cancer Scientific Publications No. 3, 55–63.
+Edwards GS, Peng M, Fine DH, Spiegelhalder B, Kahn J. 1979. Detection of N-nitrosodiethanolamine in human urine following application of a contaminant cosmetic. Toxicol Lett 4:217–222.
*Eichelberger JW, Kerns EH, Olynyk P, . 1983. Precision and accuracy in the determination of organics in water by fused silica capillary column gas chromatography/mass spectrometry and packed column gas chromatography/mass spectrometry. Anal Chem 55:1471–1479.
*Eisenbrand G, Ellen G, Preussmann R, . 1983. Determination of volatile nitrosamines in food, animal feed and other biological materials by low-temperature vacuum distillation and chemiluminescence detection. IARC Sci Pub1 45:181–203.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants of the Great Lakes ecosystem. Environ Sci Tech 15:30–38.
*EPA. 1977. Computer print-out of non-confidential production data from TSCA inventory. OPTS, CID. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1979. Federal Register 44:50912–50915. Trifluralin/Treflan RPAR, Determination.
*EPA. 1980. Guidelines and methodology used in the preparation of health effect assessment chapters of the consent decree water criteria documents. Washington, DC: U.S. Environmental Protection Agency. Federal Register 45:79347–79357.
*EPA. 1982. Test Methods: Methods for organic chemical analysis of municipal and industrial wastewater. Method No. 607 and 625, Nitrosoamines and Base/Neutrals and Acids. Cincinnati, OH: Environmental Monitoring and Support Laboratory, U.S. Environmental Protection Agency.
*EPA. 1986a. Graphical Exposure Modeling System (GEMS). PCCHEM Computer Program, Version 1.60. November 1, 1986. U.S. Environmental Protection Agency.
*EPA. 1986b. Test Methods for Evaluating Solid Waste. SW-846, 3rd ed. Method No. 8250 and 8270, Vol IB: Laboratory Manual: Physical/Chemical Methods, Office of Solid Waste and Emergency Response, U.S. EPA, Washington, DC.
*EPA. 1987. U.S. EPA Contract Laboratory Program. Statement of Work for Organic Analysis. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1988. Integrated Risk Information System (IRIS). Risk estimate for carcinogenicity for N-nitrosodi-n-propylamine. Online. (Verification date 3/1/88). Cincinnati, OH: Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, U.S. Environmental Protection Agency.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. May 11, 2017.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) Values. U.S. Environmental Protection Agency. https://www.epa.gov/aegl/access-acute-exposure-guideline-levels-aegls-values#chemicals. February 28, 2017.
*Fajen JM, Fine DH, Roundbehler DP. 1980. N-Nitrosamines in the factory environment. IARC Sci Publ 31:517–528.
*Farrelly JG, Stewart ML, Lijinsky W. 1984. The metabolism of nitrosodinpropylamine, nitrosodiallylamine and nitrosodiethanolamine. Carcinogenesis 5:1015–1019.6744511
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. February 28, 2017.
*Fine DH, Rounbehler DP, Oettinger PE. 1975. Rapid method for the determination of sub part per billion amounts of n-nitroso compounds in foodstuffs. Anal Chim Acta 78:383–389.1166962
*Fisk JF. 1986. Semi-volatile organic analytical methods – general description and quality control considerations. ASTM Spec Tech Pub1 925:143–156.
*Foiles PC, Miglietta LM, Akerkar SA, Everson RB, Hecht SS. 1988. Detection of 06-methyldeoxyguanosine in human placental DNA. Cancer Res 48:4184–4188.3390812
*Freund HA. 1937. Clinical manifestations and studies in parenchymatous hepatitis. Ann Int Med 10:1144–1155.
*Fussgaenger RD, Ditschuneits H. 1980. Lethal exitus of a patient with N-nitrosodimethylamine poisoning. 2.5 Years following the first ingestion and signs of intoxication. Oncology 37:273–277.7443160
*Gavinelli M, Fanelli R, Bonfanti M, . 1988. Volatile nitrosamines in foods and beverages: Preliminary survey of the Italian market. Bull Environ Contam Toxicol 40:41–46.3345364
*Gaff EU, Fine DH. 1979. Analysis of volatile N-nitrosamines in alcoholic beverages. Food Cosmet Toxicol 17:569–573.546693
*Gray JI, Dugan LR Jr. 1974. Formation of N-nitrosamines in low moisture systems. J Food Sci 39:474–478.
*Gray JI, Stachiw MA, 1987. Gas-chromatographic - thermal energy analysis method for determination of volatile N-nitrosamines in baby-bottle rubber nipples: collaborative study. J Assoc Off Anal Chem 70:64–68.3558278
*Greenfield EL, Vasco GA, Legette L, . 1982. Screening procedure for detection of volatile N-nitrosamines in cooked bacon by l-trap mineral oil vacuum distillation and thermal energy analyzer. J Assoc Off Anal Chem 65:1316–1318.7174574
+*Griciute L, Castegnaro M, Bereziat JC. 1982. Influence of ethyl alcohol on the carcinogenic activity of N-nitrosodi-n-propylamine. IARC Sci Pub1 41:643–648.
*Groenen PJ, De Cock-Behbeder MW, Bouwman J, . 1980. Formation of N-nitrosodiamino acids from food products and nitrite under simulated gastric conditions. IARC Sci Pub1 31:215–229.
*Gross RL, Newberne PM. 1977. Naturally occurring toxic substances in foods. Clin Pharmacol Ther 22:680–698.334438
*Guttenplan JB. 1987. Structure-activity relationships in metabolism and mutagenicities of N-nitrosamines. IARC Sci Publ 84:129–131.
*Guttenplan JB, Hu YC. 1984. Mutagenesis by N-nitroso compounds in Salmonella typhimurium TA102 and TA104: Evidence for premutagenic adenine or thymine DNA adducts. Mutat Res 141:153–159.6392880
*Hamada S, Ohyama W, Takashima R, . 2015. Evaluation of the repeated-dose liver and gastrointestinal tract micronucleus assays with 22 chemicals using young adult rats: Summary of the collaborative study by the Collaborative Study Group for the Micronucleus Test (CSGMT)/The Japanese Environmental Mutagen Society (JEMS) - Mammalian Mutagenicity Study Group (MMS). Mutat Res Genet Toxicol Environ Mutagen 780–781:2–17.
*Hansch C, Leo AJ. 1985. Medchem Project Issue No. 26. Pomona College, Claremont, CA.
*Hartmetz G, Slemrova J. 1980. Detection of volatile nitrosamines in waste water from chemical plants by combined capillary gas chromatography mass spectrometry. Bull Environ Contam Toxicol 25:106–112.7459472
*HSDB. 1988. Record no. 5108. Hazardous Substances Data Bank. National Library of Medicine. Online: August, 1988.
*Huang DP, Ho JHC, Webb KS, . 1981. Volatile nitrosamines in salt preserved fish before and after cooking. Food Cosmet Toxicol 19:167–172.7286866
*IARC. 1978. N-nitrosodi-n-propylamine. International Agency for Research on Cancer. IARC Monogr Eva1 Carcinog Risk Chem Man 17:177–189.
*IARC. 1987. IARC Monographs on the Evaluation of Carcinogens Risk to Humans. Update of IARC Monographs. International Agency for Research on Cancer. Vols 1–42, Suppl 7, 31–32, 68.
*IRIS. 2002. N-Nitrosodi-N-propylamine; CASRN 621-64-7. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0177_summary.pdf. May 11, 2017.
*Ishinishi N, Tanaka A, Hisanaga A, . 1988. Comparative study on the carcinogenicity of N-nitrosodiethylamine, N-nitrosodimethylamine, N-nitrosomorpholine, N-nitrosopyrrolidine and N-nitrosodi-n-propylamine to the lung of Syrian golden hamsters following intermittent instillations to the trachea. Carcinogenesis 9(6):947–950.3370758
*Jones CA, Huberman E. 1980. A sensitive hepatocyte-mediated assay for the metabolism of nitrosamines to mutagens for mammalian cells. Cancer Res 40:406–411.7188682
*Kaminski NE, Jordan SD, Page D, . 1989. Suppression of humoral immune responses by dialkylnitrosamines: Structure-activity relationships. Fundam Appl Toxicol 12(2):321–332.2785465
*Kaneko A, Hayashi M, Yoshikawa K, . 1978. Chromosome aberration tests combined with S-9 metabolic activation system in vitro. Mutat Res 54:240.
*Kirkland D, Aardema M, Henderson L, . 2005. Evaluation of the ability of a battery of three in vitro genotoxicity tests to discriminate rodent carcinogens and non-carcinogens. I. Sensitivity, specificity and relative predictivity. Mutat Res 584(1–2):1–256.15979392
*Klein RG. 1982. Calculations and measurements on the volatility of N-nitrosamines and their aqueous solutions. Toxicology. 23:135–147.7112590
*Klein RG, Schmezer P. 1984. Quantitative measurement of the exhalation rate of volatile N-nitrosamines in inhalation experiments with anesthetized Sprague-Dawley rats. IARC Sci Publ 57:513–517.
*Knasmüller S, Parzefall W, Sanyal R, . 1998. Use of metabolically competent human hepatoma cells for the detection of mutagens and antimutagens. Mutat Res 402(1–2):185–202.9675276
*Knasmuller S, Szakmary A, Kehrer M. 1990. Use of differential DNA-repair host mediated assays to investigate the biotransformation of xenobiotics in Drosophila melanogaster. 1. Genotoxic effects of nitrosamines. Chem Biol Interact 75:17–29.2114223
*Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kruger FW. 1971. Metabolism of nitrosamines in vivo. I. Evidence for beta-oxidation of aliphatic dialkylnitrosamines. Simultaneous formation of 7-methylguanine and 7-propyl- or 7-butylguanine after application of dipropyl- or dibutylnitrosamine. Z Krebsforsch 76:145–154.
*Kruger FW. 1973, Metabolism of nitrosamines in vivo. II. On the methylation of nucleic acids by aliphatic di-n-alkyl-nitrosamines in vivo, caused by beta-oxidation: The increased formation of 7-methylguanine after application of beta-hydroxypropyl-propyl-nitrosamine compared to that after application of di-n-propyl-nitrosamine. Z Krebsforsch Klin Onkol 79:90–97.
*Kruger F, Bertram B. 1973. Metabolism of nitrosamines in vivo. III. On the methylation of nucleic acids by aliphatic di-n-alkylnitrosamines in vivo resulting from beta-oxidation: the formation of 7-methylguanine after application of 2-oxopropylpropyl-nitrosamine and methylpropylnitrosamine. Z Krebsforsch Klin Onkol 80:189–196. (Cited in Bauman et al. 1985)
*Kuroki T, Drevon C, Montesano R. 1977. Microsome-mediated mutagenesis in V79 Chinese hamster cells by various nitrosamines. Cancer Res 37:1044–1050.321116
*Langenbach R. 1986. Mutagenic activity and structure-activity relationship of short-chain dialkyl N-nitrosamines in a hamster hepatocity cell-mediated system. Mutat Res 163:303–311.3785266
Lee SA. 1982. Health hazard evaluation report no. HETA-82-156-1231, order no. 882316081, PB84-172-915, Sheller-Globe Corporation, Keokuk, Iowa. Hazard Evaluations and Technical Assistance Branch, NIOSH Cincinnati, OH, 8 pages.
*Lethco EJ, Wallace WC, Brouwer E. 1982. The fate of N-nitrosodiethanolamine after oral and topical administration to rats. Food Chem Toxicol 20:401–406.6890019
*Leung KH, Archer MC. 1981. Urinary metabolites of N-nitrosodipropylamine, N-nitroso-2-hydroxypropylpropylamine and N-nitroso-2-oxo-propylpropylamine in the rat. Carcinogenesis 2:859–862.7296770
*Leung KH, Archer M. 1984. Studies on the metabolic activation of betaketo nitrosamines: mechanisms of DNA methylation by N-(2-oxopropyl)N-nitrosourea and N-nitroso-n-acetoxymethyl-n-2-oxopropylamine. Chem Biol Interact 48:169–179. (Cited in Bauman et al. 1985)6697420
Lijinsky W. 1977. Relative carcinogenicity of aliphatic nitrosamines at equimolar doses. Proc Amer Ass Cancer Res 18:14.
Lijinsky W. 1984. Species differences in nitrosamine carcinogenesis. J Cancer Res Clin Oncol 108:46–55.6746715
+*Lijinsky W, Reuber MD. 1981. Comparative carcinogenesis by some aliphatic nitrosamines in Fischer rats. Cancer Lett 14:297–302.7332906
+*Lijinsky W, Reuber MD. 1983. Carcinogenesis in Fischer rats by nitrosodipropylamine, nitrosodibutylamine and nitrosobis(2-oxopropylamine given by gavage. Cancer Lett 19:207–213.6883308
+*Lijinsky W, Taylor HW. 1978. Comparative carcinogenicity of some derivatives of nitrosodi-n-propylamine in rats. Ecotoxicol Environ Saf 2:421–426.751794
+*Lijinsky W, Taylor HW. 1979. Carcinogenicity of methylated derivatives of N-nitrosodiethylamine and related compounds in Sprague-Dawley rats. J Nat Cancer Inst 62:407–410.283272
*Lijinsky W, Losifoff AM, Sansone EP. 1981. Penetration of rat skin by N-nitrosodiethanolamine and N-nitrosomorpholine. J Nat Cancer Inst 66:125–128.6935453
*Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Handbook of chemical property estimation methods. Lyman WJ, Reehl WF, Rosenblatt DH, Eds. Chapter 4. New York, NY: McGraw Hill Book Co.
*Lyman WJ. 1985. Estimation of physical properties. In: Environmental exposure from chemicals, vol 1. Neely WB, Blau GE, Eds. Boca Raton, Florida: CRC Press Inc.
*MacMillan, WD. 1983. Separation and direct chemical determination of nitrosamines by high performance liquid chromatography (HPLC). Anal Lett 16:957–968.
*Magee PN, Montesano R, Preussman R. 1976. N-nitroso compounds and related carcinogens. ACS Monograph 173:491–625.
*Maki T. 1980. A rapid and simple method for the determination of volatile N-nitrosamines in biological materials. Bull Environ Contam Toxicol 25:751–754.7470650
Margison GP. 1982. Chronic or acute administration of various dialkylnitrosamines enhances the removal of 06-methylguanine from rat liver DNA in vivo. Chem-Biol Interact 38:189–202.6173138
*Martelli A, Robbiano L, Gazzaniga GM, . 1988. Comparative study of DNA damage and repair induced by ten N-nitroso compounds in primary cultures of human and rat hepatocytes. Cancer Res 48(15):4144–4152.3390807
*Martin CN, McDermid AC, Garner RC. 1978. Testing of known carcinogens and noncarcinogens for their ability to induce unscheduled DNA synthesis in HELA cells. Cancer Res 38:2621–2627.667855
*Marzulli FN, Anjo DM, Maibach HI. 1981. In vivo skin penetration studies of 2,4-toluenediamine, 2,4-diaminoanisole, 2-nitro-p-phenylenediamine, dioxane and N-nitrosodiethanolamine in cosmetics. Food Cosmet Toxicol 19:743–747.7327475
*Matsuoka A, Hayashi M, Ishidate M Jr. 1979. Chromosomal aberration tests on 29 chemicals combined with S-9 mix in vitro. Mutat Res 66:277–290.375085
*Maybury RB, Grant RG. 1983. Gas - liquid chromatography and nitrogen phosphorus detection of N-nitrosodipropylamine in trifluralin products. J Assoc Off Anal Chem 66:1209–1213.
McCann J, Choi E, Yamasaki E, . 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Nat1 Acad Sci USA 72:5135–5139.
*McCormick A, Nicholson JM, Baylis MA, . 1973. Nitrosamines in cigarette smoke condensate. Nature 244:237–238.4583100
*McMahon RE, Cline JC, Thompson CZ. 1979. Assay of 855 test chemicals in ten tester strains using a new modification of the Ames test for bacterial mutagens. Cancer Res 39:682–693.371791
*Mersch-Sundermann V, Schneider U, Klopman G, . 1994. SOS induction in Escherichia coli and Salmonella mutagenicity: A comparison using 330 compounds. Mutagenesis 9(3):205–224.7934961
*Millar JD, Thomas RE, Schattenberg HJ. 1984. EPA method study 17, method 607 (nitrosamines). Report, ISS EPA600484051. PB84207646.
*Mills AL, Alexander M. 1976. Factor affecting dimethylnitrosamine formation in samples of soil and water. J Environ Qua1 5:437–440.
*Mirkin BL. 1973. Maternal and fetal distribution of drugs in pregnancy. Clin Pharmacol Ther 14:643–647.4737092
*Mirvish SS, Issenberg P, Sornsen HC. 1976. Air-water and ether-water distribution of N-nitroso compounds: Implications for laboratory safety analytical methodology, and carcinogenicity for the rat esophagus, nose, and liver. J Natl Cancer Inst 56:1125–1129.994213
*Moore CM, Goodall CM, Beagley KW, . 1985. Mutagenic activation of dialkylnitrosamines by intact urothelial cells. Mutat Res 157:95–105.3892287
*Morita T, Asano N, Awogi T, . 1997. Evaluation of the rodent micronucleus assay in the screening of IARC carcinogens (groups 1, 2A and 2B) the summary report of the 6th collaborative study by CSGMT/JEMS MMS. Collaborative study of the micronucleus group test. Mammalian mutagenicity study group [published erratum appears in Mutat Res 1997 Jul 14;391(3):259-67]. Mutat Res 389(1):3–122.9062586
*Nakajima T, Tanaka A, Tojyo K. 1974. Effect of metabolic activation with rat liver preparations on the mutagenicity of several N-nitrosamines on a streptomycin dependent strain of Escherichia coli. Mutat Res 26:361–366.4607183
Napalkov NP. 1969. Sequences of exposure to chemical carcinogen during pregnancy. Bull Int Union Cancer 713–714.
*NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC, 15–35.
NIOSH. 1982. Health Hazard Evaluation. Report No. HETA 82-156-1231. Seller-Globe Corporation, Keokuk, IA. National Institute for Occupational Safety and Health. PB84172915.
*NIOSH. 2016. NIOSH pocket guide to chemical hazards. Index of Chemical Abstracts Service Registry Numbers (CAS No.). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgdcas.html. May 11, 2017.
+*Nishie K, Norred WP, Wasserman A, . 1972. Phototoxicity and differential hepatotoxicity as biological indicators of nitrosamine activity. Toxicol Appl Pharmacol 23:680–691.4630166
*NTP. 2016. N-Nitrosamines: 15 Listings. Report on carcinogens, Fourteenth Edition. CASRN Index in MS Excel. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/nitrosamines.pdf. May 11, 2017.
*OHM-TADS. 1988. On-line computer data base. Oil and Hazardous Materials-Technical Assistance Data System. July 31, 1988.
*Okochi E, Kurahashi A, Mochizuki M. 1997. Detection of mutagenicity in Ames test using a metalloporphyrin/oxidant model system for cytochrome P450. Mutat Res 373(1):99–105.9015158
Olah GA, Donovan DJ, Keefer LK. 1975. Carcinogen chemistry. I. Reactions of protonated dialkylnitrosamines leading to alkylating and aminoalkylating agents of potential metabolic significance. J Natl Cancer Inst 54:465–472.1113327
*Oliver JE. 1979. Volatilization of some herbicide-related nitrosamines from soils. J Environ Qua1 8:596–601.
*Oliver JE. 1981. Pesticide-derived nitrosamines. Occurrence and environmental fate. Agric Symposium series 174:349–362.
*Oliver JE, Kearney PC, Kontson A. 1979. Degradation of herbicide related nitrosamines in aerobic soils. J Agric Food Chem 27:887–891.
*OSHA. 2016a. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2016b. Subpart D Occupational health and environment controls. Section 1926.55 - Gases, vapors, fumes, dusts, and mists. Appendix A to Part 1926.55 - threshold limit values of airborne contaminants for construction. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
*OSHA. 2016c. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol7/pdf/CFR-2016-title29-vol7-sec1915-1000.pdf. March 6, 2017.
*Pancholy SK. 1976. Gas chromatographic analysis of carcinogenic nitrosamines in soil. Soil Biol Biochem 8:75–76.
*Park KK, Archer MC. 1978. Microsomal metabolism of N-nitrosodi-npropylamine: Formation of products resulting from alpha- and betaoxidation. Chem Biol Interact 22:83–90.688527
*Park KK, Archer MC, Wishnok JS. 1980. Alkylation of nucleic acids by N-nitrosodi-n-propylamine: Evidence that carbonium ions are not significantly involved. Chem Biol Interact 29:139–144.7353229
*Park KK, Wishnok JS, Archer MC. 1977. Mechanism of alkylation by N-nitroso compounds: Detection of rearranged alcohol in the microsomal metabolism of N-nitrosodi-n-propylamine and base-catalyzed decomposition of N-n-propyl-n-nitrosourea. Chem-Biol Interact 18:349–354.912817
*Parodi S, Taningher M, Santi L: 1982. Alkaline elution in vivo: Fluorometric analysis in rats. Quantitative predictivity of carcinogenicity, as compared with other short-term tests. In: Indicators of genotoxic exposure. Banbury Report 13:137–155.
*Parodi S, Zunino A, Ottaggio L, . 1983. Quantitative correlation between carcinogenicity and sister chromatid exchange induction in vivo for a group of 11 N- nitroso derivatives. J Toxicol Environ Health 11:337–346.6842616
*Pedal I, Besserer K, Goertitler K, . 1982. Fatal nitrosamine poisoning. Arch Toxicol 50:101–112.7125905
*Phillipson CE, Ioannides C. 1985. Metabolic activation of nitrosamines to mutagens by various animal species including man. Biochem Pharmacol 34:441–442.
*Pour P, Cardesa A, Althoff J, . 1974. Tumorigenesis in the nasal olfactory region of Syrian golden hamsters as a result of dipropylnitrosamine and related compounds. Cancer Res 34:16–26.4809455
*Pour P, Krueger FW, Cardesa A, . 1973, Carcinogenic effect of dipropylnitrosamine in Syrian golden hamsters. J Natl Cancer Inst 51:1019–1027.4743551
*Preussmann R, Wuertele G, Eisenbrand G, . 1978. Urinary excretion of N-nitrosodiethanolamine administered orally to rats. Cancer Lett 4:207–209.647660
*Preussmann R, Spiegelhalder B, Eisenbrand G, . 1981. Urinary excretion of N-nitrosodiethanolamine in rats following its epicutaneous and intratracheal administration and its formation in vivo following skin application of diethanolamine. Cancer Lett 13:227–232.7296532
*Probst GS, McMahon RE, Hill LE, . 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
*Rao TK, Allen BE, Winton W, . 1981. Nitrosamine-induced mutagenesis in Escherichia coli K12 (343/113). I. Mutagenic properties of certain aliphatic nitrosamines. Mutat Res 89:209–215.7022195
*Rao TK, Epler JL, Lijinsky W. 1982. Structure activity studies with N-nitrosamines using Salmonella typhimurium and Escherichia coli. IARC Sci Pub1 41:543–551.
*Rao TK, Young JA, Lijinsky W, . 1979. Mutagenicity of aliphatic nitrosamines in Salmonella typhimurium. Mutat Res 66:1–7.370582
*Rawlings GD, Samfield M. 1979. Toxicity of secondary effluents from textile plants. In: Proc Symp Process Meas Environ Assess 1978. Office of Research and Development, U.S. EPA, Dayton, OH. EPA 600778168.
*Reznik G, Mohr U, Krueger FW. 1975. Carcinogenic effects of dipropylnitrosamine, beta-hydroxypropylpropylnitrosamine, and methylpropylnitrosamine on Sprague-Dawley rats. J Natl Cancer Inst 54:937–943.1127723
*Rhoades JW, Hosenfield JM, Taylor JM, . 1980. Comparison of analysis of wastewaters for N-nitrosamines using various detectors. IARC Sci Pub1 31:377–387.
Richter E, Richter-Cooberg U. 1984. Transfer and metabolism of symmetric di alkyl nitrosamines in jejunal and ileal segments of rats. NaunynSchmiedeberg’s Arch Pharmacol 325:R4.
*Robbiano L, Mereto E, Corbu C, . 1996. DNA damage induced by seven N-nitroso compounds in primary cultures of human and rat kidney cells. Mutat Res 368(1):41–47.8637509
*Ross RD, Morrison J, Roundbehler DP, . 1977. N-Nitroso compound impurities in herbicide formulations. J Agric Food Chem 25:1416–1418.915140
*Ross R, Morrison J, Fine DH. 1978, Assessment of dipropylnitrosamine levels in a tomato field following application of Treflan EC. J Agric Food Chem 26:455–457.632439
RTECS (Registry of Toxic Effects of Chemical Substances). 1988. On-line: August 5, 1988.
*Ruhl C, Reusch J. 1985. Analysis of volatile nitrosamines by microbore high-performance liquid chromatography and thermal energy analyser detection. J Chromatography 328:362–366.
*Sakai A, Inoue T, Tanimura A. 1984. Formation of volatile nitrosamines by drug-nitrite interactions under physiological conditions. Gann 75:245–252.6724228
*SANSS (Structure and Nomanclature Search System). 1988. Computer Information System (CIS). Computer data base, on-line: August 29, 1988.
*Saunders DG, Mosier JW, Gray JE, . 1979. Distribution, movement, and dissipation of N-nitrosodipropylamine in soil. J Agric Food Chem 27:584–589.
*Saunders DG, Mosier JW. 1980. Photolysis of N-nitrosodi-n-propylamine in water. J Agric Food Chem 28:315–319.
Schrenk D, Schwarz M, Tennekes HA, . 1982. A novel pathway of nitrosamine metabolism in liver microsomes: denitrosation of nitrosamines by cytochrome P 450. Adv Exp Med Biol 136B:1157–1164.
*Sen NP, Baddoo PA, Seaman SW. 1987. Volatile nitrosamines in cured meats packaged in elastic rubber nettings. J Agric Food Chem 35:346–350.
Shank RC. 1975. Toxicology of N-nitroso compounds. Toxicol Appl Pharmacol 31:361–368.1096366
*Shu L, Hollenberg PF. 1996. Identification of the cytochrome P450 isozymes involved in the metabolism of N-nitrosodipropyl-,N-nitrosodibutyl- and N-nitroso-n-butyl-n-propylamine. Carcinogenesis 17(4):839–848.8625499
State of Kentucky. 1986. New or modified sources emitting toxic air pollution. 401 KAR 63:022.
+*Suzuki E, Okada M. 1981. Metabolic fate of N-N-dipropylnitrosamine and N,N-diamylnitrosamine in the rat, in relation to their lack of carcinogenic effect on the urinary bladder. Gan 72:552–561.7308667
*Suzuki T, Itoh S, Nakajima M, . 1999. Target organ and time-course in the mutagenicity of five carcinogens in MutaMouse: A summary report of the second collaborative study of the transgenic mouse mutation assay by JEMS/MMS. Mutat Res 444(2):259–268.10521667
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio and water solubility. Res Rev 85:17–28.
*Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Contr Fed 53:1503–1518.
*Tate RL III, Alexander M. 1975. Stability of nitrosamines in samples of lake water, soil, and sewage. J Nat1 Cancer Inst 54:327–330.
*Teiber JF, Hollenberg PF. 2000. Identification of the human liver microsomal cytochrome P450s involved in the metabolism of N-nitrosodi-n-propylamine. Carcinogenesis 21(8):1559–1566.10910959
*Teiber JF, Mace K, Hollenberg PF. 2001. Metabolism of the β-oxidized intermediates of N-nitrosodi-n-propylamine: N-nitroso-β-hydroxypropylpropylamine and N-nitroso-β-oxopropylpropylamine. Carcinogenesis 22(3):499–506.11238192
*Terashima Y, Yokoi R, Takakura I, . 2015. Detection of micronuclei in hepatocytes isolated from young adult rats repeatedly treated with N-nitrosodi-n-propylamine. Mutat Res 780–781:36–40. 10.1016/j.mrgentox.2014.04.001.
*TRI16 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency, Office of Information Analysis and Access. Office of Environmental Information. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 29, 2017.
+*Tyndall RL, Clapp NK, Davidson KA, . 1978. Effects of carcinogenic and non-carcinogenic chemicals on plasma esterases in BALB/C mice. Chem Biol Interactions 23:159–169.
VIAR. 1988. Contract Laboratory Program Statistical Database. Output date: August 10, 1988.
*VIEW Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. June 1989.
*Vohra SK, Harrington GW. 1981. Chromatopolarography of N-nitrosamines including determination of N-nitrosodiethanolamine in cosmetic products. Food Cosmet Toxicol 19:485–488.7274883
*Weast RC. 1983. CRC Handbook of Chemistry and Physics. 64th ed. CRC Press, Inc., Boca Raton, Florida, C-275.
*West SD, Day EW. 1979. Determination of volatile nitrosamines in crops and soils treated with dinitroaniline herbicides. J Agric Food Chem 27:1075–1080.546947
*Westin JB, Castegnaro MJJ, Friesen MD. 1987. N-nitrosamines and nitrosatable amines, potential precursors of N-nitramines, in children’s pacifiers and baby-bottle nipples. Environ Res 43:126–134.3582302
White INH, Smith AG, Farmer PB. 1983. Formation of N-alkylated protoporphyrin IX in the livers of mice after diethylnitrosamine treatment. Biochem J 212:599–608.6882387
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Wishnok JS, Snow K, Woolworth V. 1982. Passage of nitrosamines through animal membranes. IARC Sci Pub1 41:435–442.
*Wotherspoon, D, Hindle R. 1988. Determination of N-nitrosodipropylamine in trifluralin emulsifiable concentrates using minicolumn cleanup and gas chromatography with thermal energy analyzer. J Assoc Off Anal Chem 71:333–336.3384781
*Yahagi T, Nagao M, Seino Y, . 1977. Mutagenicities of N-nitrosamines on Salmonella. Mutat Res 48:121–130.406555
*Yamazaki H, Mori Y, Toyoshi K, . 1985. Genotoxicity of carcinogenic N-nitrosopropylamine derivatives in the hepatocyte primary culture/DNA repair test. Mutat Res 144:197–202.4058439