# VERSION HISTORY

Date | Description
February 2019 | Update of data in Chapters 2, 3, and 7
July 2010 | Addendum to the toxicological profile released
December 1989 | Final toxicological profile released