# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of N-nitrosodi-n-propylamine are listed in Table 4-1.

Table 4-1 Chemical Identity of Nitrosodi-n-Propylamine

Characteristic | Information | Reference
Chemical name | 1-Propanamine, N-nitroso-N-propyl | CAS 1988
Synonym(s) and registered trade name(s) | N-nitrosodipropylamine; N,N-dipropylnitrosamine; N-Nitroso-N-di-n-propylamine; NDPA; DPNA; DPN | HSDB 1988; SANSS 1988
Chemical formula | C_6_H_14_N_2_O | CAS 1988
Chemical structure | [image] | SANSS 1988
CAS Registry | 621-64-7 | CAS 1988

CAS = Chemical Abstracts Services

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of N-nitrosodi-n-propylamine are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of N-Nitrosodi-n-Propylamine

Property | Information | Reference
Molecular weight | 130.19 | Weast 1983
Color | Yellow | IARC 1978
Physical state | Liquid | IARC 1978
Melting point | 6.6°C (estimated) | Lyman 1985
Melting point | −12°C (estimated) | EPA 1986a
Boiling point | 206°C | Weast 1983
Density at 20°C | 0.9163 | Weast 1983
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 23–25°C | 9,894 mg/L | Mirvish et al. 1976
Organic solvents | Soluble in alcohol, ether, other organic solvents | IARC 1978; Weast 1983
Partition coefficients:
Log K_ow_ | 1.36 | Hansch and Leo 1985
Log K_oc_ | 2.11 (estimated) | Hansch and Leo 1985
Vapor pressure at 20°C | 0.086 mm Hg (estimated) | Klein 1982
Henry’s law constant at 20°C | 1.47×10^−6^ atm-m^3^/mole (estimated from vapor pressure and water solubility data)
Autoignition temperature | No data
Flashpoint | No data
Flammability limits in air | No data^a^
Conversion factors
ppm (v/v) to mg/m^3^ in air (20°C) | ppm (v/v)×5.41=mg/m^3^
mg/m^3^ to ppm (v/v) in air (20°C) | mg/m^3^×0.185=ppm (v/v)
Explosive limits

a Vapor probably does not form an explosive mixture with air at ordinary temperatures (OHM-TADS 1988).