# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## N-Nitrosodi-n-propylamine Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodi-n-propylamine
CAS Numbers: | 621-64-7
Date: | December 1989
Date: | March 2017 – Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies were identified.

Agency Contact (Chemical Manager): Malcolm Williams, DVM, Ph.D.

## N-Nitrosodi-n-propylamine Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodi-n-propylamine
CAS Numbers: | 621-64-7
Date: | December 1989
Date: | March 2017 – Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies were identified.

Agency Contact (Chemical Manager): Malcolm Williams, DVM, Ph.D.

## N-Nitrosodi-n-propylamine Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodi-n-propylamine
CAS Numbers: | 621-64-7
Date: | December 1989
Date: | March 2017 – Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified.

Agency Contact (Chemical Manager): Malcolm Williams, DVM, Ph.D.

## N-Nitrosodi-n-propylamine Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodi-n-propylamine
CAS Numbers: | 621-64-7
Date: | February 2019
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The acute-duration oral database was not considered suitable for identifying the most sensitive target of toxicity.

There are limited data on the acute toxicity of N-nitrosodi-n-propylamine. In an acute lethality study, hepatic centrilobular necrosis and fatty degeneration were observed (Druckery et al. 1967); although the doses tested were not reported, the LD_50_ was 480 mg/kg/day. Hepatocellular necrosis was observed in rats administered via gavage 10 mg/kg/day for 14 days (Terashima et al. 2015). At 20 and 40 mg/kg/day, hepatocellular necrosis, hypertrophy, and vacuolation and centrilobular inflammation were observed. A 4-day gavage administration of 40 mg/kg/day N-nitrosodi-n-propylamine resulted in hepatocellular swelling and increases in pentobarbital sleep time in mice (Nishie et al. 1972). No alterations in serum aspartate aminotransferase, lactate dehydrogenase, or γ-glutamyl transferase were observed in mice administered 9.5 mg/kg/day via drinking water for 1 week (Tyndall et al. 1978); this study did not include a histological examination. The database was not considered adequate for deriving an MRL because the available acute duration studies only examined the liver and body weight endpoints; and there is uncertainty as to whether the liver would be the most sensitive target of toxicity.

Agency Contact (Chemical Manager): Malcolm Williams, DVM, Ph.D.

## N-Nitrosodi-n-propylamine Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodi-n-propylamine
CAS Numbers: | 621-64-7
Date: | December 1989
Date: | March 2017 – Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No intermediate-duration oral studies examining noncancer endpoints were identified.

Agency Contact (Chemical Manager): Malcolm Williams, DVM, Ph.D.

## N-Nitrosodi-n-propylamine Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | N-Nitrosodi-n-propylamine
CAS Numbers: | 621-64-7
Date: | December 1989
Date: | March 2017 – Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No chronic-duration oral studies were identified.

Agency Contact (Chemical Manager): Malcolm Williams, DVM, Ph.D.