# CHAPTER 8 REFERENCES

Abdollahi M, Mohammadirad A. 2014. Nitrophenol, 4-. In: Wexler P, ed. Encyclopedia of toxicology. 3^rd^ ed. Oxford: Academic Press, 575–577. 10.1016/B978-0-12-386454-3.01143-X.
Abu-Qare AW, Brownie CF, Abou-Donia MB. 2000. Placental transfer and pharmacokinetics of a single oral dose of [14C]p-nitrophenol in rats. Arch Toxicol 74(7):388–396. 10.1007/s002040000133.11043494
Adhya TK, Sudhakar B, Sethunathan N. 1981. Hydrolysis of selected organophosphorus insecticides by two bacteria isolated from flood soil. J Appl Bacteriol 50(1):167–172. 10.1111/j.1365-2672.1981.tb00881.x.7228819
Adler B, Braun R, Schöneich J, . 1976. Repair-defective mutants of Proteus mirabilis as a prescreening system for the detection of potential carcinogens. Biol Zent Bl 95:463–469.
Aelion CM, Swindoll CM, Pfaender FK. 1987. Adaptation to and biodegradation of xenobiotic compounds by microbial communities from a pristine aquifer. Appl Environ Microbiol 53(9):2212–2217. 10.1128/aem.53.9.2212-2217.1987.3314709
Alexander M, Lustigman BK. 1966. Effect of chemical structure on microbial degradation of substituted benzenes. J Agric Food Chem 14(4):410–413. 10.1021/jf60146a022.
Amacher DE, Turner GN. 1982. Mutagenic evaluation of carcinogens and non-carcinogens in the L5178Y/TK assay utilizing postmitochondrial fractions (S9) from normal rat liver. Mutat Res 97(1):49–65. 10.1016/0165-1161(82)90019-x.7057798
Ashurst JV, Wasson MN, Hauger W, . 2010. Pathophysiologic mechanisms, diagnosis, and management of dapsone-induced methemoglobinemia. J Am Osteopath Assoc 110(1):16–20. 10.7556/jaoa.2010.110.1.16.20093649
Atkinson R. 1986. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 86(1):69–201. 10.1021/cr00071a004.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2018. Guidance for the preparation of toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/guidance/profile_development_guidance.pdf. December 30, 2022.
ATSDR. 2019. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Bannan TJ, Booth AM, Jones BT, . 2017. Measured saturation vapor pressures of phenolic and nitro-aromatic compounds. Environ Sci Technol 51(7):3922–3928. 10.1021/acs.est.6b06364.28263597
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barr DB, Turner WE, DiPietro E, . 2002. Measurement of p-nitrophenol in the urine of residents whose homes were contaminated with methyl parathion. Environ Health Perspect 110(Suppl 6):1085–1091. 10.1289/ehp.02110s61085.12634145
Battaglia C, Salvatori M, Maxia N, . 1999. Adjuvant L-arginine treatment for in-vitro fertilization in poor responder patients. Hum Reprod 14(7):1690–1697. 10.1093/humrep/14.7.1690.10402369
Battersby NS, Wilson V. 1989. Survey of the anaerobic biodegradation potential of organic chemicals in digesting sludge. Appl Environ Microbiol 55(2):433–439. 10.1128/aem.55.2.433-439.1989.16347851
Belloli R, Bolzacchini E, Clerici L, . 2006. Nitrophenols in air and rainwater. Environ Eng Sci 23(2):405–415. 10.1089/ees.2006.23.405.
Béranger R, Hardy EM, Dexet C, . 2018. Multiple pesticide analysis in hair samples of pregnant French women: Results from the ELFE national birth cohort. Environ Int 120:43–53. 10.1016/j.envint.2018.07.023.30064054
Béranger R, Hardy EM, Binter AC, . 2020. Multiple pesticides in mothers’ hair samples and children’s measurements at birth: Results from the French national birth cohort (ELFE). Int J Hyg Environ Health 223(1):22–33. 10.1016/j.ijheh.2019.10.010.31708466
Bingham E, Cohrssen B, Powell CH. 2001. Nitrophenols. In: Patty’s toxicology. Vol. 4. 5^th^ ed. New York, NY: John Wiley & Sons, 849.
Bingham NC, Verma-Kurvari S, Parada LF, . 2006. Development of a steroidogenic factor 1/Cre transgenic mouse line. Genesis 44(9):419–424. 10.1002/dvg.20231.16937416
Blok J, de Morsier A, Gerike P, . 1985. Harmonisation of ready biodegradability tests. Chemosphere 14(11–12):1805–1820. 10.1016/0045-6535(85)90123-7.
Bloom JC, Brandt JT. 1999. Toxic responses of the blood. In: Klassen CD, ed. Casarett and Doull’s toxicology: The basic science of poisons. 5^th^ ed. New York, NY: McGraw-Hill,
Boatman RJ, Cunningham SL, Ziegler DA. 1986. A method for measuring the biodegradation of organic chemicals. Environ Toxicol Chem 5(3):233–243. 10.1002/etc.5620050302.
Bojar RM, Rastegar H, Payne DD, . 1987. Methemoglobinemia from intravenous nitroglycerin: a word of caution. Ann Thorac Surg 43(3):332–334. 10.1016/s0003-4975(10)60627-3.3103557
Bonnefoy A, Chiron S, Botta A. 2012. Environmental nitration processes enhance the mutagenic potency of aromatic compounds. Environ Toxicol 27(6):321–331. 10.1002/tox.20644.20737582
Borisover MD, Graber ER. 1997. Specific interactions of organic compounds with soil organic carbon. Chemosphere 34(8):1761–1776. 10.1016/s0045-6535(97)00032-5.
Bourquin AW. 1984. Biodegradation in the estuarine-marine environments and the genetically altered microbe. Basic Life Sci 28:97–115. 10.1007/978-1-4684-4715-6_7.6704077
Bourquin AW, Spain JC, Pritchard PH. 1982. Microbial degradation of xenobiotic compounds. Proceedings of the twelfth conference on environmental toxicology 3, 4, and 5 November 1981. Dayton, OH: Air Force Aerospace Medical Research Lab. 354–369. AFMRL-TR-81–149. ADA115900.
Boutwell RK, Bosch DK. 1959. The tumor-promoting action of phenol and related compounds for mouse skin. Cancer Res 19(4):413–424.13652126
Boyd SA. 1982. Adsorption of substituted phenols by soil. Soil Sci 134(5):337–343.
Boyd SA, Shelton DR, Berry D, . 1983. Anaerobic biodegradation of phenolic compounds in digested sludge. Appl Environ Microbiol 46(1):50–54. 10.1128/aem.46.1.50-54.1983.6614908
Branch D, Stout LD, Folk RM. 1983a. Acute dermal toxicity of p-nitrophenol to rabbits. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8. OTS0518155. 86-890000359.
Branch D, Stout LD, Folk RM. 1983b. Acute oral toxicity of p-nitrophenol to rats. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8. OTS0518152. 86-890000358. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0518152.xhtml. December 30, 2022.
Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5(1):1–30. 10.1089/hwm.1988.5.1.
Buckley JP, Kuiper JR, Bennett DH, . 2022. Exposure to contemporary and emerging chemicals in commerce among pregnant women in the United States: The Environmental influences on Child Health Outcome (ECHO) Program. Environ Sci Technol 56(10):6560–6573. 10.1021/acs.est.1c08942.35536918
Budavari S. 1996. m-Nitrophenol, o-Nitrophenol, p-Nitrophenol. In: The Merck index - An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station, NJ: Merck and Co., Inc., 1137.
Buselmaier W, Röhrborn G, Propping P. 1973. Comparative investigations on the mutagenicity of pesticides in mammalian test systems. Mutat Res 21(1):25–26.
Call DJ, Brooke LT, Lu PY. 1980. Uptake, elimination, and metabolism of three phenols by fathead minnows. Arch Environ Contam Toxicol 9(6):699–714. 10.1007/BF01055545.7469481
Cameron MA. 1958. The action of nitrophenols on the metabolic rate of rats. Br J Pharmacol 13(1):25–29. 10.1111/j.1476-5381.1958.tb00185.x.
CDC. 2020. National Health and Nutrition Examination Survey. 2013-2014 data documentation, codebook, and frequencies. Pyrethroids, herbicides, & organophosphorus metabolites - urine (UPHOPM_H). Centers for Disease Control and Prevention. https://wwwn.cdc.gov/Nchs/Nhanes/2013-2014/UPHOPM_H.htm. September 21, 2020.
Cecinato A, Di Palo V, Pomata D, . 2005. Measurement of phase-distributed nitrophenols in Rome ambient air. Chemosphere 59(5):679–683. 10.1016/j.chemosphere.2004.10.045.15792665
Chambers CW, Tabak HH, Kabler PW. 1963. Degradation of aromatic compounds by phenol-adapted bacteria. J Water Pollut Control Fed 35(12):1517–1528.
Chen J, Song M, Li Y, . 2016. The effect of phytosterol protects rats against 4-nitrophenol-induced liver damage. Environ Toxicol Pharmacol 41:266–271. 10.1016/j.etap.2015.12.011.26748050
Chiu CW, Lee LH, Wang CY, . 1978. Mutagenicity of some commercially available nitro compounds for Salmonella typhimurium. Mutat Res 58(1):11–22. 10.1016/0165-1218(78)90090-3.362191
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
Degirmenci E, Ono Y, Kawara O, . 2000. Genotoxicity analysis and hazardousness prioritization of a group of chemicals. Water Sci Technol 42(7–8):125–131. 10.2166/wst.2000.0560.
Delhomme O, Morville S, Millet M. 2010. Seasonal and diurnal variations of atmospheric concentrations of phenols and nitrophenols measured in the Strasbourg area, France. Atmos Pollut Res 1(1):16–22. 10.5094/apr.2010.003.
Dellarco VL, Prival MJ. 1989. Mutagenicity of nitro compounds in Salmonella typhimurium in the presence of flavin mononucleotide in a preincubation assay. Environ Mol Mutagen 13(2):116–127. 10.1002/em.2850130206.2645131
Dobson KR, Stephenson M, Greenfield PF, . 1985. Identification and treatability of organics in oil shale retort water. Water Res 19(7):849–856. 10.1016/0043-1354(85)90142-3.
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Dzengel J, Theurich J, Bahnemann DW. 1999. Formation of nitroaromatic compounds in advanced oxidation processes: Photolysis versus photocatalysis. Environ Sci Technol 33(2):294–300. 10.1021/es980358j.
ECETOC. 1984. The phototransformation of chemicals in water: Results of a ring-test. Brussels, Belgium: European Chemical Industry, Ecology and Toxicology Center. Technical Report No. 12. https://www.ecetoc.org/wp-content/uploads/2021/10/ECETOC-TR-012.pdf. December 30, 2022.
Eichenbaum G, Johnson M, Kirkland D, . 2009. Assessment of the genotoxic and carcinogenic risks of p-nitrophenol when it is present as an impurity in a drug product. Regul Toxicol Pharmacol 55(1):33–42. 10.1016/j.yrtph.2009.05.018.19500632
Ellis DD, Jone CM, Larson RA, . 1982. Organic constituents of mutagenic secondary effluents from wastewater treatment plants. Arch Environ Contam Toxicol 11(3):373–382. 10.1007/BF01055214.7103563
EPA. 1980. Ambient water quality criteria for nitrophenols. Washington, DC: U.S. Environmental Protection Agency. EPA440580063. https://www.epa.gov/sites/default/files/201903/documents/ambient-wqc-nitrophenols-1980.pdf. January 3, 2023.
EPA. 1981a. Treatability manual. Volume. 1. Treatability data. Washington, DC: U.S. Environmental Protection Agency. 1.8.6-3, 1.8.7-3. EPA600282001a. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30005R3P.txt. January 3, 2023.
EPA. 1981b. Engineering handbook for hazardous waste incineration. Washington, DC: U.S. Environmental Protection Agency. SW889. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000KAVZ.txt. January 3, 2023.
EPA. 1984. Method 625: Base/neutrals and acids. Appendix A to Part 136: Methods for organic chemical analysis of municipal and industrial wastewater. U.S. Environmental Protection Agency.
EPA. 1985a. Health and environmental effects profile for nitrophenols. Final draft. Cincinnati, OH: U.S. Environmental Protection Agency. PB88180450.
EPA. 1985b. Chemical composition of drum samples from hazardous waste sites. Denver, CO: U.S. Environmental Protection Agency. EPA331R85001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101XQVV.txt.
EPA. 1990a. Data evaluation record: In vitro cytogenetic testing on 4-nitrophenol employing the chromosome aberration assay in Chinese hamster ovary cells, MRID number: 422709-01. U.S. Environmental Protection Agency.
EPA. 1990b. Data evaluation record: In vitro mutagenicity tests on p-nitrophenol and ClC4 employing the Salmonella/Ames assay test system, MRID number: 421748-01. U.S. Environmental Protection Agency. 42174801.
EPA. 1990c. Data evaluation record: L5178Y TK+/- mouse lymphoma mutagenesis assay, MRID number: 422710-01. U.S. Environmental Protection Agency.
EPA. 1991. Alpha 2u-globulin: Association with chemically induced renal toxicity and neoplasia in the male rat. Washington, DC: U.S. Environmental Protection Agency. EPA625391019F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=3000480X.txt. November 3, 2022.
EPA. 1992a. Data evaluation record: Effect of paranitrophenol on the embryonic development of rats, MRID 42788601. U.S. Environmental Protection Agency.
EPA. 1992b. Data evaluation record: Primary eye irritation of paranitrophenol in rabbits, MRID No: 425398-01. U.S. Environmental Protection Agency.
EPA. 1998. Method 8270D: Semivolatile organic compounds by gas chromatography/mass spectrometry (GC/MS). U.S. Environmental Protection Agency.
EPA. 2000a. Method 528: Determination of phenols in drinking water by solid phase extraction and capillary column gas chromatography/mass spectrometry (GC/MS). U.S. Environmental Protection Agency. https://cfpub.epa.gov/si/si_public_file_download.cfm?p_download_id=525081&Lab=NERL. January 3, 2023.
EPA. 2000b. R.E.D. facts: Ethyl parathion. U.S. Environmental Protection Agency. EPA738F00009. https://www3.epa.gov/pesticides/chem_search/reg_actions/reregistration/fs_PC-057501_1-Sep-00.pdf. November 7, 2022.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2019_rfi.pdf. January 3, 2023.
EPA. 2007a. Method 8041A: Phenols by gas chromatography. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-12/documents/8041a.pdf. January 3, 2023.
EPA. 2007b. Provisional peer reviewed toxicity values for 2-nitrophenol (CASRN 88-75-5). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R07023F. https://cfpub.epa.gov/ncea/pprtv/documents/Nitrophenol2.pdf. November 7, 2022.
EPA. 2009a. Toxicological review of nitrobenzene (CAS No. 98-95-3) Washington, DC: U.S. Environmental Protection Agency. EPA635R08004F. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0079tr.pdf. November 7, 2022.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. August 2, 2019.
EPA. 2016. 2016 Chemical data reporting results. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. December 15, 2020.
EPA. 2017. National emission inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. October 20, 2022.
EPA. 2018a. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018b. 2018 edition of the drinking water standards and health advisories tables. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. January 3, 2023.
EPA. 2020a. Electroplating point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413. https://www.ecfr.gov/cgi-bin/text-idx?SID=9b2ad535d533c8e67ed84ba64ff900de&mc=true&node=pt40.31.413&rgn=div5. December 18, 2020.
EPA. 2020b. Electrical and electronic components point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 469. https://www.ecfr.gov/cgi-bin/textidx?SID=9b2ad535d533c8e67ed84ba64ff900de&mc=true&node=pt40.32.469&rgn=div5. December 18, 2020.
Fazzalari FA. 1978. Compilation of odor and taste threshold values data. In: ASTM Data Series DS 48A (Committee E-18). Philadelphia, PA: American Society for Testing and Materials,
FDA. 2006. 2004-2005 Summary of pesticide residues and industrial chemicals found in TDS foods - sorted by pesticide/chemical. Food and Drug Administration. https://www.fda.gov/media/83172/download. October 26, 2020.
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Fenske RA, Lu C, Barr D, . 2002. Children’s exposure to chlorpyrifos and parathion in an agricultural community in central Washington State. Environ Health Perspect 110(5):549–553. 10.1289/ehp.02110549.12003762
Fernández SF, Pardo O, Adam-Cervera I, . 2020. Biomonitoring of non-persistent pesticides in urine from lactating mothers: Exposure and risk assessment. Sci Total Environ 699:134385. 10.1016/j.scitotenv.2019.134385.31678881
Figge K, Klahn J, Koch J. 1983. Testing of chemicals by evaluation of their distribution and degradation patterns in an environmental standard system. Regul Toxicol Pharmacol 3(3):199–215. 10.1016/0273-2300(83)90028-4.6635268
Freitag D, Geyer H, Kraus A, . 1982. Ecotoxicological profile analysis. VII. Screening chemicals for their environmental behavior by comparative evaluation. Ecotoxicol Environ Saf 6(1):60–81. 10.1016/0147-6513(82)90081-1.6802631
Garrett NE, Lewtas J. 1983. Cellular toxicity in Chinese hamster ovary cell cultures. I. Analysis of cytotoxicity endpoints for twenty-nine priority pollutants. Environ Res 32(2):455–465. 10.1016/0013-9351(83)90125-1.6641673
Gawlik BM, Feicht EA, Karcher W, . 1998. Application of the European reference soil set (EUROSOILS) to a HPLC-screening method for the estimation of soil adsorption coefficients of organic compounds. Chemosphere 36(14):2903–2919. 10.1016/s0045-6535(97)10247-8.
Gerike P, Fischer WK. 1979. A correlation study of biodegradability determinations with various chemicals in various tests. Ecotoxicol Environ Saf 3(2):159–173. 10.1016/0147-6513(79)90009-5.120246
Geyer H, Politzki G, Freitag D. 1984. Prediction of ecotoxicological behaviour of chemicals: Relationship between n-octanol/water partition coefficient and bioaccumulation of organic chemicals by alga Chlorella. Chemosphere 13(2):269–284.
Grant CM. 1959. The action of nitrophenols on the pulmonary ventilation of rats. Br J Pharmacol 14:401–403. 10.1111/j.1476-5381.1959.tb00265.x.
Güsten H, Klasinc L, Marić D. 1984. Prediction of the abiotic degradability of organic compounds in the troposphere. J Atmos Chem 2(1):83–93. 10.1007/BF00127264.
Haller HD. 1978. Degradation of mono-substituted benzoates and phenols by wastewater. J Water Pollut Control Fed 50(12):2771–2777.
Hansch C, Leo A, Hoekman D. 1995. o-Nitrophenol and p-nitrophenol. In: Exploring QSAR - Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 18.
Harrison MAJ, Cape JN, Heal MR. 2002. Experimentally determined Henry’s Law coefficients of phenol, 2-methylphenol and 2-nitrophenol in the temperature range 281–302K. Atmos Environ 36(11):1843–1851. 10.1016/s1352-2310(02)00137-1.
Harrison MAJ, Barra S, Borghesi D, . 2005. Nitrated phenols in the atmosphere: a review. Atmos Environ 39(2):231–248. 10.1016/j.atmosenv.2004.09.044.
Hartmann A, Speit G. 1997. The contribution of cytotoxicity to DNA-effects in the single cell gel test (comet assay). Toxicol Lett 90(2–3):183–188. 10.1016/s0378-4274(96)03847-7.9067486
Hattori M, Tabata S. 2006. Nitric oxide and ovarian function. Anim Sci J 77(3):275–284. 10.1111/j.1740-0929.2006.00349.x.
Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2(3):249–271. 10.1007/BF00394456.24264296
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5 Suppl 1:1–142. 10.1002/em.2860050703.
Haynes WM, Lide DR, Bruno TJ. 2015. Physical constants of organic compounds. In: CRC handbook of chemistry and physics. 95^th^ ed. Boca Raton, FL: CRC Press Inc., 3–414.
Hazleton. 1983. Subacute dust inhalation toxicity study in rats with p-nitrophenol (final report) with attachments and cover letter dated 060889. Monsanto Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8. OTSO520433. 86-890000362. HLA study no. 82-242.
Hazleton. 1984. Initial submission: Subacute inhalation toxicity study in rats with o-nitrophenol with cover letter dated 080792. Monsanto Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. 88-920007617. OTS0545809. 88-920007617. 8EHQ-0892-9294.
Hazleton. 1989. Subchronic toxicity study in rats with paranitrophenol (final report) with cover letter. Monsanto Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 4. OTS0526338. 40-8915314. 42088A H1-37. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0526338.xhtml. January 3, 2023.
Heimbuch JA, Wilhelmi AR. 1985. Wet air oxidation - A treatment means for aqueous hazardous waste streams. J Hazard Mater 12(2):187–200. 10.1016/0304-3894(85)85006-8.
Ho YL, Ho SK. 1981. Screening of carcinogens with the prophage lambda cIts857 induction test. Cancer Res 41(2):532–536.6449995
Hodson J, Williams NA. 1988. The estimation of the adsorption coefficient (Koc) for soils by high performance liquid chromatography. Chemosphere 17(1):67–77. 10.1016/0045-6535(88)90045-8.
Hollman PCH, Hertog MGL, Katan MB. 1996. Analysis and health effects of flavonoids. Food Chem 57(1):43–46. 10.1016/0308-8146(96)00065-9.
Hoover DG, Borgonovi GE, Jones SH, . 1986. Anomalies in mineralization of low concentrations of organic compounds in lake water and sewage. Appl Environ Microbiol 51(2):226–232. 10.1128/aem.51.2.226-232.1986.3954341
Horowitz A, Shelton DR, Cornell CP, . 1982. Anaerobic degradation of aromatic compounds in sediment and digested sludge. Develop Ind Microbiol 23:435–444.
Hughes MF, Hall LL. 1997. In vivo disposition of p-substituted phenols in the young rat after intraperitoneal and dermal administration. Food Chem Toxicol 35(7):697–704. 10.1016/s0278-6915(97)00035-5.9301654
Hustert K, Mansour M, Parlar H. 1981. [The EPA test: A method to determine the photochemical degradation of organic compounds in aqueous systems]. Chemosphere 10:995–998. (German)
IARC. 2022. Agents classified by the IARC Monographs, volumes 1-132. International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. October 26, 2022.
Iglesias-González A, Schaeffer C, Dahm G, . 2021. Comprehensive assessment of local population chemical exposome by combination of organic pollutant- and metal-multi-residue analysis in hair. Exposure and Health 14(3):685–712. 10.1007/s12403-021-00444-2.
Ingerslev F, Nyholm N. 2000. Shake-flask test for determination of biodegradation rates of (14)C-labeled chemicals at low concentrations in surface water systems. Ecotoxicol Environ Saf 45(3):274–283. 10.1006/eesa.1999.1877.10702347
Inomata S, Fushimi A, Sato K, . 2015. 4-Nitrophenol, 1-nitropyrene, and 9-nitroanthracene emissions in exhaust particles from diesel vehicles with different exhaust gas treatments. Atmos Environ 110:93–102. 10.1016/j.atmosenv.2015.03.043.
Inomata S, Yamada H, Tanimoto H. 2016. Investigation on VOC emissions from automobile sources by means of online mass spectrometry. Curr Pollut Rep 2(3):188–199. 10.1007/s40726-016-0032-6.
IRIS. 2002. Chemical assessment summary: p-Nitrophenol; CASRN 100-02-7. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0360_summary.pdf. October 17, 2022.
Isnard P, Lambert S. 1988. Estimating bioconcentration factors from octanol-water partition coefficient and aqueous solubility. Chemosphere 17(1):21–34. 10.1016/0045-6535(88)90040-9.
Jones SH, Alexander M. 1986. Kinetics of mineralization of phenols in lake water. Appl Environ Microbiol 51(5):891–897. 10.1128/aem.51.5.891-897.1986.3755316
Jones SH, Alexander M. 1988. Effect of inorganic nutrients on the acclimation period preceding mineralization of organic chemicals in lake water. Appl Environ Microbiol 54(12):3177–3179. 10.1128/aem.54.12.3177-3179.1988.3223773
Kavlock RJ. 1990. Structure-activity relationships in the developmental toxicity of substituted phenols: in vivo effects. Teratology 41(1):43–59. 10.1002/tera.1420410106.2305374
Kincannon DF, Esfandi A. 1981. Performance comparison of activated sludge, PAC activated sludge, granular activated carbon and a resin column for removing priority pollutants from a pharmaceutical wastewater. In: Proceedings of the 35^th^ Industrial Waste Conference, May 13, 14 and 15, 1980, Purdue University Lafayette, Indiana. Ann Arbor, MI: Ann Arbor Science, 476–483.
Kincannon DF, Lin YS. 1985. Microbial degradation of hazardous wastes by land treatment. In: Proceedings of the 40th Industrial Waste Conference, May 14, 15, 16, 1985, Purdue University, West Lafayette, Indiana. Boston, MA: Butterworths, 607–620.
Kissel JC, Curl CL, Kedan G, . 2005. Comparison of organophosphorus pesticide metabolite levels in single and multiple daily urine samples collected from preschool children in Washington State. J Expo Anal Environ Epidemiol 15(2):164–171. 10.1038/sj.jea.7500384.15187987
Kitanovski Z, Hovorka J, Kuta J, . 2020. Nitrated monoaromatic hydrocarbons (nitrophenols, nitrocatechols, nitrosalicylic acids) in ambient air: levels, mass size distributions and inhalation bioaccessibility. Environ Sci Pollut Res Int 28(42):59131–59140. 10.1007/s11356-020-09540-3.32529617
Klán P, Holoubek I. 2002. Ice (photo)chemistry. Ice as a medium for long-term (photo)chemical transformations-environmental implications. Chemosphere 46(8):1201–1210. 10.1016/s0045-6535(01)00285-5.11951987
Koizumi M, Yamamoto Y, Ito Y, . 2001. Comparative study of toxicity of 4-nitrophenol and 2,4-dinitrophenol in newborn and young rats. J Toxicol Sci 26(5):299–311. 10.2131/jts.26.299.11871126
Kool HJ. 1984. Influence of microbial biomass on the biodegradability of organic compounds. Chemosphere 13(7):751–761. 10.1016/0045-6535(84)90178-4.
Korte F, Klein W. 1982. Degradation of benzene in the environment. Ecotoxicol Environ Saf 6(4):311–327. 10.1016/0147-6513(82)90046-x.7117183
Kotzias D, Herrmann M, Zsolnay A, . 1986. Photochemical reactivity of humic materials. Naturwissenschaften 73(1):35–36. 10.1007/BF01168804.
Krishnan K, Clewell HJ, Andersen ME. 1994. Physiologically based pharmacokinetic analyses of simple mixtures. Environ Health Perspect 102(Suppl 9):151–155. 10.1289/ehp.94102s9151.
Kudale S, Sethi SK, Dhaliwal M, . 2014. Methemoglobinemia due to quinine causing severe acute kidney injury in a child. Indian J Nephrol 24(6):394–396. 10.4103/0971-4065.134681.25484537
Laughlin KA, Schardein JL, Blair M. 1983. Range-finding teratology study in rats with cover letter and summary. International Research and Development Corporation. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. IR-83-100. OTS0526380. 88-900000151. 8EHQ-0590-0978.
Lawford DJ, King E, Harvey DG. 1954. On the metabolism of some aromatic nitro-compounds by different species of animal. II. The elimination of various nitro-compounds from the blood of different species of animal. J Pharm Pharmacol 6(9):619–624. 10.1111/j.20427158.1954.tb10995.x.13192621
Lemaire J, Guth JA, Klais O, . 1985. Ring test of a method for assessing the phototransformation of chemicals in water. Chemosphere 14(1):53–77. 10.1016/0045-6535(85)90041-4.
Leuenberger C, Ligocki MP, Pankow JF. 1985. Trace organic compounds in rain. 4. Identities, concentrations, and scavenging mechanisms for phenols in urban air and rain. Environ Sci Technol 19(11):1053–1058. 10.1021/es00141a005.22288749
Leuenberger C, Czuczwa J, Tremp J, . 1988. Nitrated phenols in rain: Atmospheric occurrence of phytotoxic pollutants. Chemosphere 17(3):511–515. 10.1016/0045-6535(88)90026-4.
Lewis RJ. 2007. [m-Nitrophenol, o-nitrophenol, p-nitrophenol]. In: Hawley’s condensed chemical dictionary. 15^th^ ed. New York, NY: John Wiley & Sons, Inc., 898–899.
Li AJ, Kannan K. 2018. Urinary concentrations and profiles of organophosphate and pyrethroid pesticide metabolites and phenoxyacid herbicides in populations in eight countries. Environ Int 121(Pt 2):1148–1154. 10.1016/j.envint.2018.10.033.
Li C, Taneda S, Suzuki AK, . 2006. Estrogenic and anti-androgenic activities of 4-nitrophenol in diesel exhaust particles. Toxicol Appl Pharmacol 217(1):1–6. 10.1016/j.taap.2006.06.010.16884752
Li R, Song M, Li Z, . 2017. 4-Nitrophenol exposure alters the AhR signaling pathway and related gene expression in the rat liver. J Appl Toxicol 37(2):150–158. 10.1002/jat.3332.27172127
Li Y, Wang X, Toms LL, . 2019. Pesticide metabolite concentrations in Queensland pre-schoolers - Exposure trends related to age and sex using urinary biomarkers. Environ Res 176:108532. 10.1016/j.envres.2019.108532.31226627
Li M, Wang X, Lu C, . 2020. Nitrated phenols and the phenolic precursors in the atmosphere in urban Jinan, China. Sci Total Environ 714:136760. 10.1016/j.scitotenv.2020.136760.31982756
Loehr RC, Krishnamoorthy R. 1988. Terrestrial bioaccumulation potential of phenolic compounds. Haz Waste Haz Mater 5:109–128. 10.1089/hwm.1988.5.109.
Løkke H. 1985. Degradation of 4-nitrophenol in two Danish soils. Environ Pollut Ser A Ecol Biol 38(2):171–181. 10.1016/0143-1471(85)90075-3.
López-Gálvez N, Wagoner R, Beamer P, . 2018. Migrant farmworkers’ exposure to pesticides in Sonora, Mexico. Int J Environ Res Public Health 15(12) 10.3390/ijerph15122651.
Lu C, Wang X, Dong S, . 2019. Emissions of fine particulate nitrated phenols from various on-road vehicles in China. Environ Res 179(Pt A):108709. 10.1016/j.envres.2019.108709.31479872
Machida M, Morita Y, Hayashi M, . 1982. Pharmacokinetic evidence for the occurrence of extrahepatic conjugative metabolism of p-nitrophenol in rats. Biochem Pharmacol 31(5):787–791. 10.1016/0006-2952(82)90464-6.7082347
Mahmood N, Khan MU, Haq IUL, . 2019. A case of dapsone induced methemoglobinemia. J Pharm Policy Pract 12:22. 10.1186/s40545-019-0185-y.31249693
Marshall JB, Ecklund RE. 1980. Methemoglobinemia from overdose of nitroglycerin. JAMA 244(4):330. 10.1001/jama.1980.03310040014005.
McCormick NG, Feeherry FE, Levinson HS. 1976. Microbial transformation of 2,4,6-trinitrotoluene and other nitroaromatic compounds. Appl Environ Microbiol 31(6):949–958. 10.1128/aem.31.6.949-958.1976.779650
Means JL, Anderson SJ. 1981. Comparison of five different methods for measuring biodegradability in aqueous environments. Water Air Soil Pollut 16(3):301–315. 10.1007/BF01046911.
Meerman JH, Nijland C, Mulder GJ. 1987. Sex differences in sulfation and glucuronidation of phenol, 4-nitrophenol and N-hydroxy-2-acetylaminofluorene in the rat in vivo. Biochem Pharmacol 36(16):2605–2608. 10.1016/0006-2952(87)90538-7.3606659
Mi Y, Tu L, Wang H, . 2013. Supplementation with quercetin attenuates 4-nitrophenol-induced testicular toxicity in adult male mice. Anat Rec 296(10):1650–1657. 10.1002/ar.22765.
Monsanto. 1983a. Primary eye irritation of p-nitrophenol to rabbits with attachments and cover letter date 060889. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0518154. 86-890000360.
Monsanto. 1983b. Primary skin irritation of p-nitrophenol to rabbits with attachments and cover letter date 060889. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0518155. 86-890000361.
Monsanto. 1984. Primary skin irritancy and Department of Transportation (DOT) skin corrosivity test of p-nitrophenol in rabbits with attachments and cover letter dated 060889. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0518156. 86-890000363. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0518156.xhtml. October 21, 2022.
Naoum PC. 2012. Methemoglobinemia in children: how to explain the results? Rev Bras Hematol Hemoter 34(1):5. 10.5581/1516-8484.20120003.23049373
Nappe TM, Pacelli AM, Katz K. 2015. An atypical case of methemoglobinemia due to self-administered benzocaine. Case Rep Emerg Med 2015:670979. 10.1155/2015/670979.25874137
NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy Press. 15–35. https://www.ncbi.nlm.nih.gov/books/NBK218931/. January 3, 2023.
Neujahr HY, Lindsjo S, Varga JM. 1974. Oxidation of phenols by cells and cell-free enzymes from Candida tropicalis. Antonie Van Leeuwenhoek 40(2):209–216. 10.1007/BF00394378.4209029
NIOSH. 2018. Index of CAS no. In: NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health, https://www.cdc.gov/niosh/npg/npgdcas.html. September 28, 2020.
NLM. 2022a. Compound summary: 2-Nitrophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/2-Nitrophenol. November 3, 2022.
NLM. 2022b. Compound summary: 3-Nitrophenol. PubChem. U.S. National Library of Medicine: https://pubchem.ncbi.nlm.nih.gov/compound/3-Nitrophenol. November 3, 2022.
NLM. 2022c. Compound summary: 4-Nitrophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/4-Nitrophenol. November 3, 2022.
Nojima K, Ikarigawa T, Kanno S. 1980. Studies on photochemistry of aromatic hydrocarbons VI. Chemosphere 9(7–8):421–436. 10.1016/0045-6535(80)90026-0.
Nojima K, Fukaya K, Fukui S, . 1976. Studies on photochemistry of aromatic hydrocarbons III. Chemosphere 5(1):25–30. 10.1016/0045-6535(76)90052-7.
Nojima K, Kawaguchi A, Ohya T, . 1983. Studies on photochemical reaction of air pollutants. X. Identification of nitrophenols in suspended particulates. Chem Pharm Bull (Tokyo) 31(3):1047–1051. 10.1248/cpb.31.1047.
NTP. 1993. Toxicology and carcinogenesis studies of p-nitrophenol (CAS no. 100-02-7) in SwissWebster mice (dermal studies). National Toxicology Program. NTP TR 417. NIH Publ No. 93-3148. https://ntp.niehs.nih.gov/publications/reports/tr/400s/tr417/index.html?utm_source=direct&utm_medium=prod&utm_campaign=ntpgolinks&utm_term=tr417abs. January 3, 2023.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. January 3, 2023.
NTP. 2015a. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. January 3, 2023.
NTP. 2015b. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf. January 3, 2023.
NTP. 2021. CASRN index. In: Report on carcinogens. 15^th^ ed. National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
Oberly TJ, Bewsey BJ, Probst GS. 1984. An evaluation of the L5178Y TK+/- mouse lymphoma forward mutation assay using 42 chemicals. Mutat Res 125(2):291–306. 10.1016/0027-5107(84)90079-4.6700611
OHM/TADS. 1989. Oil and hazardous materials - Technical assistance data system. Washington, DC: U.S. Environmental Protection Agency.
O’Neil MJ. 2006. m-Nitrophenol, o-nitrophenol, p-nitrophenol. In: The Merck index - An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station, NJ: Merck and Co., Inc, 1145.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Özel MZ, Hamilton JF, Lewis AC. 2011. New sensitive and quantitative analysis method for organic nitrogen compounds in urban aerosol samples. Environ Sci Technol 45(4):1497–1505. 10.1021/es102528g.21210660
Paris DF, Wolfe NL, Steen WC, . 1983. Effect of phenol molecular structure on bacterial transformation rate constants in pond and river samples. Appl Environ Microbiol 45(3):1153–1155. 10.1128/aem.45.3.1153-1155.1983.16346236
Patterson JW, Kodukala PS. 1981. Biodegradation of hazardous organic pollutants. Chem Eng Prog 77:48–55.
Percy MJ, Lappin TR. 2008. Recessive congenital methaemoglobinaemia: cytochrome b(5) reductase deficiency. Br J Haematol 141(3):298–308. 10.1111/j.1365-2141.2008.07017.x.18318771
Perrone MG, Carbone C, Faedo D, . 2014. Exhaust emissions of polycyclic aromatic hydrocarbons, n-alkanes and phenols from vehicles coming within different European classes. Atmos Environ 82:391–400. 10.1016/j.atmosenv.2013.10.040.
Pitter P. 1976. Determination of biological degradability of organic substances. Water Res 10(3):231–235. 10.1016/0043-1354(76)90132-9.
Plasterer MR, Bradshaw WS, Booth GM, . 1985. Developmental toxicity of nine selected compounds following prenatal exposure in the mouse: naphthalene, p-nitrophenol, sodium selenite, dimethyl phthalate, ethylenethiourea, and four glycol ether derivatives. J Toxicol Environ Health 15(1):25–38. 10.1080/15287398509530633.3981663
Portier RJ. 1985. Comparison of environmental effect and biotransformation of toxicants on laboratory microcosm and field microbial communities. In: Boyle T, ed. Validation and predictability of laboratory methods for assessing the fate effects of contaminants in aquatic ecosystems. Philadelphia, PA: American Society for Testing and Materials, 14–30.
Price DP. 2011. Methemoglobin inducers. In: Nelson LS, Lewin NA, Howland MA, . eds. Goldfrank’s toxicologic emergencies. 9^th^ ed. The McGraw-Hill Companies 1698–1707.
Probst GS, McMahon RE, Hill LE, . 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: a comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3(1):11–32. 10.1002/em.2860030103.7021142
Qiao GL, Chang SK, Brooks JD, . 2000. Dermatotoxicokinetic modeling of p-nitrophenol and its conjugation metabolite in swine following topical and intravenous administration. Toxicol Sci 54(2):284–294. 10.1093/toxsci/54.2.284.10774810
Rashid KA, Mumma RO. 1986. Screening pesticides for their ability to damage bacterial DNA. J Environ Sci Health B 21(4):319–334. 10.1080/03601238609372527.3531299
Reinke LA, Moyer MJ. 1985. p-Nitrophenol hydroxylation. A microsomal oxidation which is highly inducible by ethanol. Drug Metab Dispos 13(5):548–552.2865101
RePORTER. 2022. Nitrophenols. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. October 28, 2022.
Rippen G, Zietz E, Frank R, . 1987. Do airborne nitrophenols contribute to forest decline? Environ Technol Lett 8(1–12):475–482. 10.1080/09593338709384508.
Robinson D, Smith JN, Williams RT. 1951a. Studies in detoxication. 39. Nitro compounds; (a) the metabolism of o-, m- and p-nitrophenols in the rabbit; (b) the glucuronides of the mononitrophenols and observations on the anomalous optical rotations of triacetyl beta-o-nitrophenyl glucuronide and its methyl ester. Biochem J 50(2):221–227. 10.1042/bj0500221.14904397
Robinson D, Smith JN, Williams RT. 1951b. Studies in detoxication. 40. The metabolism of nitrobenzene in the rabbit; o-, m- and p-nitrophenols, o-, m- and p-aminophenols and 4-nitrocatechol as metabolites of nitrobenzene. Biochem J 50(2):228–235. 10.1042/bj0500228.14904398
Roca M, Miralles-Marco A, Ferré J, . 2014. Biomonitoring exposure assessment to contemporary pesticides in a school children population of Spain. Environ Res 131:77–85. 10.1016/j.envres.2014.02.009.24657944
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rott B, Viswanathan R, Freitag D, . 1982. Comparative study of the applicability of various tests for determining the degradability of environmental chemicals. Chemosphere 11:531–538. 10.1016/0045-6535(82)90186-2. (German)
Rubin HE, Alexander M. 1983. Effect of nutrients on the rates of mineralization of trace concentrations of phenol and p-nitrophenol. Environ Sci Technol 17(2):104–107. 10.1021/es00108a008.22295962
Rubin HE, Subba-Rao RV, Alexander M. 1982. Rates of mineralization of trace concentrations of aromatic compounds in lake water and sewage samples. Appl Environ Microbiol 43(5):1133–1138. 10.1128/aem.43.5.1133-1138.1982.16346010
Rubio MA, Lissi E, Herrera N, . 2012. Phenol and nitrophenols in the air and dew waters of Santiago de Chile. Chemosphere 86(10):1035–1039. 10.1016/j.chemosphere.2011.11.046.22178376
Rubio MA, Bustamante P, Vásquez P Y. 2019. Atmospheric phenolic derivatives as tracers in an urban area. J Chilean Chem Soc 64(2):4407–4411. 10.4067/s0717-97072019000204407.
Rudel RA, Brody JG, Spengler JD, . 2001. Identification of selected hormonally active agents and animal mammary carcinogens in commercial and residential air and dust samples. J Air Waste Manag Assoc 51(4):499–513. 10.1080/10473289.2001.10464292.11321907
Schechter AN. 2008. Hemoglobin research and the origins of molecular medicine. Blood 112(10):3927–3938. 10.1182/blood-2008-04-078188.18988877
Schueuermann G, Klein W. 1988. Advances in biochemical prediction. Chemosphere 17:1551–1574.
Schüürmann G, Ebert RU, Kühne R. 2006. Prediction of the sorption of organic compounds into soil organic matter from molecular structure. Environ Sci Technol 40(22):7005–7011. 10.1021/es060152f.17154008
Scow KM, Simkins S, Alexander M. 1986. Kinetics of mineralization of organic compounds at low concentrations in soil. Appl Environ Microbiol 51(5):1028–1035. 10.1128/aem.51.5.1028-1035.1986.3729388
Scow KM, Schmidt SK, Alexander M. 1989. Kinetics of biodegradation of mixtures of substrates in soil. Soil Biol Biochem 21(5):703–708. 10.1016/0038-0717(89)90067-9.
Scully FE, Hoigné J. 1987. Rate constants for reactions of singlet oxygen with phenols and other compounds in water. Chemosphere 16(4):681–694. 10.1016/0045-6535(87)90004-x.
Shelton DR, Tiedje JM. 1984. General method for determining anaerobic biodegradation potential. Appl Environ Microbiol 47(4):850–857. 10.1128/aem.47.4.850-857.1984.6721493
Shimizu M, Yano E. 1986. Mutagenicity of mono-nitrobenzene derivatives in the Ames test and rec assay. Mutat Res 170(1–2):11–22. 10.1016/0165-1218(86)90077-7.3083245
Siragusa GR, Delaune RD. 1986. Mineralization and sorption of p-nitrophenol in estuarine sediment. Environ Toxicol Chem 5(2):175–178. 10.1002/etc.5620050208.
Sittig M. 1981. Nitrophenols. In: Handbook of toxic and hazardous chemicals. Park Ridge, NJ: Noyes Data Corporation, 332.
Smith LW, Hall GT, Kennedy GL. 1988. Acute and repeated dose inhalation toxicity of para-nitrophenol sodium salt in rats. Drug Chem Toxicol 11(3):319–327. 10.3109/01480548809017886.3181044
Snider EH, Manning FS. 1982. A survey of pollutant emission levels in wastewaters and residuals from the petroleum refining industry. Environ Int 7(4):237–258. 10.1016/0160-4120(82)90114-3.
Solomon GM, Hurley S, Carpenter C, . 2021. Fire and water: Assessing drinking water contamination after a major wildfire. ACS ES T Water 1(8):1878–1886. 10.1021/acsestwater.1c00129.34423333
Spain JC, Van Veld PA. 1983. Adaptation of natural microbial communities to degradation of xenobiotic compounds: effects of concentration, exposure time, inoculum, and chemical structure. Appl Environ Microbiol 45(2):428–435. 10.1128/aem.45.2.428-435.1983.16346193
Spain JC, Wyss O, Gibson DT. 1979. Enzymatic oxidation of p-nitrophenol. Biochem Biophys Res Commun 88(2):634–641. 10.1016/0006-291x(79)92095-3.37837
Spain JC, Pritchard PH, Bourquin AW. 1980. Effects of adaptation on biodegradation rates in sediment/water cores from estuarine and freshwater environments. Appl Environ Microbiol 40(4):726–734. 10.1128/aem.40.4.726-734.1980.16345646
Spain JC, Van Veld PA, Monti CA, . 1984. Comparison of p-nitrophenol biodegradation in field and laboratory test systems. Appl Environ Microbiol 48(5):944–950. 10.1128/aem.48.5.944-950.1984.16346668
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4(2):131–142. 10.1002/etc.5620040202.
Stone AT. 1987. Reductive dissolution of manganese(III/IV) oxides by substituted phenols. Environ Sci Technol 21(10):979–988. 10.1021/es50001a011.19994996
Stucke AG, Riess ML, Connolly LA. 2006. Hemoglobin M (Milwaukee) affects arterial oxygen saturation and makes pulse oximetry unreliable. Anesthesiology 104(4):887–888. 10.1097/00000542-200604000-00036.16571987
Stuehr DJ. 2004. Enzymes of the L-arginine to nitric oxide pathway. J Nutr 134(10 Suppl):2748S–2751S. 10.1093/jn/134.10.2748S.15465779
Suarez C, Louys F, Günther K, . 1970. OH-radical induced denitration of nitrophenols. Tetrahedron Lett 11(8):575–578. 10.1016/s0040-4039(01)97773-1.
Subba-Rao RV, Rubin HE, Alexander M. 1982. Kinetics and extent of mineralization of organic chemicals at trace levels in freshwater and sewage. Appl Environ Microbiol 43(5):1139–1150. 10.1128/aem.43.5.1139-1150.1982.16346011
Sudhakar B, Sethunathan N. 1978. Metabolism of nitrophenols in flooded soils. J Environ Qual 7(3):349–352. 10.2134/jeq1978.00472425000700030011x.
Sudhakar B, Siddaramappa R, Sethunathan N. 1976. Metabolism of nitrophenols by bacteria isolated from parathion-amended flooded soil. Antonie Van Leeuwenhoek 42(4):461–470. 10.1007/BF00410177.797317
Suzuki J, Koyama T, Suzuki S. 1983. Mutagenicities of mono-nitrobenzene derivatives in the presence of norharman. Mutat Res 120(2–3):105–110. 10.1016/0165-7992(83)90150-1.6341826
Swindoll CM, Aelion CM, Pfaender FK. 1988. Influence of inorganic and organic nutrients on aerobic biodegradation and on the adaptation response of subsurface microbial communities. Appl Environ Microbiol 54(1):212–217. 10.1128/aem.54.1.212-217.1988.3125792
Szybalski W. 1958. Special microbiological systems. II. Observations on chemical mutagenesis in microorganisms. Ann N Y Acad Sci 76(3):475–489. 10.1111/j.17496632.1958.tb57106.x.13627873
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53(10):1503–1518.
Tang J, Song M, Watanabe G, . 2016. Effects of 4-nitrophenol on expression of the ER-α and AhR signaling pathway-associated genes in the small intestine of rats. Environ Pollut 216:27–37. 10.1016/j.envpol.2016.05.040.27235926
Toker I, Yesilaras M, Tur FC, . 2015. Methemoglobinemia caused by dapsone overdose: Which treatment is best? Turk J Emerg Med 15(4):182–184. 10.1016/j.tjem.2014.09.002.27239625
Tremp J, Mattrel P, Fingler S, . 1993. Phenols and nitrophenols as tropospheric pollutants: Emissions from automobile exhausts and phase transfer in the atmosphere. Water Air Soil Pollut 68(1–2):113–123. 10.1007/bf00479396.
TRI21. 2022. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. August 2, 2022.
Tülp HC, Fenner K, Schwarzenbach RP, . 2009. pH-Dependent sorption of acidic organic chemicals to soil organic matter. Environ Sci Technol 43(24):9189–9195. 10.1021/es902272j.20000509
U.S. Army. 1983. Phase 1. Dermal penetration and distribution of 14C-labeled paranitrophenol (PNP). Aberdeen Proving Ground, MD: U.S. Army. ADA134315. Study No. 75-51-0047-84. https://apps.dtic.mil/sti/pdfs/ADA134315.pdf. January 3, 2023.
U.S. Army. 1985. Final phase effect of dermal applications of paranitrophenol on the reproductive functions of rats. Study no. 75-51-0047-85. September 1980 - March 1985. Aberdeen Proving Ground, MD: U.S. Army. ADA157120.
USITC. 2022. Nitrophenols. Dataweb. U.S. International Trade Commission. https://dataweb.usitc.gov/. November 3, 2022.
Vaishnav DD, Korthals ET. 1988. Comparison of chemical biodegradation rates in BOD dilution and natural waters. Bull Environ Contam Toxicol 41(2):291–298. 10.1007/BF01705445.3207911
Vernot EH, MacEwen JD, Haun CC, . 1977. Acute toxicity and skin corrosion data for some organic and inorganic compounds and aqueous solutions. Toxicol Appl Pharmacol 42:417–423. 10.1016/0041-008X(77)90019-9.595018
Vershueren K. 1983. m-Nitrophenol, o-Nitrophenol, p-Nitrophenol. In: Handbook of environmental data on organic chemicals. 2^nd^ ed. New York: Van Nostrand Reinhold Co., 917–920.
Villanueva JR. 1961. Organic nitro compounds reduced by Nocardia V. Microbiol Espanola 14:157–162.
Vione D, Maurino V, Minero C, . 2001. Phenol photonitration upon UV irradiation of nitrite in aqueous solution I: Effects of oxygen and 2-propanol. Chemosphere 45(6–7):893–902. 10.1016/s0045-6535(01)00035-2.11695611
Wei J, Lu T, Dong F, . 2021. Gene expression profiles of two testicular somatic cell lines respond differently to 4-nitrophenol mediating vary reproductive toxicity. Toxicology 463:152991. 10.1016/j.tox.2021.152991.34673133
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. World Health Organization. https://apps.who.int/iris/bitstream/handle/10665/254637/9789241549950eng.pdf;jsessionid=8AD40533ABAFCC37B8C6ABE4EFF2AC2F?sequence=1. November 7, 2022.
Wiggins BA, Alexander M. 1988. Role of chemical concentration and second carbon sources in acclimation of microbial communities for biodegradation. Appl Environ Microbiol 54(11):2803–2807. 10.1128/aem.54.11.2803-2807.1988.3214159
Wilderer P. 1981. A model river test to describe the various impacts of chemical substances on microbial biocommunities. AIChE Symp Ser 37:205–213.
Williams RT. 1938. Studies in detoxication: The influence of (a) dose and (b) o-, m- and p-substitution on the sulphate detoxication of phenol in the rabbit. Biochem J 32(5):878–887. 10.1042/bj0320878.16746699
Wise CF, Hammel SC, Herkert NJ, . 2022. Comparative assessment of pesticide exposures in domestic dogs and their owners using silicone passive samplers and biomonitoring. Environ Sci Technol 56(2):1149–1161. 10.1021/acs.est.1c06819.34964617
WQP. 2022. Nitrophenols. Water quality portal. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. October 13, 2022.
Wróbel K, Wróbel K, Madai Colunga Urbina E, . 2000. The determination of 3-nitrophenol and some other aromatic impurities in 4-nitrophenol by reversed phase HPLC with peak suppression diode array detection. J Pharm Biomed Anal 22(2):295–300. 10.1016/s0731-7085(99)00249-6.10719912
Wu J, Kaufman RJ. 2006. From acute ER stress to physiological roles of the Unfolded Protein Response. Cell Death Differ 13(3):374–384. 10.1038/sj.cdd.4401840.16397578
Xu WF, Li YS, Dai PY, . 2016. Potential protective effect of arginine against 4-nitrophenol-induced ovarian damage in rats. J Toxicol Sci 41(3):371–381. 10.2131/jts.41.371.27193729
Yalkowsky SH, He Y, Jain P. 2010. m-Nitrophenols. In: Handbook of aqueous solubility data. 2^nd^ ed. Boca Raton, FL: CRC Press, 22, 229.
Yoshida K, Shigeoka T, Yamauchi F. 1983. Non-steady-state equilibrium model for the preliminary prediction of the fate of chemicals in the environment. Ecotoxicol Environ Saf 7(2):179–190. 10.1016/0147-6513(83)90064-7.6851931
Young DR. 1978. Priority pollutants in municipal wastewaters. In: 1978 Annual report. South California Coastal Water Research Project, https://www.sccwrp.org/publications/annual-reports/1978-annual-report/. April 22, 2020.
Zaidi BR, Murakami Y, Alexander M. 1988. Factors limiting success of inoculation to enhance biodegradation of low concentrations of organic chemicals. Environ Sci Technol 22(12):1419–1425. 10.1021/es00177a005.22200467
Zaidi BR, Murakami Y, Alexander M. 1989. Predation and inhibitors in lake water affect the success of inoculation to enhance biodegradation of organic chemicals. Environ Sci Technol 23(7):859–863. 10.1021/es00065a016.
Zeyer J, Kearney PC. 1984. Degradation of o-nitrophenol and m-nitrophenol by a Pseudomonas putida. J Agric Food Chem 32(2):238–242. 10.1021/jf00122a015.
Zhang Y, Piao Y, Li Y, . 2013. 4-Nitrophenol induces Leydig cells hyperplasia, which may contribute to the differential modulation of the androgen receptor and estrogen receptor-α and -β expression in male rat testes. Toxicol Lett 223(2):228–235. 10.1016/j.toxlet.2013.09.011.24070737
Zhang Y, Song M, Rui X, . 2015. Supplemental dietary phytosterin protects against 4-nitrophenol-induced oxidative stress and apoptosis in rat testes. Toxicol Rep 2:664–676. 10.1016/j.toxrep.2015.04.007.28962402
Zhang Y, Cao Y, Wang F, . 2016. 4-Nitrophenol induces activation of Nrf2 antioxidant pathway and apoptosis of the germ cells in rat testes. Environ Sci Pollut Res Int 23(13):13035–13046. 10.1007/s11356-016-6470-2.26996915
Zhang H, Taya K, Nagaoka K, . 2017. 4-Nitrophenol (PNP) inhibits the expression of estrogen receptor β and disrupts steroidogenesis during the ovarian development in female rats. Environ Pollut 229:1–9. 10.1016/j.envpol.2017.04.088.28570923